# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- James Adamson, M.D.
  Vice President and Medical Officer for National Accounts
  Arkansas Blue Cross and Blue Shield
  Little Rock, AR
- James D. Cox, M.D.
  Professor
  Department of Radiation Oncology
  Stringer Distinguished Chair in Oncology
  University of Texas M.D. Anderson Cancer Center
  Houston, TX
- David Sturges
  Patient Advocate
  Lung Cancer Foundation of America
  New Ulm, MN
- Lynn Tanoue, M.D.
  Professor of Medicine
  Co-Director, Yale Cancer Center Thoracic Oncology Program
  Yale School of Medicine
  New Haven, CT
- Robert D. Timmerman, M.D.
  Professor of Radiation Oncology and Neurosurgery
  University of Texas Southwestern Medical Center
  Dallas, TX