# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Claudia Bonnell, R.N., M.L.S.; Lisa Garofalo, B.A.; Sarah Godfrey, M.P.H.; David Samson, M.S.; Lisa Sarsany, M.A.; Kathleen Ziegler, Pharm.D.