# Discussion

## Overview

This chapter presents a discussion of the results of the comparative effectiveness review (CER) organized as follows:

- Key Findings
- Strength of Evidence (SOE)
- Relationship of the Findings to Existing Information
- Applicability of the Findings
- Implications for Clinical and Policy Decisionmaking
- Limitations of the CER Process
- Limitations of the Evidence Base
- Research Gaps and Conclusions
- In each of the above-mentioned sections, the results are organized by Key Questions 1, 2, and 3.

## Key Findings

### Key Question 1 Local Nonsurgical Interventions in Medically Inoperable Patients With Stage I Non–Small-Cell Lung Cancer (NSCLC)

- Thirty-five single-arm studies reported clinical benefits and harms associated with the use of three-dimensional radiotherapy (3DRT), proton beam radiotherapy (PBRT), radiofrequency ablation (RFA) and stereotactic body radiotherapy (SBRT) to treat patients with stage I NSCLC who were deemed to be medically inoperable. Clinical benefits included post-treatment overall survival, cancer-specific survival and local control rates. Harms were radiation-induced for 3DRT, PBRT and SBRT and procedural complications for RFA.
- No studies directly compared the relative benefits or harms of the interventions of interest in inoperable stage I NSCLC patients.
- The evidence is insufficient to answer Key Question 1.

### Key Question 2 Local Nonsurgical Interventions in Medically Operable Patients With Stage I NSCLC

- Six single-arm studies reported clinical benefits and harms associated with the use of PBRT and SBRT to treat patients with stage I NSCLC who were deemed to be medically operable. Clinical benefits included post-treatment overal survival, cancer-specific survival and local control rates. Harms were radiation-induced for PBRT and SBRT.
- No studies directly compared the relative benefits or harms of the interventions of interest in medically operable stage I NSCLC patients.
- The evidence is insufficient to answer Key Question 2.

### Key Question 3 Local Nonsurgical Interventions for Inoperable Patients With NSCLC and Symptoms Due to an Endoluminal Lesion

- Six comparative studies reported clinical benefits and harms associated with the use of local nonsurgical therapies (external-beam radiotherapy (EBRT), brachytherapy, laser therapy, photodynamic therapy (PDT) and electrocautery) for palliation in symptomatic inoperable patients with obstructive endoluminal NSCLC. Reported clinical benefits included post-treatment symptom relief and overall survival. Harms were hemoptysis, pneumothorax, radiation bronchitis, bronchoesophageal fistulas and photosensitivity.
- One comparative study was available per treatment comparison. All six comparative studies were of poor quality and therefore the evidence from these studies had a high risk of bias, consistency was unknown, evidence was direct and all were imprecise.
- Evidence from three single-arm studies of debridement and stenting is insufficient to draw conclusions about the effectiveness of those interventions.
- The evidence is insufficient to answer Key Question 3.

## Strength of Evidence

To evaluate the SOE, we used an approach that was specfically developed for the Evidence-based Practice Center program and referenced in the Methods Guide.37 This approach is based on a system developed by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) Working Group.43 This system explicitly addresses four required domains: risk of bias, consistency, directness, and precision, as outlined in the Methods section.

### Key Question 1

As shown in Table 27 below, the overall SOE is insufficient to form conclusions about the comparative beneficial effects or toxicities of 3DRT, PBRT, RFA or SBRT in the treatment of stage I NSCLC in medically inoperable patients. Direct outcomes of interest were overall survival, cancer-specific survival, and toxicities.

Table 27 Strength of evidence for local nonsurgical interventions in medically inoperable stage I NSCLC patients

Treatment and Evidence Base | Risk of Bias | Consistency | Directness | Precision | Overall Strength of Evidence
SBRT (22 single-arm studies,17,48,49,53,56–75 total n=1665 patients) | High | Unknown | Indirect | Imprecise | Insufficient
3DRT (7 single-arm studies,50,51,54,55,75–77 total n=240 patients) | High | Unknown | Indirect | Imprecise | Insufficient
PBRT (3 single-arm studies,47,52,79 total n=144 patients) | High | Unknown | Indirect | Imprecise | Insufficient
RFA (1 single-arm study,80 n=19 patients) | High | Unknown | Indirect | Imprecise | Insufficient

3DRT = three dimensional radiotherapy; n = number; NSCLC = non–small-cell lung cancer; PBRT = proton beam radiotherapy; RFA = radiofrequency ablation; SBRT = stereotactic body radiotherapy

Thirty-five single-arm studies were available. The risk of bias among the studies was inherently high. The consistency of effect size direction cannot be determined in the absence of comparative studies, so this domain was deemed unknown. No direct comparative evidence is available among interventions, so this domain was deemed indirect. Because precision cannot be determined in the absence of direct comparative evidence among interventions, we deemed the evidence to be imprecise.

### Key Question 2

As shown in Table 28, the overall SOE is insufficient to form conclusions about the comparative benefical effects or toxicities of PBRT or SBRT in the treatment of stage I NSCLC in medically operable patients. Direct outcomes of interest were overall survival, cancer-specific survival, and toxicities.

Table 28 Strength of evidence for local nonsurgical interventions in medically operable stage I NSCLC patients

Treatment and Evidence Base | Risk of Bias | Consistency | Directness | Precision | Overall Strength of Evidence
SBRT (5 single-arm studies,48,49,81–83 total n=378) | High | Unknown | Indirect | Imprecise | Insufficient
PBRT (1 single-arm study,47 total n=28) | High | Unknown | Indirect | Imprecise | Insufficient

n = number; NSCLC = non–small-cell lung cancer; PBRT = proton beam radiotherapy; SBRT = stereotactic body radiotherapy

Six single-arm studies were available. The risk of bias among the studies was inherently high. The consistency of effect size direction cannot be determined in the absence of comparative studies, so this domain was deemed unknown. No direct comparative evidence is available among interventions, so this domain was deemed indirect. Because precision cannot be determined in the absence of direct comparative evidence among interventions, we deemed the evidence to be imprecise.

### Key Question 3

Overall, evidence from five randomized controlled trials (RCTs) and one nonrandomized comparative study is insufficient to form conclusions about the benefits (symptom relief, survival) and harms (treatment-related toxicities) of local nonsurgical therapies (brachytherapy plus EBRT versus brachytherapy alone; brachytherapy plus EBRT versus EBRT alone; brachytherapy versus EBRT; laser plus brachytherapy versus laser alone; laser versus electrocautery or PDT) in symptomatic inoperable patients with obstructive endoluminal NSCLC.

Evidence from three single-arm studies of debridement and stenting is insufficient to draw conclusions about the effectiveness of those interventions.

#### Strength of Evidence

##### Brachytherapy Plus EBRT Versus Brachytherapy Alone

The evidence for comparison of brachytherapy plus EBRT versus brachytherapy alone comprised of one small RCT85 (n=45, 15 patients per treatment arm). This trial was considered to have a high risk of bias because it failed to provide details of randomization and allocation concealment. The consistency of the evidence was unknown as it was a single RCT without confirmation from any other study. The outcomes measured in the study – symptom relief, quality of life (QOL) and treatment-related toxicities were all direct. The evidence for symptom relief, QOL and treatment-related toxicities was imprecise.

Because the evidence base that addressed these outcomes consisted of one RCT, the starting level of SOE was high (Table 29). SOE was reduced by one level each based on the high risk of bias, unknown consistency and imprecision. Therefore, compared to brachytherapy alone, the SOE that brachytherapy plus EBRT improves symptom relief, QOL and reduces treatment-related toxicities is insufficient.

Table 29 Strength of comparative evidence for local nonsurgical therapies for symptoms secondary to an inoperable obstructive endoluminal NSCLC

Treatment and Evidence Base | Outcome | Unit of Measure | Risk of Bias | Consistency | Directness | Precision | SOE
Brachytherapy plus EBRT versus brachytherapy alone (1 RCT, n=45)85 | Symptom relief | Incidence and response rate | High | Unknown | Yes | Imprecise | Insufficient
Brachytherapy plus EBRT versus brachytherapy alone (1 RCT, n=45)85 | QOL | EORTC QLQ-C30 & LC 13 V3.0 | High | Unknown | Yes | Imprecise | Insufficient
Brachytherapy plus EBRT versus brachytherapy alone (1 RCT, n=45)85 | Treatment toxicity | Incidence of Grade ≥II RTOG morbidity scoring scriteria | High | Unknown | Yes | Imprecise | Insufficient
Brachytherapy plus EBRT versus EBRT alone (1 RCT, n=95)86 | Symptom relief | Response rate | High | Unknown | Yes | Imprecise | Insufficient
Brachytherapy plus EBRT versus EBRT alone (1 RCT, n=95)86 | Survival | Overall survival | High | Unknown | Yes | Imprecise | Insufficient
Brachytherapy plus EBRT versus EBRT alone (1 RCT, n=95)86 | Treatment toxicity | Incidence | High | Unknown | Yes | Imprecise | Insufficient
Brachytherapy versus EBRT (1 RCT, n=99)87 | Symptom relief | % improvement | High | Unknown | Yes | Imprecise | Insufficient
Brachytherapy versus EBRT (1 RCT, n=99)87 | Survival | Overall survival | High | Unknown | Yes | Precise | Insufficient
Brachytherapy versus EBRT (1 RCT, n=99)87 | Treatment toxicity | Incidence | High | Unknown | Yes | Imprecise | Insufficient
Nd-YAG plus Brachytherapy versus Nd-YAG alone (1 RCT, n=29)88 | Symptom relief | Speiser’s index | High | Unknown | Yes | Imprecise | Insufficient
Nd-YAG plus Brachytherapy versus Nd-YAG alone (1 RCT, n=29)88 | Survival | Overall survival | High | Unknown | Yes | Imprecise | Insufficient
Nd-YAG plus Brachytherapy versus Nd-YAG alone (1 RCT, n=29)88 | Treatment toxicity | Incidence | High | Unknown | Yes | Imprecise | Insufficient
Photodynamic Therapy versus Laser (1 RCT, n= 31)89 | Survival | Overall survival | High | Unknown | Yes | Precise | Insufficient
Photodynamic Therapy versus Laser (1 RCT, n= 31)89 | Treatment toxicity | Incidence | High | Unknown | Yes | Imprecise | Insufficient
Nd-YAG versus Electrocautery (1 NRC, n=29)90 | Survival | Mean survival | High | Unknown | Yes | Imprecise | Insufficient
Nd-YAG versus Electrocautery (1 NRC, n=29)90 | Symptom relief | % response | High | Unknown | Yes | Imprecise | Insufficient

BT = brachytherapy; EBRT = external beam radiotherapy; EORTC QLQ = European Organization for Research and Treatment of Cancer Quality of Life Questionnaire; KQ = Key Question; n = number; N = total sample size of the study; Nd-YAG = neodymium-doped yttrium aluminum garnet; NSCLC = non–small-cell lung cancer; NRC = nonrandomized comparative study; QOL = quality of life; RCT = randomized controlled trial; RTOG = Radiation Therapy Oncology Group; SOE = strength of evidence

##### Brachytherapy Plus EBRT Versus EBRT Alone

The evidence for comparison of brachytherapy plus EBRT versus EBRT alone comprised of one small RCT86 (n=95). This trial was considered to have a high risk of bias primarily because the trial was discontinued prematurely due to lack of patient accrual and was underpowered to detect a difference in the rate of primary endpoint (rate of dyspnea). The consistency of the evidence was unknown as it was a single RCT without confirmation from any other study. The outcomes measured in the study – symptom relief, survival and treatment-related toxicities were all direct. The evidence for symptom relief, survival and treatment-related toxicities was imprecise.

Because the evidence base that addressed these outcomes consisted of one RCT, the starting level of SOE was high. SOE was reduced by one level each based on the high risk of bias, unknown consistency and imprecision. Therefore, compared to EBRT alone, the SOE that brachytherapy plus EBRT improves symptom relief, survival and reduces treatment-related toxicities is insufficient.

##### Brachytherapy Versus EBRT

The evidence for comparison of brachytherapy versus EBRT comprised of one small RCT87 (n=99). This trial was considered to have a very serious risk of bias because the study failed to adjust for potential confounding secondary to crossover of a large proportion of patients between treatment arms during the trial period. The consistency of the evidence was unknown as it was a single RCT without confirmation from any other study. The outcomes measured in the study – symptom relief, survival and treatment-related toxicities were all direct. The evidence for symptom relief and treatment-related toxicities was imprecise while the evidence for survival was precise.

Because the evidence base that addressed these outcomes consisted of one RCT, the starting level of SOE was high. SOE was reduced by two levels based on very serious risk of bias, by one level for unknown consistency and by one level for imprecision (only for symptom relief and treatment toxicity). Therefore, compared to EBRT, the SOE that brachytherapy improves symptom relief, survival and reduces treatment-related toxicities is insufficient.

##### Laser Plus Brachytherapy Versus Laser Alone

The evidence for comparison of laser plus brachytherapy versus laser alone comprised of one small RCT88 (n=29). This trial was considered to have a high risk of bias primarily due to failure to provide details of randomization, allocation concealment and NSCLC staging of patients at the baseline. The consistency of the evidence was unknown as it was a single RCT without confirmation from any other study. The outcomes measured in the study—symptom relief, survival and treatment-related toxicities—were all direct. The evidence for symptom relief, survival and treatment-related toxicities was imprecise.

Because the evidence base that addressed these outcomes consisted of one RCT, the starting level of SOE was high. SOE was reduced by one level each based on the high risk of bias, unknown consistency and imprecision. Therefore, compared to laser alone, the SOE that laser plus brachytherapy improves symptom relief, survival and reduces treatment-related toxicities is insufficient.

##### Laser Versus Photodynamic Therapy

The evidence for comparison of laser versus PDT comprised of one small RCT89 (n=31). This trial was considered to have a serious risk of bias primarily because the treatment arms had imbalances at the baseline. The proportion of patients with stage III–IV cancer was much smaller in the PDT group (57%, 8 of 14) than the laser group (88%, 15 of 17) at the baseline. The consistency of the evidence was unknown as it was a single RCT without confirmation from any other study. The outcomes measured in the study–survival and treatment-related toxicities were all direct. The evidence for treatment-related toxicities was imprecise while it was precise for survival.

Because the evidence base that addressed these outcomes consisted of one RCT, the starting level of SOE was high. SOE was reduced by two levels based on very serious risk of bias, by one level for unknown consistency and by one level for imprecision (only for treatment-related toxicity). Therefore, compared to PDT, the SOE that laser therapy improves survival and reduces treatment-related toxicities is insufficient.

##### Laser Versus Electrocautery

The evidence for comparison of laser versus electrocautery comprised of one small nonrandomized comparative study90 (n=29). This study was considered to have serious risk of bias primarily because of lack of adjustment for any potential confounders. A disproportionate number of patients had received previous treatment in the laser treated group (93 percent) as compared with the electrocautery group (53 percent). Further, the mean time from diagnosis to study treatment was different in the two groups (4.7 versus 7.5 months in laser versus electrocautery group). The consistency of the evidence was unknown as it was a single nonrandomized comparative study without confirmation from any other study. The outcomes measured in the study–survival and symptom relief were direct. The evidence for symptom relief and survival was imprecise.

Because the evidence base that addressed these outcomes consisted of one nonrandomized comparative study, the starting level of SOE was low (Table 30). SOE was reduced by two levels based on very serious risk of bias and by one level each for unknown consistency and imprecision. Therefore, compared to electrocautery, the SOE that laser therapy improves survival and symptom relief is insufficient.

Table 30 Strength of noncomparative evidence for local nonsurgical therapies for symptoms secondary to an inoperable obstructive endoluminal NSCLC

Treatment and Evidence Base | Risk of Bias | Consistency | Directness | Precision | Overall Strength of Evidence
RFA (1 study, n=33)91 | High | Unknown | Indirect | Imprecise | Insufficient
BT + STNT (1 study, n=10)92 | High | Unknown | Indirect | Imprecise | Insufficient
LASR + STNT (1 study, n=52)93 | High | Unknown | Indirect | Imprecise | Insufficient

BT = brachytherapy; LASR = laser; n = total sample size of the study; NSCLC = non–small-cell lung cancer; RFA = radiofrequency ablation; STNT = stenting

## Relationship of the Findings to Existing Information

### Key Questions 1 and 2

We sought credible sources of evidence-based information on the use of the local nonsurgical interventions assessed in this CER to treat stage I NSCLC. We identified a recent systematic review that examined the effectiveness of SBRT among patients with severe chronic obstructive pulmonary disease.17 The authors of that review reported limited, noncomparative published data are available to assess outcomes in this setting. An Agency for Healthcare Research and Quality (AHRQ) Technical Brief reported on the state of the evidence for SBRT in a number of cancers, including NSCLC.104 The authors of this Technical Brief did not identify any published RCTs or other comparative studies that compared SBRT to another modality. Our systematic literature search and review did not reveal any relevant evidence-based guidelines we could compare to our findings. Our report offers the first comprehensive systematic review on this topic.

### Key Question 3

This systematic review sought RCTs that compared local nonsurgical bronchoscopic interventions in patients with an endobronchial NSCLC. We found five RCTs of poor quality and one nonrandomized comparative study that compared six unique combinations of bronchoscopic interventions in NSCLC patients. Evidence is insufficient to conclude relative benefits and harms of one therapy over another for the following six interventions:

- Brachytherapy plus EBRT versus brachytherapy alone
- Brachytherapy plus EBRT versus EBRT alone
- Brachytherapy versus EBRT
- Laser plus brachytherapy versus laser alone
- Laser versus electrocautery
- Laser versus PDT

Evidence from three single-arm studies of debridement and stenting is insufficient to draw conclusions about the effectiveness of those interventions.

We found one Cochrane systematic review34 that compares endobronchial brachytherapy with palliative intent for NSCLC patients with other available treatments including EBRT, other bronchoscopic interventions, chemotherapy or best supportive care. The Cochrane review included only RCTs with only metastatic or advanced (stage IIIb and IV) NSCLC patients. The strength of this review is its broader scope as it included all NSCLC stages patients including recurrent patients. Further, we addressed all possible combination of local nonsurgical bronchoscopic therapies and all possible study designs except for case reports. However, unlike the Cochrane review, the present review excluded all studies published prior to 1995 and did not include data from studies that were published as abstracts only.

In concurrence with our findings, the Cochrane review also agreed that the evidence did not provide conclusive results that endobronchial brachytherapy plus EBRT improved symptom relief compared with EBRT alone or there was any conclusive evidence to recommend endobronchial brachytherapy in combination with EBRT, chemotherapy or laser therapy.

The second edition of American College of Chest Physicians (ACCP) Evidence Based Clinical Practice Guidelines105 for palliative care of lung cancer patients relevant in part to the current context of local nonsurgical bronchoscopic interventions for endoluminal obstruction in NSCLC patients. These guidelines describe the general landscape of palliative bronchoscopic therapies including mechanical debridement, laser, argon plasma coagulation, brachytherapy, cryotherapy, balloon dilatation, PDT, electrocautery and stenting. The ACCP guidelines105 state that all such interventions provide significant relief from dyspnea and hemoptysis in majority of patients but do not discuss comparative effectiveness (harms and benefits) of these therapies. The guideline recommends treatment with appropriate therapies (Grade 1C) for all lung cancer patients who complain of dyspnea with a potentially correctable cause. These guidelines also state that in all lung cancer patients with large volume hemoptysis, bronchoscopic evaluation of source of bleeding followed by endobronchial management options such as argon plasma coagulation, laser and electrocautery is recommended (Grade 1C).

## Applicability of the Findings

### Key Questions 1 and 2

In general, applicability assessment would depend on a body of evidence sufficient to permit conclusions about the comparative outcomes of local nonsurgical therapies for stage I NSCLC. The evidence for Key Questions 1 and 2 does not reach that level, so we have primarily limited comments to relevance of the PICOTS (Population, Intervention, Comparator, Outcomes, Timing, Setting) elements.46 The PICOTS format comprises a practical and useful structure to review applicability in a systematic manner. These factors are summarized in Table 31 for Key Questions 1 and 2.

Table 31 Summary of applicability of evidence for Key Questions 1 and 2

Domain | Applicability of Evidence
Populations | - Overall, the patients included in the single-arm studies were not suitable for surgery, or were suitable for surgery but declined it.; - The patients with stage I NSCLC in the studies included in this report appear representative of cases that would be considered for a local nonsurgical intervention.; - Patients typically were in their late 60s to mid-70s, congruent with the incidence of stage I NSCLC that tends to rise with age.; - The medically inoperable patients of KQ1 had compromised cardiopulmonary reserves or other comorbidities that preclude surgical resection.; - The medically operable patients of KQ2 were often not substantially different from the inoperable population of KQ1, but neither are considered as healthy as the population that undergoes surgery.
Interventions | - 3DRT, IMRT and SBRT represent different technological approaches to the delivery of conformal photon radiotherapy. The major advantage of these interventions as compared to traditional wide-field 2DRT is the ability to deliver tightly focused cytotoxic radiation by delineating the shape and size of the tumor using a CT-based or other imaging planning system.; - 3DRT represents a minimum technical standard for delivery of conformal radiotherapy. It involves static fields with a fixed shape, modified by compensators (wedges and segments). 3DRT is widely available.; - IMRT offers beam strength attenuation through a multileaf collimator (tungsten), with dynamic field shapes for each beam angle. IMRT is not as widely available as 3DRT, and requires a higher level of inverse planning and quality assurance.; - SBRT is a hypofractionated technique administered in 5 or fewer fractions; 3DRT and IMRT typically deliver radiation in many more fractions than SBRT.; - SBRT is not as widely available as 3DRT or IMRT but its use is growing. It may soon supplant other technologies in the KQ1 and KQ2 settings. The institutional programmatic requirements for SBRT are similar to those of IMRT.; - This CER did not allow for a rigorous and systematic comparison of the relative performance of local nonsurgical therapies stratified by technological factors. The impact of these factors factors on health outcomes remains unclear.; - The applicability of the evidence for PBRT and RFA is unknown due to limited evidence.
Comparators | - See above for Intervention
Outcomes | - The major health outcomes in this CER are OS, CSS, and LCT, typically reported over a period of one to five years.; - OS is the primary direct outcome for any cancer intervention study.; - CSS reflects the absolute effect of a cancer intervention on the disease. CSS is a highly relevant direct outcome in the KQ1 practice setting in that such patients are generally fragile and susceptible to succumbing to underlying comorbidities. Its relevance in KQ2 patients may be slightly less than in KQ1 as the former may be relatively healthier than the latter, but still not as healthy as good surgical candidates.; - LCT is of interest to patients because it measures the effectiveness of an intervention in disease control. Upon local failure, patients enter into a new category centered on systemic chemotherapy. This is a potentially perilous position for the medically frail patients considered in KQ1, and perhaps many of those in KQ2.
Timing | - The relevant periods occur at the time of treatment through followup over months (palliation) or years (overall survival).
Setting | - The evidence for KQ1 and KQ2 is international, primarily obtained in tertiary institutional settings. More sophisticated interventions such as IMRT and SBRT require an institutional commitment to quality assurance and on-going training that may be difficult to achieve in smaller community-based centers.; - We did not collect or analyze information to examine these issues.

2DRT = two-dimensional radiotherapy; 3DRT = three-dimensional radiotherapy; CER = comparative effectiveness review; CSS = cancer-specific survival; CT = computer tomography; IMRT = intensity-modulated radiotherapy; KQ = Key Question; n = number; LCT = local control; NSCLC = non–small-cell lung cancer; OS = overall survival; PBRT = proton beam radiotherapy; RFA = radiofrequency ablation; SBRT = stereotactic body radiotherapy

The degree to which the data presented in this report are applicable to clinical practice is a function of the similarity between populations in the included studies and the patient population that receives clinical care in diverse settings. It also is related to the relative availability of the interventions. The literature base is observational, lacking comparative evidence. Case series are descriptive studies that are limited in their ability to control for biases. Selection bias is of particular concern as patients receive treatment based on clinician preferences, center resources, patient characteristics and preference rather than random allocation. This evidence base is therefore insufficient to support any attempt to draw comparative conclusions.

### Key Question 3

Multiple shortcomings with the current evidence base preclude interpretation about general applicability. Firstly, the comparative benefits and harms of various endobronchial treatments are still unknown because of lack of good quality RCTs. The available studies were all poor quality, often small and not powered to detect a prespecified clinically meaningful difference in a standardized outcome of interest. Secondly, patient characteristics were poorly defined. The majority of studies did not report performance status and therefore it is difficult to assess the relative health and activity level of these patients and to whom this limited evidence applies. Thirdly, there was a wide variation in the outcomes measures to report symptom relief in the current studies. Fourthly, many studies did not report the frequency, the process or the method of assessing severity of treatment-related toxicities and therefore the true harms associated with these interventions are likely to be underrepresented in the current data. Factors that affect the applicability of the findings of this CER to practice are summarized in Table 32.

Table 32 Summary of applicability of evidence for Key Question 3

Domain | Applicability of Evidence
Populations | - The patients in the studies included in this report appear representative of cases that would be considered for a bronchoscopic intervention. All patients included in the 6 studies had histologically confirmed NSCLC with airway obstruction that required a bronchoscopic intervention. The mean age of patients included in these studies ranged from 61–68 years and this is congruent with the incidence of NSCLC that tends to rise with age.
Interventions | - The single modality interventions (brachytherapy, EBRT, electrocautery, laser, photodynamic, debridement, stenting) and 2 dual modality interventions (laser plus brachytherapy and brachytherapy plus EBRT) represent a general landscape of current treatments options for patients with endoluminal obstructive NSCLC and therefore are applicable.
Comparators | - See above for Intervention
Outcomes | - The major outcomes of interest were symptom relief, overall survival, disease specific survival, quality of life and treatment-related toxicity.; - Although OS is the primary direct outcome for any cancer intervention study, it may not be the best measure of efficacy of a palliative intervention in symptomatic patients. Immediate relief of obstructive symptom and improvement in quality of life provide reasonable and pertinent justification for use of endobronchial intervention in such patients.; - According to the structured review by the Patient Reported Outcome Measurement Group-Oxford on the use of PROMs (Patient Reported Outcomes Measures),106 both generic and disease specific instruments exists that can be used in patients with lung cancer to assess the impact of interventions on QOL. These measures include generic measures such as SF-36 and EQ-5D and lung cancer specific measures such as EORTC QLQ-C30, EORTC QLQ-LC13 and FACT-L. However, QOL data was reported only by one small study of the six comparative studies. Therefore, applicability of the current evidence base on QOL cannot be determined.
Timing | - The relevant periods occur at the time of treatment through followup over months (palliation) or years (overall survival).
Setting | - The outcomes of local bronchoscopic therapies largely depend on the expertise of the provider and the center providing these services. We could not assess the impact of such operating characteristics on the treatment outcomes because these data were not available in the published papers.

EBRT = external-beam radiotherapy; EORTC QLQ = European Organization for Research and Treatment of Cancer Quality of Life Questionnaire; EQ-5D = EuroQOL 5 dimension; FACT-L = Functional Assessment of Cancer Therapy-Lung; NSCLC = non–small-cell lung cancer; QOL = quality of life; SF-36 = Short Form 36 Health Survey

## Implications for Clinical and Policy Decisionmaking

Our results show no direct comparative evidence to support a decision among 3DRT, PBRT, RFA, or SBRT in stage I NSCLC patients. Comparative evidence is sparse among any of the interventions considered in Key Question 3.

In the absence of adequate direct comparative effectiveness data, other factors may be considered in making a treatment decision. Those could include relative convenience, and cost. The latter is outside the scope of this CER. Relative convenience would entail treatment duration and availability or access to a technology. Treatment duration can be substantially different for the interventions considered in Key Questions 1 and 2. It may reach 3 weeks or more for 3DRT or intensity-modulated radiation therapy (IMRT), compared with a week or less for SBRT or RFA. The availability of a technology locally, as opposed to a distant tertiary center, may be very relevant to NSCLC patients who are often elderly and perhaps debilitated by underlying comorbidities. According to the National Association for Proton Therapy (www.proton-therapy.org), PBRT is available for NSCLC therapy at 10 specialized centers in the United States, with seven under development. Thus, PBRT would be a limited choice for a large proportion of NSCLC patients.

Although we did not formally examine this issue, the body of published literature we identified for this CER suggests interest in SBRT has been growing over the past several years. It may be poised to supplant earlier conformal radiotherapy modalities in treating stage I NSCLC. This view is congruent with results of a recent survey of 1,600 radiation oncologists regarding SBRT use in the U.S.107,108 The survey results indicated nearly 64 percent (95% confidence interval [CI], 60–68%) of radiation oncologists use SBRT in their practice, among whom about 50 percent adopted it in 2008 or later. Among SBRT users in this survey, 89 percent used it to treat lung cancer patients.

From the institutional perspective, decisionmakers may face pressures on acquisition that blend considerations of awareness and demand by referring physicians and patients with marketing and competition issues. These may lead to acquisition of one technology over another regardless of the availability of evidence of comparative effectiveness. Clinical uncertainties for all three Key Questions were a driver of development of this CER. Its findings ideally would provide a foundation for critically considering each technology in terms of the evidence available. However, it is unclear whether this CER will ultimately affect policy decisions.

## Limitations of the Comparative Effectiveness Review Process

At the time of initiation of this CER, we expected that the total evidence base would be substantial. The volume of literature identified in the AHRQ Topic Development and Refinement process suggested the existence of a robust evidence base for all Key Questions. However, when we began to screen articles, it became evident that very few published comparative studies exist overall, none for Key Questions 1 and 2 and only six for Key Question 3.

## Limitations of Evidence Base

### Key Questions 1 and 2

The primary limitation is lack of comparative trials of any design for Key Questions 1 and 2. Percutaneous image-guided RFA has been investigated as an option for the treatment of stage I NSCLC. In our review, we found that RFA studies in lung primarily comprise heterogeneous case series that are complicated by several factors. First, many reports included metastatic and primary lesions from non-lung and lung sites, but did not stratify outcomes such as overall survival according to tumor stage or type. Second, the technical details of RFA, such as the type of equipment used, the power settings or wattage delivered, and details of followup assessment and subsequent therapy, were not consistent or consistently reported across studies. These factors conspired to severely limit RFA study selection in the report.

Although the body of evidence we included for the conformal radiotherapy techniques, particularly SBRT, was more substantial in quantity than for RFA, we have similar concerns about inter-study heterogeneity, with variability in radiotherapy dose, schedule of treatment, patient selection criteria, tumor size and location, and so forth. In a systematic review in general, heterogeneous, noncomparative evidence makes it very difficult to assess the benefits and harms of any intervention. In this CER, the type of evidence we identified for Key Questions 1 and 2 precludes comparative assessment among the interventions we investigated. We therefore believe further careful study of the interventions we considered in this CER is needed in the settings of Key Question 1 or 2 to identify optimal technical protocols and patient selection criteria, perhaps standardizing and comparing them across institutions. These data and methods could in theory be applied to the design and conduct of comparative studies of the local nonsurgical interventions for stage I NSCLC, as outlined in the Research Gaps section below.

### Key Question 3

The body of evidence available for Key Question 3 comprised five RCTs, one nonrandomized comparative study and three relevant single arms from three otherwise comparative studies. We included the latter three study arms because we did not have higher level evidence for the interventions in question, debridement and stenting. Significant limitations in the quality and quantity of the evidence base led us to conclude that the evidence was insufficient to make conclusions about comparative effectiveness of local nonsurgical interventions to treat endobronchial obstructions in NSCLC patients. There was only one comparative study available per six unique treatment comparisons to draw inferences about comparative effectiveness. Therefore the consistency domain for SOE was unknown. All six studies received a low U.S. Preventive Services Task Force (USPSTF) study quality; often the studies were small and not powered to detect a prespecified clinically meaningful difference in a standardized outcome of interest thereby limiting their utility beyond hypothesis generation. Most studies lacked details about randomization and allocation concealment. The one nonrandomized comparative study available for Key Question 3 did not use statistical adjustment to reduce confounding; such adjustment for confounding should be consistently used in nonrandomized studies.

## Research Gaps

### Overview

Key Question 1 considers the relative clinical effectiveness of local nonsurgical interventions—3DRT, SBRT, PBRT and RFA—as sole therapy for patients with stage I NSCLC who are deemed to be medically inoperable. Key Question 2 addresses the same set of interventions in patients with stage I NSCLC who are deemed operable but who decline resection. The evidence base for Key Questions 1 and 2 comprises single-arm studies. The largest body of evidence is on SBRT, which suggests it may be gaining status among clinicians as a preferred treatment in patients with stage I disease. However, we did not identify evidence that supports one intervention relative to any other. Overall, the SOE is insufficient to draw conclusions on the comparative effectiveness of the interventions in terms of overall survival or cancer-specific survival.

Key Question 3 compared outcomes of available local endobronchial interventions used with curative or palliative intent to treat airway obstruction. There was only one comparative study available per six unique treatment comparisons to draw inferences about comparative effectiveness. Evidence on the patient outcomes was limited and, as such, is insufficient to make conclusions on the comparative effectiveness of the interventions in terms of symptom relief, overall survival or cancer-specific survival and harms of the treatment.

### Key Questions 1 and 2

The primary research gap we identified in preparing this CER is the lack of evidence from comparative studies to draw conclusions as to the relative clinical benefits and harms of the local nonsurgical interventions used in the stage I NSCLC setting of medically inoperable or operable patients. We have also identified some feasibility issues associated with the interventions that are potential impediments to the type of rigorous comparative studies we suggest are necessary to determine their comparative effectiveness. In this section, we first describe characteristics of ideal comparative studies we believe are needed to compare these technologies. The potential impediments to such studies are discussed subsequently in this section.

#### Lack of Clinical Trial Evidence on Local Nonsurgical Interventions for Stage I NSCLC

We found no direct comparative evidence in this CER on the relative clinical effectiveness among any of the local nonsurgical interventions we evaluated: RFA, SBRT, 3DRT, IMRT or PBRT. As part of this review, we searched for ongoing clinical trials of these technologies in stage I NSCLC. In the process, we identified two international randomized, phase 3 clinical trials of surgical resection versus SBRT that are recruiting patients (NCT01336894 and NCT 00840749). However, neither of these trials will reveal relative outcomes among local nonsurgical interventions in stage I NSCLC. Thus, we suggest prospective studies are needed to properly evaluate the relative clinical benefits and harms of the technologies evaluated in this CER, taking into account the potential impediments to study we discuss below. Ideally, comparative studies in medically inoperable or operable stage I NSCLC patients would incorporate the following:

- To assure comparability of patients and minimize bias, standardized patient selection criteria would be used that involve consultation including a thoracic surgeon, medical oncologist, and radiation oncology specialist. Key factors to consider include comorbidity status (particularly cardiopulmonary function and capacity), age, performance status, tumor size and tumor location.
- Standardized intervention protocols with training and quality assurance programs within and across participating institutions are necessary for the best study. For radiotherapy, key factors would include the imaging and planning method, immobilization method, dose and fractionation schedule, and the biologically effective dose (BED) for comparisons of different modalities (e.g., SBRT, 3DRT, IMRT, PBRT). For RFA, issues would include treatment power and duration in the context of tumor size and location.
- Prespecified followup criteria and methods, in particular notation of subsequent systemic therapy administered at recurrence, are key considerations. Subsequent systemic therapy is a key concern because it is impossible to discern the effect of an intervention followed by systemic therapy at progression from that achieved with the intervention alone. Is the effectiveness a function of the systemic therapy, the intervention, or the combination?
- Rigorous and standardized reporting is needed to account for all patients and treatments received. Data for operable and inoperable patients would be reported separately. Rigorous methods for conduct of RCTs is urged, particularly intent-to-treat analysis and adjustment of survival data to account for patients who develop recurrent disease and subsequently receive systemic chemotherapy as part of their treatment plan.
- Primary outcomes would include overall survival, cancer-specific survival, and local control. Prespecified, systematic collection of adverse events (AEs) using validated criteria (e.g., CTCAE criteria) is necessary to permit accurate assessment of relative benefits and risks of the interventions.

#### Potential Impediments to Comparative Studies of Local Nonsurgical Interventions for Stage I NSCLC

The general dissemination of conformal radiotherapy technologies into community clinical practice, most lately and specifically SBRT 107,108 is a potential impediment to comparative study of those technologies. Published survey results show that nearly 40 percent of solo practitioners treat patients with SBRT, which suggests that this technology is now accessible and its efficacy accepted in the broader radiation oncology community.107,108 In addition, the shorter hypofractionated SBRT course is more “patient friendly” than those associated with conventionally fractionated conformal radiotherapy methods. This patient-specific advantage may represent an additional reason why SBRT has rapidly disseminated into clinical practice in the absence of direct comparative clinical trial evidence to support its reputation of clinical superiority over conventionally fractionated conformal techniques. We also recognize a number of other significant – perhaps insurmountable – technical impediments to conducting adequate comparative studies among the most widely available conformal radiotherapy-based modalities and other interventions such as RFA. These are outlined below.

Practical limitations exist to complicate comparative study of RFA and the conformal radiotherapy modalities in the stage I NSCLC setting. Although we did not evaluate these issues in this CER, it is generally thought that a tumor size greater than 4 cm, or a tumor location less than 1 cm from the hilum or large vessels, preclude the use of RFA.28,109 Current clinical wisdom suggests RFA is best suited for patients with peripherally located, smaller lesions, due to the “heat sink” effect of large blood vessels that dissipates heat from the tumor and reduces its efficacy.109–111 By contrast, although we didn’t investigate any relationship in our systematic review, conformal radiotherapy-based modalities, particularly SBRT, have been used in patients with either peripheral or central tumors, as well as tumors > 4 and up to 7 cm in diameter, the latter corresponding to stage IB (T2N0M0).4 Furthermore, radiotherapy effectiveness is not subject to a “heat sink” effect, as is RFA. Given those caveats, recruitment and accrual of sufficient numbers of similar stage I NSCLC patients to make clinically meaningful, relevant comparisons between RFA or conformal radiotherapy-based treatments would be difficult.

A key technical issue in comparing the radiotherapy interventions likely is the significant difference in the BED of radiation that can be safely delivered by SBRT, compared to IMRT or 3DRT delivered with conventional fractionation protocols. In brief, radiation therapy for NSCLC typically is delivered to a total dose of 60–70 Gray (Gy); SBRT delivers that dose in three to five fractions of 20 Gy each (estimated BED = 180 Gy_10_ using standard principles) whereas conventionally fractionated IMRT or 3DRT delivers 60–70 Gy in 30 fractions of 2 Gy each in 4 to 5 weeks, yielding an estimated BED of 72 Gy_10_. The difference in the attainable BED is considered to have potential efficacy implications.112 The higher BED causes tumor ablation, rather than tumor cell kill, allowing for little to no tumor cell repopulation between doses of radiation.

In this CER, we did not systematically investigate whether a higher BED delivered by any conformal radiotherapy modality can be associated with better clinical outcomes - such as overall survival - compared to a lower BED. This has been reported in published single-arm studies reviewed in this CER, for example the large, multicenter, retrospective series on SBRT in Japan by Onishi and colleagues.84 However, we are not aware of any direct comparative evidence on this topic among any of the conformal radiotherapy technologies, so it is not possible to make even indirect comparisons between the delivered BED and clinical outcomes in any case. Furthermore, we are aware of no published clinical trial evidence to ascertain whether a higher BED delivered by SBRT is associated with differences in patient outcomes compared to a lower BED delivered either by SBRT or by a conventionally fractionated conformal radiotherapy modality. We acknowledge the difference in delivered BED has biologically plausible clinical implications, and perhaps ethical implications, that would need to be addressed in designing a study of any type to compare conformal radiotherapy-based technologies. But, it is not clear to us that the BED issue under discussion here is settled.

In summary, we acknowledge the views of some members of the radiation oncology and interventional radiology communities - that clinical trials of local nonsurgical modalities, including RFA, SBRT and other conformal radiotherapy modalities (e.g., 3DRT, IMRT, PBRT) in stage I NSCLC patients may be very difficult to recruit and conduct, based on technical and potential ethical issues related to perceptions of unequal clinical benefit among the interventions. However, we maintain that current evidence is insufficient to support a view that clinical outcomes achieved with one technology are superior or inferior to those achieved with other modalities. Clinical evidence from comparative studies is needed to establish the standard of care for local nonsurgical treatment of stage I NSCLC patients.

### Key Question 3

#### Lack of Clinical Trial Evidence on Local Nonsurgical Interventions for Endoluminal Obstructive NSCLC

Key Question 3 compared outcomes of available local endobronchial interventions used with curative or palliative intent to treat airway obstruction as a result of NSCLC. Evidence on the patient outcomes is limited and, as such, is insufficient to make conclusions. We identified a number of research gaps during the course of review:

- Lack of comparative evidence generated from adequately powered RCTs regarding the benefits and harms of various bronchoscopic interventions used for treating endoluminal obstructions in patients with NSCLC.
- Lack of comparative evidence generated from good quality RCTs regarding the QOL data from patients who receive various bronchoscopic interventions used for treating endoluminal obstructions in patients with NSCLC.
- Need for systematic collection of treatment-related toxicities data from various bronchoscopic interventions used for treating endoluminal obstructions from actual clinical practice setting.

During our review, we identified two RCTs that aimed to compare local endobronchial interventions in patients with endobronchial NSCLC. However, both these trials were not completed due to lack of patient accrual. Among these two RCTs, the trial by Moghissi et al.,102 is most notable. The objective of this trial was to compare two treatment policies in terms of symptom relief, respiratory function, performance status, QOL and survival. This study planned to recruit 400 patients in 3 years at 24 clinical centers in the UK. Even though the study organizers had successfully conducted many RCTs in the past, they failed to recruit patients in this clinical setting. Moreover, 20 percent of those randomized did not receive the assigned treatment. Another study by Langendijk86 that randomized patients to brachytherapy plus EBRT or EBRT alone arm was discontinued due to lack of patient accrual before completing the planned enrollment of 160 patients.

#### Potential Impediments to Comparative Studies of Local Nonsurgical Interventions for Endoluminal Obstructive NSCLC

NSCLC patients with endoluminal obstructions are particularly difficult to randomize in trials because of many reasons particularly ethical issues. Most of these bronchoscopic interventions are considered complementary and are used sequentially in a clinical setting113 and therefore randomizing critically ill patients to either therapy alone has ethical implications. Further, many of these patients present with an impending obstruction and immediate symptom relief is foremost. Obtaining informed consent in such a situation is a barrier in patient recruitment. These reasons are likely to obviate successful conduct of a future RCT.

Thus, a prospective cohort study may be able to answer the questions about relative harms and benefits of local endobronchial interventions. Though concerns of selection bias and unknown confounders always exist in this study design, addressing and collecting data about most relevant confounders a priori can provide much needed informative answers about comparative benefits (including QOL data) and harms of these therapies in population of interest. We recommend that the research team for conducting such a study be multi-disciplinary including oncologists experienced in treating NSCLC patients with endobronchial obstruction, methodologist with expertise in quality of life measurement, clinical researchers with expertise in planning and conduct of large cohort multicentric studies and ethicists. Relevant outcomes that would be measured in such a study would include symptom control, QOL, survival and treatment-related AEs. Data related to symptom control would be captured using a standardized validated tool applied uniformly across all interventions. In the current evidence base, Speiser Index was used commonly to assess symptomatic control but the validity and sensitivity of such a tool to capture treatment effect is unknown. Therefore, it is crucial to address and resolve the shortcomings of current tools that are used to asses symptom control to allow objective and uniform measurements of symptom control. Generic instruments such as Short Form 36 Health Survey (SF-36) and EuroQOL 5 dimension (EQ-5D) would be used in conjunction with lung cancer specific measures such as European Organization for Research and Treatment of Cancer Quality of Life Questionnaire (EORTC QLQ) modules C30 and LC13 and Functional Assessment of Cancer Therapy-Lung (FACT-L) to measure QOL data.

Treatment-related AEs would be assessed from the date of the procedure extending to a reasonable time preferably until death using standardized and well-defined criteria with an independent causality analysis. A process to capture AEs that occur when patients are not under direct medical supervision (such as home or long term care facility) would also be prespecified in the study protocol. Data on all potential prognostic covariates would include but not be limited to patient characteristics (age, sex, race, performance status, comorbidities), disease characteristics (tumor stage, histopathology, location, size, blockage) and technical attributes of the procedure (technical success, technical variables related to use of procedures, type of instrument used) as well data on the operator (expertise, years of experience, size of the facility).

Secondly, we propose setting up a registry to systematically collect treatment-related toxicity data for patients undergoing such procedures. According to the AHRQ publication on registries114 for evaluating patient outcomes, registries need to be created with a question in mind which guides the identification of the target population, the exposures and outcomes of interest, number of patients and length of followup. Registries can be designed as an active surveillance system for identifying harms and may be particularly useful for assessing AEs.

## Conclusion

We conducted a systematic review of the literature to evaluate the comparative effectiveness of local nonsurgical therapies in patients with NSCLC. Our review addressed three Key Questions with three distinct categories of patients: those with stage I NSCLC who were deemed medically inoperable (Key Question 1); those with stage I NSCLC who were deemed medically operable (Key Question 2); and those with symptoms secondary to the presence of endoluminal NSCLC (Key Question 3). For Key Questions 1 and 2 we included only single local nonsurgical interventions: 3DRT, PBRT, RFA, and SBRT. For Key Question 3 we allowed combinations of local nonsurgical therapies including neodymium-doped yttrium aluminum garnet (Nd-YAG) laser, PDT, endobronchial debridement with stenting, and EBRT, as well as systemic chemotherapy.

Evidence for both Key Questions 1 and 2 consists only of single-arm studies, with no direct comparisons among interventions. The best evidence for Key Question 3 consists of RCTs of one comparison only, precluding indirect comparisons. Evidence from single-arm studies also is available for several interventions relevant to Key Question 3. For all Key Questions, the evidence was insufficient to reach conclusions about the relative effectiveness and safety of the interventions in terms of overall survival, cancer-specific survival, local control, QOL, symptomatic relief and toxicities.