# Evidence Tables

Appendix Table C1 Description of studies that address Key Question 1

Appendix Table C2 Outcomes and interventions of studies that address Key Question 1

Appendix Table C3 Survival and local control outcomes of studies that address Key Question 1

Appendix Table C4 Miscellaneous outcomes of studies that address Key Question 1

Appendix Table C5 Toxicity outcomes of studies that address Key Question 1

Appendix Table C6 Attributes of studies that address Key Question 1

Appendix Table C7 Description of studies that address Key Question 2

Appendix Table C8 Outcomes and interventions of studies that address Key Question 2

Appendix Table C9 Survival and local control outcomes of studies that address Key Question 2

Appendix Table C10 Miscellaneous outcomes of studies that address Key Question 2

Appendix Table C11 Toxicity outcomes of studies that address Key Question 2

Appendix Table C12 Attributes of studies that address Key Question 2

Appendix Table C13 Description of studies that address Key Question 3

Appendix Table C14 Outcomes and interventions of studies that address Key Question 3

Appendix Table C15 Survival and local control outcomes of studies that address Key Question 3

Appendix Table C16 Miscellaneous outcomes of studies that address Key Question 3

Appendix Table C17 Toxicity outcomes of studies that address Key Question 3

Appendix Table C18 Study attributes - Key Question 3

Appendix Table C19 Carey and Boden assessment tool for Key Questions 1 and 2

Appendix Table C20 Carey and Boden assessment tool for Key Question 3

## Abbreviations Used in This Appendix

Abbreviation: Definition
3DRT: Three dimensional radiation therapy
AC: Adenocarcinoma
ACE-27: Adult Co-Morbidity Evaluation-27 scoring system
BAC: Bronchoalveolar carcinoma
BED: Biologically Effective Dose
BI: Bronchus intermedius
BOI: Bronchial abstraction index
CAD: Coronary Artery Disease
CCI: Charlson Comorbidity Index
CGE: Cobalt Gray equivalent
CHF: Congestive Heart Failure
CI: Confidence interval
COPD: Chronic Obstructive Pulmonary Disease
CPD: Chronic Pulmonary Disease
CSS: Cancer-specific survival
CT: Computed Tomography
CTC: Common Toxicity Criteria
CTCAE: Common Terminology Criteria for Adverse Events
CVD: Cardiovascular disease
CWP: Chest Wall Pain
DLCO: Diffusion Lung Capacity for Carbon Monoxide
DM: Diabetes mellitus
CSS: Disease-specific survival
ECOG: Eastern Cooperative Oncology Group
EORTC: European Organization for Research and Treatment of Cancer
FACT-G: Functional Assessment of Cancer Therapy-General
FDG: Fluorodeoxyglucose
FEV: Forced expiratory volume
FRS: Fractions
FU: Followup
GTV: Gross tumor volume
GY: Gray
HC: Histopathology confirmation
HDR: High-dose-rate
Hst: Histologically
IGRT: Image-Guided Radiotherapy
IMRT: Intensity-modulated radiotherapy
INR: International Normalized Ratio
KFI: Kaplan-Feinstein index
KPS: Karnofsky performance status
LB: Lobar bronchus
LC: Lung cancer
LCC: Large cell carcinoma
LCS: Lung Cancer Subscale
LCT: Local control
LENT-SOMA: Late Effects Normal Tissue Task Force -Subjective, Objective, Management, Analytic scales
LL: Lower lobe
MB: Main bronchus
MCS: Mental Component Summary
MeV: Million electron volts
MI: Myocardial Infarction
ML: Middle lobe
mos: Months
MS: Main stem
N: Number
NA: Not applicable
NCI: National Cancer Institute
NOS: Not otherwise specified Non-Small Cell Lung Cancer
NR: Not reported
NSCC: Non squamous cell lung cancer
NSCLC: Non-small cell lung cancer
NSS: Not statistically significant
OMC: Other Medical Comorbidities
OS: Overall Survival
PCS: Physical Component Summary
PET: Positron Emission Tomography
PHDT: Photodynamic therapy
PFS: Progression-free survival
PRO: Prospective
PS: Performance status
Pts: Patients
PTV: Planning target volume
PVD: Peripheral Vascular Disease
QLQ: Quality of life Questionnaire
QOL: Quality of life
RECIST: Response Evaluation Criteria in Solid Tumors
RET: Retrospective
RFA: Radio-frequency ablation
RT: Radiation Therapy
RTOG: Radiation Therapy Oncology Group
Rx: Treatment
SAS: Single arm study
SB: Superior bronchus
SBRT: Stereotactic body radiotherapy
SCC: Squamous cell carcinoma
SCS: Simplified comorbidity score
SWOG: Southwest Oncology Group
TOI: Trial Outcome Index
UICC: Union Internationale Contre le Cancer
UL: Upper lobe
UNSCLC: Unclassified Non-Small Cell Lung Cancer
WHO: World Health Organization
YAGL: Yttrium aluminum garnet laser