# Excluded Studies

Appendix Table B1 Key to study exclusion coding system

Code | Definition
FLA | Foreign language article
NRD | Not relevant design
NRP | Not relevant population
NRI | Not relevant intervention
NRO | Not relevant outcome
OPP | Overlapping patient population
USD | Unclear study description
UTO | Unable to obtain full text

Abacioglu, Yumuk PF, Caglar H, Sengoz M, Turhal NS. Concurrent chemoradiotherapy with low dose weekly gemcitabine in stage III non-small cell lung cancer. BMC Cancer. 2005;5:71. NRP. [pmid: 16000167].
Abe, Takahashi J, Fukuda H, Ono S, Yoshioka S, Akaizawa T, Kubota K, Yamada K, Takahashi T, Ohkuda K, Asoh N, Yonechi M, Maehira N, Mariya Y, Aoki M. A phase II study of cisplatin, oral administration of etoposide, OK-432 and radiation therapy for inoperable stage III non-small cell lung cancer. International Journal of Clinical Oncology. 1998;3(6):365-369. NRP.
Abratt, Shepherd LJ, Salton DG. Palliative radiation for stage 3 non-small cell lung cancer--a prospective study of two moderately high dose regimens. Lung Cancer. 1995;13(2):137-43. NRP. [pmid: 8581393].
Adelstein, Rice TW, Rybicki LA, Greskovich JF Jr, Ciezki JP, Carroll MA, DeCamp MM. Accelerated hyperfractionated radiation, concurrent paclitaxel/cisplatin chemotherapy and surgery for stage III non-small cell lung cancer. Lung Cancer. 2002;36(2):167-74. NRP. [pmid: 11955651].
Adkison, Khuntia D, Bentzen SM, Cannon GM, Tome WA, Jaradat H, Walker W, Traynor AM, Weigel T, Mehta MP. Dose escalated, hypofractionated radiotherapy using helical tomotherapy for inoperable non-small cell lung cancer: preliminary results of a risk-stratified phase I dose escalation study. Technol Cancer Res Treat. 2008;7(6):441-7. NRI. [pmid: 19044323].
Aerts, van Baardwijk AA, Petit SF, Offermann C, Loon J, Houben R, Dingemans AM, Wanders R, Boersma L, Borger J, Bootsma G, Geraedts W, Pitz C, Simons J, Wouters BG, Oellers M, Lambin P, Bosmans G, Dekker AL, De Ruysscher D. Identification of residual metabolic-active areas within individual NSCLC tumours using a pre-radiotherapy (18)Fluorodeoxyglucose-PET-CT scan. Radiother Oncol. 2009;91(3):386-92. NRO. [pmid: 19329207].
Aerts, Surmont V, van Klaveren RJ, Tan KY, Senan S, van Wijhe G, Vernhout R, Verhoeven GT, Hoogsteden HC, van Meerbeeck JP. A phase II study of induction therapy with carboplatin and gemcitabine among patients with locally advanced non-small cell lung cancer. J Thorac Oncol. 2006;1(6):532-6. NRP. [pmid: 17409913].
Ahmad, Sandhu AP, Fuster MM, Messer K, Pu M, Nobiensky P, Bazhenova L, Seagren S. Hypofractionated radiotherapy as definitive treatment of stage I non-small cell lung cancer in older patients. Am J Clin Oncol. 2011;34(3):254-8. NRI. [pmid: 20562588].
Ahmed, Bedford J, Warrington J, Hawkins M. Volumetric modulated arc radiotherapy (VMAT) of tumours in the thorax-acute toxicity results from a single centre. Radiotherapy and Oncology. 2011;99:S499. NRD.
Ahn, Park K, Kim DY, Kim KM, Kim J, Shim YM, Lee KS, Han J, Kim HJ, Kwon J, Lim DH, Noh YJ, Lee JE, Huh SJ. Preoperative concurrent chemoradiotherapy for stage IIIA non-small cell lung cancer. Acta Oncol. 2001;40(5):588-92. NRP. [pmid: 11669330].
Ahn, Han MS, Yoon JH, Jeon SY, Kim CH, Yoo HJ, Lee JC. Treatment of stage I non-small cell lung cancer with CyberKnife, image-guided robotic stereotactic radiosurgery. Oncol Rep. 2009;21(3):693-6. NRO. [pmid: 19212628].
Ahn, Kim YC, Kim KS, Park KO, Chung WK, Nam TK, Nah BS, Song JY, Yoon MS. Results of curative radiation therapy with or without chemotherapy for stage III unresectable non-small cell lung cancer. Cancer Res Treat. 2005;37(5):268-72. NRP. [pmid: 19956525].
Aich, Bhattacharaya K, Gupta P, Sur PK. Hypofractionated radiotherapy (MRC trial) - A preferred schedule for locally advanced non-small cell lung cancers. Indian Journal of Radiology and Imaging. 1998;8(3):177-181. UTO.
Aisner, Belani CP, Kearns C, Conley B, Hiponia D, Engstrom C, Zuhowski E, Egorin MJ. Feasibility and pharmacokinetics of paclitaxel, carboplatin, and concurrent radiotherapy for regionally advanced squamous cell carcinoma of the head and neck and for regionally advanced non-small cell lung cancer. Semin Oncol. 1995;22(5 Suppl 12):17-21. NRP. [pmid: 7481856].
Ajlouni, Chapman R, Kim JH. Accelerated-interrupted radiation therapy given concurrently with chemotherapy for locally advanced non-small cell lung cancer. Cancer J Sci Am. 1996;2(6):314-20. NRP. [pmid: 9166551].
Akerley, Choy H. Concurrent paclitaxel and thoracic radiation for advanced non-small cell lung cancer. Lung Cancer. 1995;12(Suppl 2()):S107-15. NRP. [pmid: 7551942].
Akerley, Choy H. Single-agent paclitaxel and radiation for non-small cell lung cancer. Semin Radiat Oncol. 1999;9(2 Suppl 1):85-9. NRP. [pmid: 10210545].
Akerley, Herndon JE Jr, Lyss AP, Choy H, Turrisi A, Graziano S, Williams T, Zhang C, Vokes EE, Green MR. Induction paclitaxel/carboplatin followed by concurrent chemoradiation therapy for unresectable stage III non-small-cell lung cancer: a limited-access study--CALGB 9534. Clin Lung Cancer. 2005;7(1):47-53. NRP. [pmid: 16098244].
Albain, Crowley JJ, Turrisi AT 3rd, Gandara DR, Farrar WB, Clark JI, Beasley KR, Livingston RB. Concurrent cisplatin, etoposide, and chest radiotherapy in pathologic stage IIIB non-small-cell lung cancer: a Southwest Oncology Group phase II study, SWOG 9019. J Clin Oncol. 2002;20(16):3454-60. NRP. [pmid: 12177106].
Albain, Swann RS, Rusch VW, Turrisi AT 3rd, Shepherd FA, Smith C, Chen Y, Livingston RB, Feins RH, Gandara DR, Fry WA, Darling G, Johnson DH, Green MR, Miller RC, Ley J, Sause WT, Cox JD. Radiotherapy plus chemotherapy with or without surgical resection for stage III non-small-cell lung cancer: a phase III randomised controlled trial. Lancet. 2009;374(9687):379-86. NRP. [pmid: 19632716].
Albain, Rusch VW, Crowley JJ, Rice TW, Turrisi AT 3rd, Weick JK, Lonchyna VA, Presant CA, McKenna RJ, Gandara DR, et al. Concurrent cisplatin/etoposide plus chest radiotherapy followed by surgery for stages IIIA (N2) and IIIB non-small-cell lung cancer: mature results of Southwest Oncology Group phase II study 8805. J Clin Oncol. 1995;13(8):1880-92. NRP. [pmid: 7636530].
Alberto, Mirimanoff RO, Mermillod B, Leyvraz S, Nagy-Mignotte H, Bolla M, Wellmann D, Moro D, Brambilla E. Rapidly alternating combination of cisplatin-based chemotherapy and hyperfractionated accelerated radiotherapy in split course for stage IIIA and stage IIIB non-small cell lung cancer: results of a phase I–II study by the GOTHA group. Group d’Oncologie Thoracique des Regions Alpines. Eur J Cancer. 1995;31A(3):342-8. NRP. [pmid: 7786599].
Alexander, Othus M, Caglar HB, Allen AM. Tumor volume is a prognostic factor in non-small-cell lung cancer treated with chemoradiotherapy. Int J Radiat Oncol Biol Phys. 2011;79(5):1381-7. NRP. [pmid: 20605346].
Ali, Kraut MJ, Valdivieso M, Wozniak AJ, Cummings G, Kalemkerian GP. A phase II study of mitomycin C, etoposide, and cisplatin in advanced non-small cell lung cancer. Cancer Invest. 2000;18(1):1-5. NRP. [pmid: 10701360].
Allison, Schulsinger A, Shin KH, Vongtama V. Chemoradiation enhances response in stage IIIB lung cancer. Radiation Oncology Investigations. 1996;4(4):171-175. NRP.
Ambrogi, Fanucchi O, Cioni R, Dini P, De Liperi A, Cappelli C, Davini F, Bartolozzi C, Mussi A. Long-Term Results of Radiofrequency Ablation Treatment of Stage I Non-small Cell Lung Cancer: A Prospective Intention-to-Treat Study. J Thorac Oncol. 2011;6(12):2044-51. NRP. [pmid: 22052222].
Ambrogi, Dini P, Melfi F, Mussi A. Radiofrequency ablation of inoperable non-small cell lung cancer. J Thorac Oncol. 2007;2(5 Suppl):S2-3. NRP. [pmid: 17457225].
Ampil, Sanghani SV. Timing of radiotherapy in asymptomatic patients with inoperable non-small cell lung cancer: a survival analysis and literature review. Radiat Med. 1996;14(4):211-4. NRP. [pmid: 8916266].
Anacak, Mogulkoc N, Ozkok S, Goksel T, Haydaroglu A, Bayindir U. High dose rate endobronchial brachytherapy in combination with external beam radiotherapy for stage III non-small cell lung cancer. Lung Cancer. 2001;34(2):253-9. NRP. [pmid: 11679184].
Anderson, McAleer JJ, Stranex S, Prescott G. Radical radiotherapy for inoperable non-small cell lung cancer: what factors predict prognosis?. Clin Oncol (R Coll Radiol). 2000;12(1):48-52. NRI. [pmid: 10749020].
Anderson, Hopwood P, Stephens RJ, Thatcher N, Cottier B, Nicholson M, Milroy R, Maughan TS, Falk SJ, Bond MG, Burt PA, Connolly CK, McIllmurray MB, Carmichael J. Gemcitabine plus best supportive care (BSC) vs BSC in inoperable non-small cell lung cancer--a randomized trial with quality of life as the primary outcome. UK NSCLC Gemcitabine Group. Non-Small Cell Lung Cancer. Br J Cancer. 2000;83(4):447-53. NRP. [pmid: 10945489].
Anku. Successful low-dose concurrent chemotherapy and radiation for locally advanced or inoperable non-small cell lung carcinoma: a report of six cases. J Natl Med Assoc. 2000;92(3):105-15. NRD. [pmid: 10745640].
Anscher, Garst J, Marks LB, Larrier N, Dunphy F, Herndon JE 2nd, Clough R, Marino C, Vujaskovic Z, Zhou S, Dewhirst MW, Shafman TD, Crawford J. Assessing the ability of the antiangiogenic and anticytokine agent thalidomide to modulate radiation-induced lung injury. Int J Radiat Oncol Biol Phys. 2006;66(2):477-82. NRP. [pmid: 16904841].
Anscher, Marks LB, Shafman TD, Clough R, Huang H, Tisch A, Munley M, Herndon JE, Garst J, Crawford J, Jirtle RL. Risk of long-term complications after TFG-beta1-guided very-high-dose thoracic radiotherapy. Int J Radiat Oncol Biol Phys. 2003;56(4):988-95. NRP. [pmid: 12829134].
Anton, Diaz-Fernandez N, Gonzalez JL, Vadell Larriba C, Masutti B, Montalar J, Barneto I, Artal A, Rosell R. Phase II trial assessing the combination of gemcitabine and cisplatin in advanced non-small cell lung cancer (NSCLC). Lung Cancer. 1998;22(2):139-48. NRP. [pmid: 10022221].
Antonadou, Throuvalas N, Petridis A, Bolanos N, Sagriotis A, Synodinou M. Effect of amifostine on toxicities associated with radiochemotherapy in patients with locally advanced non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2003;57(2):402-8. NRP. [pmid: 12957251].
Antonadou. Radiotherapy or chemotherapy followed by radiotherapy with or without amifostine in locally advanced lung cancer. Semin Radiat Oncol. 2002;12(1 Suppl 1):50-8. NRP. [pmid: 11917285].
Antonia, Wagner H, Williams C, Alberts M, Hubbell D, Robinson L, Hilstro J, Ruckdeschel JC. Concurrent paclitaxel/cisplatin with thoracic radiation in patients with stage IIIA/B non-small cell carcinoma of the lung. Semin Oncol. 1995;22(4 Suppl 9):34-7. NRP. [pmid: 7644926].
Ardizzoni, Grossi F, Scolaro T, Giudici S, Foppiano F, Boni L, Tixi L, Cosso M, Mereu C, Ratto GB, Vitale V, Rosso R. Induction chemotherapy followed by concurrent standard radiotherapy and daily low-dose cisplatin in locally advanced non-small-cell lung cancer. Br J Cancer. 1999;81(2):310-5. NRP. [pmid: 10496358].
Argiris, Liptay M, LaCombe M, Marymont M, Kies MS, Sundaresan S, Masters G. A phase I/II trial of induction chemotherapy with carboplatin and gemcitabine followed by concurrent vinorelbine and paclitaxel with chest radiation in patients with stage III non-small cell lung cancer. Lung Cancer. 2004;45(2):243-53. NRP. [pmid: 15246197].
Aristu, Rebollo J, Martinez-Monge R, Aramendia JM, Viera JC, Azinovic I, Herreros J, Brugarolas A. Cisplatin, mitomycin, and vindesine followed by intraoperative and postoperative radiotherapy for stage III non-small cell lung cancer: final results of a phase II study. Am J Clin Oncol. 1997;20(3):276-81. NRP. [pmid: 9167753].
Armstrong, Raben A, Zelefsky M, Burt M, Leibel S, Burman C, Kutcher G, Harrison L, Hahn C, Ginsberg R, Rusch V, Kris M, Fuks Z. Promising survival with three-dimensional conformal radiation therapy for non-small cell lung cancer. Radiother Oncol. 1997;44(1):17-22. NRP. [pmid: 9288852].
Armstrong, Zelefsky MJ, Leibel SA, Burman C, Han C, Harrison LB, Kutcher GJ, Fuks ZY. Strategy for dose escalation using 3-dimensional conformal radiation therapy for lung cancer. Ann Oncol. 1995;6(7):693-7. NRP. [pmid: 8664191].
Arpin, Perol D, Blay JY, Falchero L, Claude L, Vuillermoz-Blas S, Martel-Lafay I, Ginestet C, Alberti L, Nosov D, Etienne-Mastroianni B, Cottin V, Perol M, Guerin JC, Cordier JF, Carrie C. Early variations of circulating interleukin-6 and interleukin-10 levels during thoracic radiotherapy are predictive for radiation pneumonitis. J Clin Oncol. 2005;23(34):8748-56. NRP. [pmid: 16314635].
Arrieta, Gallardo-Rincon D, Villarreal-Garza C, Michel RM, Astorga-Ramos AM, Martinez-Barrera L, de la Garza J. High frequency of radiation pneumonitis in patients with locally advanced non-small cell lung cancer treated with concurrent radiotherapy and gemcitabine after induction with gemcitabine and carboplatin. J Thorac Oncol. 2009;4(7):845-52. NRP. [pmid: 19487963].
Atagi, Kawahara M, Yokoyama A, Okamoto H, Yamamoto N, Ohe Y, Ishikura S, Fukuda H, Saijo N, Tamura T. Standard thoracic radiotherapy with or without concurrent daily low-dose carboplatin in elderly patients with locally advanced non-small cell lung cancer - A phase III trial of the Japan clinical oncology group (JCOG0301). European Journal of Cancer. 2011;47:S273. NRD.
Atagi, Kawahara M, Ogawara M, Matsui K, Masuda N, Kudoh S, Negoro S, Furuse K. Phase II trial of daily low-dose carboplatin and thoracic radiotherapy in elderly patients with locally advanced non-small cell lung cancer. Jpn J Clin Oncol. 2000;30(2):59-64. NRI. [pmid: 10768867].
Atagi, Kawahara M, Hosoe S, Ogawara M, Kawaguchi T, Okishio K, Naka N, Sunami T, Mitsuoka S, Akira M. A phase II study of continuous concurrent thoracic radiotherapy in combination with mitomycin, vindesine and cisplatin in unresectable stage III non-small cell lung cancer. Lung Cancer. 2002;36(1):105-11. NRP. [pmid: 11891041].
Atagi, Kawahara M, Tamura T, Noda K, Watanabe K, Yokoyama A, Sugiura T, Senba H, Ishikura S, Ikeda H, Ishizuka N, Saijo N. Standard thoracic radiotherapy with or without concurrent daily low-dose carboplatin in elderly patients with locally advanced non-small cell lung cancer: a phase III trial of the Japan Clinical Oncology Group (JCOG9812). Jpn J Clin Oncol. 2005;35(4):195-201. NRP. [pmid: 15845568].
Auchter, Scholtens D, Adak S, Wagner H, Cella DF, Mehta MP. Quality of life assessment in advanced non-small-cell lung cancer patients undergoing an accelerated radiotherapy regimen: report of ECOG study 4593. Eastern Cooperative Oncology Group. Int J Radiat Oncol Biol Phys. 2001;50(5):1199-206. NRP. [pmid: 11483329].
Aviram, Yu E, Tai P, Lefcoe MS. Computed tomography to assess pulmonary injury associated with concurrent chemo-radiotherapy for inoperable non-small cell lung cancer. Can Assoc Radiol J. 2001;52(6):385-91. NRP. [pmid: 11780548].
Aydiner, Sen F, Saglam EK, Oral EN, Eralp Y, Tas F, Toker A, Dilege S. Induction chemotherapy with triweekly docetaxel and cisplatin followed by concomitant chemoradiotherapy with or without surgery in stage III non-small-cell lung cancer: a phase II study. Clin Lung Cancer. 2011;12(5):286-92. NRP. [pmid: 21729649].
Baba, Shibamoto Y, Ogino H, Murata R, Sugie C, Iwata H, Otsuka S, Kosaki K, Nagai A, Murai T, Miyakawa A. Clinical outcomes of stereotactic body radiotherapy for stage I non-small cell lung cancer using different doses depending on tumor size. Radiat Oncol. 2010;5:81. USD. [pmid: 20849623].
Baba, Shibamoto Y, Tomita N, Ikeya-Hashizume C, Oda K, Ayakawa S, Ogino H, Sugie C. Stereotactic body radiotherapy for stage I lung cancer and small lung metastasis: evaluation of an immobilization system for suppression of respiratory tumor movement and preliminary results. Radiat Oncol. 2009;4:15. OPP. [pmid: 19476628].
Bahri, Flickinger JC, Kalend AM, Deutsch M, Belani CP, Sciurba FC, Luketich JD, Greenberger JS. Results of multifield conformal radiation therapy of nonsmall-cell lung carcinoma using multileaf collimation beams. Radiat Oncol Investig. 1999;7(5):297-308. NRP.
Bailey, Parmar MK, Stephens RJ. Patient-reported short-term and long-term physical and psychologic symptoms: results of the continuous hyperfractionated accelerated correction of acclerated radiotherapy (CHART) randomized trial in non-small-cell lung cancer. CHART Steering Committee. 1998;16:3082-93. NRP.
Baisden, Romney DA, Reish AG, Cai J, Sheng K, Jones DR, Benedict SH, Read PW, Larner JM. Dose as a function of lung volume and planned treatment volume in helical tomotherapy intensity-modulated radiation therapy-based stereotactic body radiation therapy for small lung tumors. Int J Radiat Oncol Biol Phys. 2007;68(4):1229-37. NRP. [pmid: 17513066].
Baka, Faivre-Finn C, Papakotoulas P, Blackhall F, Anderson H, Lorigan P, Thatcher N. Platinum-based chemotherapy with thoracic radiotherapy in stage III good performance status non-small cell lung cancer patients. European Journal of Cancer, Supplement. 2005;3(3):41-50. NRD.
Bakitas, Lyons KD, Hegel MT, Balan S, Brokaw FC, Seville J, Hull JG, Li Z, Tosteson TD, Byock IR, Ahles TA. Effects of a palliative care intervention on clinical outcomes in patients with advanced cancer: The project ENABLE II randomized controlled trial. JAMA - Journal of the American Medical Association. 2009;302(7):741-749. NRP.
Baldini, Silvano G, Tibaldi C, Campoccia S, Cionini L, Conte P. Sequential chemoradiation therapy with vinorelbine, ifosfamide, and cisplatin in stage IIIB non-small cell lung cancer: a phase II study. Semin Oncol. 2000;27(1 Suppl 1):28-32. NRP. [pmid: 10697041].
Ball, Bishop J, Smith J, Crennan E, O’Brien P, Davis S, Ryan G, Joseph D, Walker Q. A phase III study of accelerated radiotherapy with and without carboplatin in nonsmall cell lung cancer: an interim toxicity analysis of the first 100 patients. 1995;31:267-72. NRI.
Ball, Bishop J, Smith J, O’Brien P, Davis S, Ryan G, Olver I, Toner G, Walker Q, Joseph D. A randomised phase III study of accelerated or standard fraction radiotherapy with or without concurrent carboplatin in inoperable non-small cell lung cancer: final report of an Australian multi-centre trial. Radiother Oncol. 1999;52(2):129-36. NRI. [pmid: 10577698].
Ball, Smith J, Wirth A, Mac Manus M. Failure of T stage to predict survival in patients with non-small-cell lung cancer treated by radiotherapy with or without concomitant chemotherapy. 2002;54:1007-13. NRI.
Ball, Smith J, Bishop J, Olver I, Davis S, O’Brien P, Bernshaw D, Ryan G, Millward M. A phase III study of radiotherapy with and without continuous-infusion fluorouracil as palliation for non-small-cell lung cancer. Br J Cancer. 1997;75(5):690-7. NRP. [pmid: 9043026].
Ball, Lin MY, Wu M, Fisher R, Brennan S, Campeau MP, Binns D, MacManus MP, Solomon B, Hicks RJ. Absence of a relationship between 18F-fluoro-deoxglucose (FDG) uptake and survival in non-small cell lung cancer patients treated with radical radiotherapy or concomitatnt chemoradiotherapy. Journal of Thoracic Oncology. 2011;6(3):S15-S16. NRD.
Bardet, Riviere A, Charloux A, Spaeth D, Ducolone A, Le Groumellec A, Pellae-Cosset B, Henry-Amar M, Douillard JY. A phase II trial of radiochemotherapy with daily carboplatin, after induction chemotherapy (carboplatin and etoposide), in locally advanced nonsmall-cell lung cancer: final analysis. Int J Radiat Oncol Biol Phys. 1997;38(1):163-8. NRP. [pmid: 9212019].
Barone, Corsi DC, Pozzo C, Cassano A, Alvaro G, Colloca G, Landriscina M, Astone A. Vinorelbine and alternating cisplatin and ifosfamide in the treatment of non-small cell lung cancer. Oncology. 2000;58(1):25-30. NRP. [pmid: 10644937].
Barriger, Fakiris AJ, Hanna N, Yu M, Mantravadi P, McGarry RC. Dose-volume analysis of radiation pneumonitis in non-small-cell lung cancer patients treated with concurrent cisplatinum and etoposide with or without consolidation docetaxel. Int J Radiat Oncol Biol Phys. 2010;78(5):1381-6. NRP. [pmid: 20231061].
Barriger, Forquer JA, Brabham JG, Andolino DL, Shapiro RH, Henderson MA, Johnstone PA, Fakiris AJ. A Dose-Volume Analysis of Radiation Pneumonitis in Non-Small Cell Lung Cancer Patients Treated with Stereotactic Body Radiation Therapy. Int J Radiat Oncol Biol Phys. 2010;82(1):457-63. NRI, USD. [pmid: 21035956].
Basaki, Abe Y, Aoki M, Kondo H, Hatayama Y, Nakaji S. Prognostic factors for survival in stage III non-small-cell lung cancer treated with definitive radiation therapy: impact of tumor volume. Int J Radiat Oncol Biol Phys. 2006;64(2):449-54. NRP. [pmid: 16226400].
Bastos, Hatoum GF, Walker GR, Tolba K, Takita C, Gomez J, Santos ES, Lopes G, Raez LE. Efficacy and toxicity of chemoradiotherapy with carboplatin and irinotecan followed by consolidation docetaxel for unresectable stage III non-small cell lung cancer. J Thorac Oncol. 2010;5(4):533-9. NRP. [pmid: 20357618].
Baumann, Nyman J, Hoyer M, Gagliardi G, Lax I, Wennberg B, Drugge N, Ekberg L, Friesland S, Johansson KA, Lund JS, Morhed E, Nilsson K, Levin N, Paludan M, Sederholm C, Traberg A, Wittgren L, Lewensohn R. Stereotactic body radiotherapy for medically inoperable patients with stage I non-small cell lung cancer - a first report of toxicity related to COPD/CVD in a non-randomized prospective phase II study. Radiother Oncol. 2008;88(3):359-67. OPP. [pmid: 18768228].
Baumann, Herrmann T, Koch R, Matthiessen W, Appold S, Wahlers B, Kepka L, Marschke G, Feltl D, Fietkau R, Budach V, Dunst J, Dziadziuszko R, Krause M, Zips D. Final results of the randomized phase III CHARTWEL-trial (ARO 97-1) comparing hyperfractionated-accelerated versus conventionally fractionated radiotherapy in non-small cell lung cancer (NSCLC). Radiother Oncol. 2011;100(1):76-85. USD. [pmid: 21757247].
Bebb, Smith C, Rorke S, Boland W, Nicacio L, Sukhoo R, Brade A. Phase I clinical trial of the anti-EGFR monoclonal antibody nimotuzumab with concurrent external thoracic radiotherapy in Canadian patients diagnosed with stage IIb, III or IV non-small cell lung cancer unsuitable for radical therapy. Cancer Chemother Pharmacol. 2011;67(4):837-45. NRP. [pmid: 20563810].
Beckmann, Fietkau R, Huber RM, Kleine P, Schmidt M, Semrau S, Aubert D, Fittipaldo A, Flentje M. Oral vinorelbine and cisplatin with concomitant radiotherapy in stage III non-small cell lung cancer (NSCLC): a feasibility study. Onkologie. 2006;29(4):137-42. NRP. [pmid: 16601369].
Bedini, Tavecchio L, Gramaglia A, Villa S, Palazzi M. Radiotherapy and concurrent continuous infusion of cisplatin with adjuvant surgery in nonresectable Stage III lung carcinoma: short- and long-term results of a Phase II study. Int J Radiat Oncol Biol Phys. 1999;45(3):613-21. NRP. [pmid: 10524413].
Beitler, Badine EA, El-Sayah D, Makara D, Friscia P, Silverman P, Terjanian T. Stereotactic body radiation therapy for nonmetastatic lung cancer: an analysis of 75 patients treated over 5 years. Int J Radiat Oncol Biol Phys. 2006;65(1):100-6. NRP. [pmid: 16517092].
Belani, Ramanathan RK. Combined-modality treatment of locally advanced non-small cell lung cancer: incorporation of novel chemotherapeutic agents. Chest. 1998;113(1 Suppl):53S-60S. NRD. [pmid: 9438691].
Belani, Choy H, Bonomi P, Scott C, Travis P, Haluschak J, Curran WJ Jr. Combined chemoradiotherapy regimens of paclitaxel and carboplatin for locally advanced non-small-cell lung cancer: a randomized phase II locally advanced multi-modality protocol. J Clin Oncol. 2005;23(25):5883-91. NRP. [pmid: 16087941].
Belani, Aisner J, Ramanathan R, Jett J, Greenberger J, Day R, Capazolli MJ, Hiponia D, Engstrom C. Paclitaxel and carboplatin with simultaneous thoracic irradiation in regionally advanced non-small cell lung cancer. Seminars in Radiation Oncology. 1997;7(2 SUPPL 1):S1–11-S1–14. NRP.
Belani, Wang W, Johnson DH, Wagner H, Schiller J, Veeder M, Mehta M. Phase III study of the Eastern Cooperative Oncology Group (ECOG 2597): induction chemotherapy followed by either standard thoracic radiotherapy or hyperfractionated accelerated radiotherapy for patients with unresectable stage IIIA and B non-small-cell lung cancer. J Clin Oncol. 2005;23(16):3760-7. NRP. [pmid: 15837967].
Belderbos, De Jaeger K, Heemsbergen WD, Seppenwoolde Y, Baas P, Boersma LJ, Lebesque JV. First results of a phase I/II dose escalation trial in non-small cell lung cancer using three-dimensional conformal radiotherapy. Radiother Oncol. 2003;66(2):119-26. USD. [pmid: 12648783].
Belderbos, Uitterhoeve L, van Zandwijk N, Belderbos H, Rodrigus P, van de Vaart P, Price A, van Walree N, Legrand C, Dussenne S, Bartelink H, Giaccone G, Koning C. Randomised trial of sequential versus concurrent chemo-radiotherapy in patients with inoperable non-small cell lung cancer (EORTC 08972–22973. Eur J Cancer. 2007;43(1):114-21. NRI. [pmid: 17084621].
Belderbos, Heemsbergen WD, De Jaeger K, Baas P, Lebesque JV. Final results of a Phase I/II dose escalation trial in non-small-cell lung cancer using three-dimensional conformal radiotherapy. Int J Radiat Oncol Biol Phys. 2006;66(1):126-34. USD. [pmid: 16904518].
Belderbos, Heemsbergen W, Hoogeman M, Pengel K, Rossi M, Lebesque J. Acute esophageal toxicity in non-small cell lung cancer patients after high dose conformal radiotherapy. Radiother Oncol. 2005;75(2):157-64. USD. [pmid: 15890421].
Belliere, Girard N, Chapet O, Khodri M, Kubas A, Souquet PJ, Mornex F. Feasibility of high-dose three-dimensional radiation therapy in the treatment of localised non-small-cell lung cancer. Cancer Radiother. 2009;13(4):298-304. NRP. [pmid: 19525134].
Beltramo, Bergantin A, Martinotti A, Bonfanti P, Bianchi LC. Stereotactic body ablative radiotherapy for stage I non small cell lung cancer. Radiotherapy and Oncology. 2011;99:S570-S571. NRD.
Bepler, Dilling TJ, Wagner H, Hazelton T, Williams C, Chen DT, Greenberg H, Walsh F, Simon G, Tanvetyanon T, Chiappori A, Haura E, Stevens C. Phase II trial of induction gemcitabine and carboplatin followed by conformal thoracic radiation to 74 Gy with weekly paclitaxel and carboplatin in unresectable stage III non-small cell lung cancer. J Thorac Oncol. 2011;6(3):553-8. NRP. [pmid: 21289520].
Berghmans, Van Houtte P, Paesmans M, Giner V, Lecomte J, Koumakis G, Richez M, Holbrechts S, Roelandts M, Meert AP, Alard S, Leclercq N, Sculier JP. A phase III randomised study comparing concomitant radiochemotherapy as induction versus consolidation treatment in patients with locally advanced unresectable non-small cell lung cancer. Lung Cancer. 2009;64(2):187-93. NRP. [pmid: 18804894].
Bernier, Denekamp J, Rojas A, Trovo M, Horiot JC, Hamers H, Antognoni P, Dahl O, Richaud P, Kaanders J, van Glabbeke M, Pierart M. ARCON: accelerated radiotherapy with carbogen and nicotinamide in non small cell lung cancer: a phase I/II study by the EORTC. Radiother Oncol. 1999;52(2):149-56. NRP. [pmid: 10577700].
Beslija, Dizdarevic Z, Lomigoric J, Zutic H, Musanovic M, Mehic B, Cardjic A, Paralija B, Obralic N. Randomized phase II study of induction chemotherapy with gemcitabine plus cisplatin followed by sequential radiotherapy versus radiotherapy alone in patients with stage III non-small cell lung cancer. J BUON. 2005;10(3):347-55. NRP. [pmid: 17357188].
Bezjak, Dixon P, Brundage M, Tu D, Palmer MJ, Blood P, Grafton C, Lochrin C, Leong C, Mulroy L, Smith C, Wright J, Pater JL. Randomized phase III trial of single versus fractionated thoracic radiation in the palliation of patients with lung cancer (NCIC CTG SC.15). Int J Radiat Oncol Biol Phys. 2002;54(3):719-28. NRP. [pmid: 12377323].
Bhatia, Hanna N, Ansari R, Einhorn L, Sandler A. Carboplatin plus paclitaxel and sequential radiation followed by consolidation carboplatin and paclitaxel in patients with previously untreated locally advanced NSCLC. A Hoosier Oncology Group (HOG) phase II study. Lung Cancer. 2002;38(1):85-9. NRP. [pmid: 12367798].
Bhatnagar, Flickinger JC, Bahri S, Deutsch M, Belani C, Luketich JD, Greenberger JS. Update on results of multifield conformal radiation therapy of non-small-cell lung cancer using multileaf collimated beams. Clin Lung Cancer. 2002;3(4):259-64. NRP. [pmid: 14662034].
Bhatt, Mohani BK, Kumar L, Chawla S, Sharma DN, Rath GK. Palliative treatment of advanced non small cell lung cancer with weekly fraction radiotherapy. Indian J Cancer. 2000;37(4):148-52. NRP. [pmid: 12018566].
Bi, Yang M, Zhang L, Chen X, Ji W, Ou G, Lin D, Wang L. Cyclooxygenase-2 genetic variants are associated with survival in unresectable locally advanced non-small cell lung cancer. Clin Cancer Res. 2010;16(8):2383-90. NRP. [pmid: 20332326].
Biedermann, Landmann C, Kann R, Passweg J, Soler M, Lohri A, Rochlitz C, Herrmann R, Pless M. Combined chemoradiotherapy with daily low-dose cisplatin in locally advanced inoperable non-small cell lung cancer. Radiother Oncol. 2000;56(2):169-73. NRI. [pmid: 10927135].
Birim, Kappetein AP, Goorden T, van Klaveren RJ, Bogers AJ. Proper treatment selection may improve survival in patients with clinical early-stage nonsmall cell lung cancer. Ann Thorac Surg. 2005;80(3):1021-6. NRI. [pmid: 16122477].
Bishawi, Kim B, Moore WH, Bilfinger TV. Pulmonary Function Testing After Stereotactic Body Radiotherapy to the Lung. Int J Radiat Oncol Biol Phys. 2011. NRO.
Blackstock, Ho C, Butler J, Fletcher-Steede J, Case LD, Hinson W, Miller AA. Phase Ia/Ib chemo-radiation trial of gemcitabine and dose-escalated thoracic radiation in patients with stage III A/B non-small cell lung cancer. J Thorac Oncol. 2006;1(5):434-40. NRP. [pmid: 17409896].
Blackstock, Lesser GJ, Fletcher-Steede J, Case LD, Tucker RW, Russo SM, White DR, Miller A. Phase I study of twice-weekly gemcitabine and concurrent thoracic radiation for patients with locally advanced non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2001;51(5):1281-9. NRP. [pmid: 11728688].
Blanco, Sole J, Montesinos J, Mesia C, Algara M, Terrassa J, Gay M, Domenech M, Bastus R, Bover I, Nogue M, Vadell C. Induction chemotherapy with cisplatin and gemcitabine followed by concurrent chemoradiation with twice-weekly gemcitabine in unresectable stage III non-small cell lung cancer: final results of a phase II study. Lung Cancer. 2008;62(1):62-71. NRP. [pmid: 18440089].
Blanke, Ansari R, Mantravadi R, Gonin R, Tokars R, Fisher W, Pennington K, O’Connor T, Rynard S, Miller M, et al. Phase III trial of thoracic irradiation with or without cisplatin for locally advanced unresectable non-small-cell lung cancer: a Hoosier Oncology Group protocol. J Clin Oncol. 1995;13(6):1425-9. NRI. [pmid: 7751888].
Blanke, DeVore R, Shyr Y, Epstein B, Murray M, Hande K, Stewart S, Johnson D. A pilot study of protracted low dose cisplatin and etoposide with concurrent thoracic radiotherapy in unresectable stage III nonsmall cell lung cancer. Int J Radiat Oncol Biol Phys. 1997;37(1):111-6. NRP. [pmid: 9054884].
Blumenschein Jr, Paulus R, Curran WJ, Robert F, Fossella F, Werner-Wasik M, Herbst RS, Doescher PO, Choy H, Komaki R. Phase II study of cetuximab in combination with chemoradiation in patients with stage IIIA/B non-small-cell lung cancer: RTOG 0324. J Clin Oncol. 2011;29(17):2312-8. NRP. [pmid: 21555682].
Bogart, Govindan R. A randomized phase II study of radiation therapy, pemetrexed, and carboplatin with or without cetuximab in stage III non-small-cell lung cancer. Clin Lung Cancer. 2006;7(4):285-7. NRP. [pmid: 16512986].
Bogart, Alpert TE, Kilpatrick MC, Keshler BL, Pohar SS, Shah H, Dexter E, Aronowitz JN. Dose-intensive thoracic radiation therapy for patients at high risk with early-stage non-small-cell lung cancer. Clin Lung Cancer. 2005;6(6):350-4. NRI. [pmid: 15943895].
Bollineni, Wiegman EM, Pruim J, Langendijk JA, Widder J. 18F-FDG-PET 12 weeks after stereotactic body radiotherapy for stage I non-small-cell lung cancer predicts outcome. European Journal of Cancer. 2011;47:S595. NRD.
Bonfili, Di Staso M, Gravina GL, Franzese P, Buonopane S, Solda F, Festuccia C, Tombolini V. Hypofractionated radical radiotherapy in elderly patients with medically inoperable stage I–II non-small-cell lung cancer. Lung Cancer. 2010;67(1):81-5. NRP. [pmid: 19395119].
Bongers, Haasbeek CJ, Lagerwaard FJ, Slotman BJ, Senan S. Incidence and risk factors for chest wall toxicity after risk-adapted stereotactic radiotherapy for early-stage lung cancer. J Thorac Oncol. 2011;6(12):2052-7. USD. [pmid: 22052227].
Bonner, McGinnis WL, Stella PJ, Marschke RF Jr, Sloan JA, Shaw EG, Mailliard JA, Creagan ET, Ahuja RK, Johnson PA. The possible advantage of hyperfractionated thoracic radiotherapy in the treatment of locally advanced nonsmall cell lung carcinoma: results of a North Central Cancer Treatment Group Phase III Study. Cancer. 1998;82(6):1037-48. NRP. [pmid: 9506347].
Bonnet, Bush D, Cheek GA, Slater JD, Panossian D, Franke C, Slater JM. Effects of proton and combined proton/photon beam radiation on pulmonary function in patients with resectable but medically inoperable non-small cell lung cancer. Chest. 2001;120(6):1803-10. NRP. [pmid: 11742905].
Bonomi, Blanco-Savorio A, Cerchietti L, Navigante A, Castro M, Roth B, Wisnivesky JP. Continuous hyperfractionated accelerated radiation therapy week-end less in combination with neoadjuvant chemotherapy for the treatment of stage III non-small-cell lung cancer. Lung Cancer. 2008;60(1):75-82. NRP. [pmid: 17936404].
Borst, De Jaeger K, Belderbos JS, Burgers SA, Lebesque JV. Pulmonary function changes after radiotherapy in non-small-cell lung cancer patients with long-term disease-free survival. Int J Radiat Oncol Biol Phys. 2005;62(3):639-44. USD. [pmid: 15936539].
Bouillet, Morère JF, Mazeron JJ, Piperno-Neuman S, Boaziz C, Haddad E, Breau JL. Induction chemotherapy followed by concomitant combined radiotherapy and chemotherapy in stage III non-small cell bronchial carcinoma. 1997;1:121-31. FLA.
Brade, Bezjak A, MacRae R, Laurie S, Sun A, Cho J, Leighl N, Pearson S, Southwood B, Wang L, McGill S, Iscoe N, Shepherd FA. Phase I trial of radiation with concurrent and consolidation pemetrexed and cisplatin in patients with unresectable stage IIIA/B non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2011;79(5):1395-401. NRP. [pmid: 20605367].
Bradley, Scott CB, Paris KJ, Demas WF, Machtay M, Komaki R, Movsas B, Rubin P, Sause WT. A phase III comparison of radiation therapy with or without recombinant beta-interferon for poor-risk patients with locally advanced non-small-cell lung cancer (RTOG 93-04). Int J Radiat Oncol Biol Phys. 2002;52(5):1173-9. NRP. [pmid: 11955727].
Bradley, El Naqa I, Drzymala RE, Trovo M, Jones G, Denning MD. Stereotactic body radiation therapy for early-stage non-small-cell lung cancer: the pattern of failure is distant. Int J Radiat Oncol Biol Phys. 2010;77(4):1146-50. NRP. [pmid: 19800181].
Bradley, Moughan J, Graham MV, Byhardt R, Govindan R, Fowler J, Purdy JA, Michalski JM, Gore E, Choy H. A phase I/II radiation dose escalation study with concurrent chemotherapy for patients with inoperable stages I to III non-small-cell lung cancer: phase I results of RTOG 0117. Int J Radiat Oncol Biol Phys. 2010;77(2):367-72. NRP. [pmid: 20457350].
Bradley, Deasy JO, Bentzen S, El-Naqa I. Dosimetric correlates for acute esophagitis in patients treated with radiotherapy for lung carcinoma. Int J Radiat Oncol Biol Phys. 2004;58(4):1106-13. NRI. [pmid: 15001251].
Bradley, Bae K, Graham MV, Byhardt R, Govindan R, Fowler J, Purdy JA, Michalski JM, Gore E, Choy H. Primary analysis of the phase II component of a phase I/II dose intensification study using three-dimensional conformal radiation therapy and concurrent chemotherapy for patients with inoperable non-small-cell lung cancer: RTOG 0117. J Clin Oncol. 2010;28(14):2475-80. NRI. [pmid: 20368547].
Bradley, Graham MV, Winter K, Purdy JA, Komaki R, Roa WH, Ryu JK, Bosch W, Emami B. Toxicity and outcome results of RTOG 9311: a phase I–II dose-escalation study using three-dimensional conformal radiotherapy in patients with inoperable non-small-cell lung carcinoma. Int J Radiat Oncol Biol Phys. 2005;61(2):318-28. USD. [pmid: 15667949].
Bradley, Ieumwananonthachai N, Purdy JA, Wasserman TH, Lockett MA, Graham MV, Perez CA. Gross tumor volume, critical prognostic factor in patients treated with three-dimensional conformal radiation therapy for non-small-cell lung carcinoma. Int J Radiat Oncol Biol Phys. 2002;52(1):49-57. USD. [pmid: 11777621].
Bral, Van Parijs H, Soete G, Linthout N, Van Moorter L, Verellen D, Storme G. A feasibility study of image-guided hypofractionated conformal arc therapy for inoperable patients with localized non-small cell lung cancer. Radiother Oncol. 2007;84(3):252-6. NRP. [pmid: 17720266].
Bral, Duchateau M, Versmessen H, Engels B, Tournel K, Vinh-Hung V, De Ridder M, Schallier D, Storme G. Toxicity and outcome results of a class solution with moderately hypofractionated radiotherapy in inoperable Stage III non-small cell lung cancer using helical tomotherapy. Int J Radiat Oncol Biol Phys. 2010;77(5):1352-9. NRP. [pmid: 20056350].
Bral, Duchateau M, Versmessen H, Verdries D, Engels B, De Ridder M, Tournel K, Collen C, Everaert H, Schallier D, De J, Storme Greve G. Toxicity report of a phase 1/2 dose-escalation study in patients with inoperable, locally advanced nonsmall cell lung cancer with helical tomotherapy and concurrent chemotherapy. Cancer. 2010;116(1):241-50. NRP. [pmid: 19918925].
Bral, Duchateau M, De Ridder M, Everaert H, Tournel K, Schallier D, Verellen D, Storme G. Volumetric response analysis during chemoradiation as predictive tool for optimizing treatment strategy in locally advanced unresectable NSCLC. Radiother Oncol. 2009;91(3):438-42. NRP. [pmid: 19368985].
Bral, Gevaert T, Linthout N, Versmessen H, Collen C, Engels B, Verdries D, Everaert H, Christian N, De M, Storme Ridder G. Prospective, risk-adapted strategy of stereotactic body radiotherapy for early-stage non-small-cell lung cancer: results of a Phase II trial. Int J Radiat Oncol Biol Phys. 2011;80(5):1343-9. NRP. [pmid: 20708849].
Brattstrom, Bergqvist M, Hesselius P, Wagenius G, Brodin O. Different fraction schedules and combinations with chemotherapy in radiation treatment of non-small cell lung cancer. Anticancer Res. 2000;20(3B):2087-90. NRP. [pmid: 10928157].
Breathnach, Kasturi V, Kaye F, Herscher L, Georgiadis MS, Edison M, Schuler BS, Pizzella P, Steinberg SM, O’Neil K, Johnson BE. Phase II neoadjuvant trial of paclitaxel by 96-hour continuous infusion (CIVI) in combination with cisplatin followed by chest radiotherapy for patients with stage III non-small-cell lung cancer. Am J Clin Oncol. 2002;25(3):269-73. NRP. [pmid: 12040286].
Bretel, Arriagada R, Le Chevalier T, Baldeyrou P, Grunenwald D, Le Pechoux C, Pellae-Cosset B, Ruffie P. Optimization of combined radiotherapy and chemotherapy in treatment of non-small cell lung carcinoma. 1997;1:148-53. FLA.
Brown, Fayad F, Hevezi J, Fowler J, Monterroso MI, Garcia S, Medina A, Schwade J. Individualized higher dose of 70–75 Gy using five-fraction robotic stereotactic radiotherapy for non-small-cell lung cancer: a feasibility study. Comput Aided Surg. 2011;16(1):1-10. NRI. [pmid: 21198423].
Brown, Wu X, Amendola B, Perman M, Han H, Fayad F, Garcia S, Lewin A, Abitbol A, de la Zerda A, Schwade JG. Treatment of early non-small cell lung cancer, stage IA, by image-guided robotic stereotactic radioablation--CyberKnife. Cancer J. 2007;13(2):87-94. NRI. [pmid: 17476136].
Brown, Wu X, Wen BC, Fowler JF, Fayad F, Amendola BE, Garcia S, De La A, Huang Zerda Z, Schwade JG. Early results of CyberKnife image-guided robotic stereotactic radiosurgery for treatment of lung tumors. Comput Aided Surg. 2007;12(5):253-61. NRI. [pmid: 17957532].
Brown, Wu X, Fayad F, Fowler JF, Amendola BE, Garcia S, Han H, de la Zerda A, Bossart E, Huang Z, Schwade JG. CyberKnife radiosurgery for stage I lung cancer: results at 36 months. Clin Lung Cancer. 2007;8(8):488-92. NRI. [pmid: 17922973].
Brown, Wu X, Fayad F, Fowler JF, Garcia S, Monterroso MI, de la Zerda A, Schwade JG. Application of robotic stereotactic radiotherapy to peripheral stage I non-small cell lung cancer with curative intent. Clin Oncol (R Coll Radiol). 2009;21(8):623-31. NRI. [pmid: 19682875].
Brundage, Bezjak A, Dixon P, Grimard L, Larochelle M, Warde P, Warr D. The role of palliative thoracic radiotherapy in non-small cell lung cancer. Can J Oncol. 1996;6(Suppl 1()):25-32. NRD. [pmid: 8853535].
Brunsvig, Hatlevoll R, Berg R, Lauvvang G, Owre K, Wang M, Aamdal S. Weekly docetaxel with concurrent radiotherapy in locally advanced non-small cell lung cancer: a phase I/II study with 5 years’ follow-up. Lung Cancer. 2005;50(1):97-105. NRP. [pmid: 16005105].
Burfeind Jr, D’Amico TA, Toloza EM, Wolfe WG, Harpole DH, Miller DL, Decamp MM, Cerfolio RJ. Low morbidity and mortality for bronchoplastic procedures with and without induction therapy. Annals of Thoracic Surgery. 2005;80(2):418-422. NRP. [pmid: 16039176].
Burmeister, Fielding DI, Ramsay JR, Baumann KC, Dauth M, Walpole ET. A phase I study of moderate-dose radiation therapy and weekly gemcitabine in patients with locally advanced non-small cell lung cancer not suitable for radical chemoradiation therapy. Clin Oncol (R Coll Radiol). 2005;17(5):332-6. NRP. [pmid: 16097563].
Burmeister, Michael M, Burmeister E, Cox S, Lehman M, Wirth A, Horwood K, Sasso G, Forouzesh B, Ball D. A Randomized Phase II Trial of Two Regimens of Moderate Dose Chemoradiation Therapy for Patients with Non-small Cell Lung Cancer Not Suitable for Curative Therapy: Trans Tasman Radiation Oncology Study TROG 03.07. J Thorac Oncol. 2011;6(12):2076-82. NRP. [pmid: 21892106].
Burmeister, Gogna NK, Bryant GP, Armstrong J, Kelly W, Mackintosh J, Walpole E, Morton K. Chemoradiation for inoperable non small cell lung cancer: a phase II study using a regimen with acceptable toxicity. Lung Cancer. 1999;23(3):233-40. NRI. [pmid: 10413199].
Bush, Slater JD, Bonnet R, Cheek GA, Dunbar RD, Moyers M, Slater JM. Proton-beam radiotherapy for early-stage lung cancer. Chest. 1999;116(5):1313-9. USD. [pmid: 10559093].
Bush, Dunbar RD, Bonnet R, Slater JD, Cheek GA, Slater JM. Pulmonary injury from proton and conventional radiotherapy as revealed by CT. AJR Am J Roentgenol. 1999;172(3):735-9. NRO. [pmid: 10063871].
Bush, Do SY, Slater JD. Comorbidity-adjusted survival in early stage lung cancer patients treated with hypofractionated proton therapy. Journal of Oncology. 2010. OPP.
Byhardt, Scott C. A palliative accelerated irradiation regimen for advanced non-small-cell lung cancer vs. conventionally fractionated 60 Gy: results of a randomized equivalence study: regarding Nestle et al. IJROBP 2000; 48:95–103. Int J Radiat Oncol Biol Phys. 2001;50(3):837. NRD. [pmid: 11417531].
Byhardt, Scott CB, Ettinger DS, Curran WJ, Doggett RL, Coughlin C, Scarantino C, Rotman M, Emami B. Concurrent hyperfractionated irradiation and chemotherapy for unresectable nonsmall cell lung cancer. Results of Radiation Therapy Oncology Group 90-15. Cancer. 1995;75(9):2337-44. NRP. [pmid: 7712445].
Byhardt, Scott C, Sause WT, Emami B, Komaki R, Fisher B, Lee JS, Lawton C. Response, toxicity, failure patterns, and survival in five Radiation Therapy Oncology Group (RTOG) trials of sequential and/or concurrent chemotherapy and radiotherapy for locally advanced non-small-cell carcinoma of the lung. Int J Radiat Oncol Biol Phys. 1998;42(3):469-78. NRP. [pmid: 9806503].
Byhardt, Vaickus L, Witt PL, Chang AY, McAuliffe T, Wilson JF, Lawton CA, Breitmeyer J, Alger ME, Borden EC. Recombinant human interferon-beta (rHuIFN-beta) and radiation therapy for inoperable non-small cell lung cancer. J Interferon Cytokine Res. 1996;16(11):891-902. NRP. [pmid: 8938564].
Byrne, Phillips M, Powell A, Cameron F, Joseph D, Spry N, Dewar J, Van Hazel G, Buck M, Lund H, De Y, Newman Melker M. Cisplatin and gemcitabine induction chemotherapy followed by concurrent chemoradiotherapy or surgery for locally advanced non-small cell lung cancer. Intern Med J. 2005;35(6):336-42. NRP. [pmid: 15892762].
Caglar, Baldini EH, Othus M, Rabin MS, Bueno R, Sugarbaker DJ, Mentzer SJ, Janne PA, Johnson BE, Allen AM. Outcomes of patients with stage III nonsmall cell lung cancer treated with chemotherapy and radiation with and without surgery. Cancer. 2009;115(18):4156-66. NRP. [pmid: 19551884].
Caglayan, Fidan A, Salepci B, Kiral N, Torun E, Salepci T, Mayadagli A. Effects of prognostic factors and treatment on survival in advanced non-small cell lung cancer. Tuberk Toraks. 2004;52(4):323-32. NRP. [pmid: 15558354].
Cai, Dai FG, Min QF, Shi M, Miao JX, Luo RC. Clinical study of the effects of radiotherapy in combination with traditional Chinese medicine on non-small cell lung cancer. 2002;22:1112-3. FLA.
Cai, Xu LY, Wang L, Hayman JA, Chang AC, Pickens A, Cease KB, Orringer MB, Kong FM. Comparative survival in patients with postresection recurrent versus newly diagnosed non-small-cell lung cancer treated with radiotherapy. Int J Radiat Oncol Biol Phys. 2010;76(4):1100-5. NRP. [pmid: 19540063].
Cakir, Egehan I. A randomised clinical trial of radiotherapy plus cisplatin versus radiotherapy alone in stage III non-small cell lung cancer. Lung Cancer. 2004;43(3):309-16. NRP. [pmid: 15165089].
Call, Rami-Porta R, Obiols C, Serra-Mitjans M, Gonzalez-Pont G, Bastus-Piulats R, Quintana S, Belda-Sanchis J. Repeat mediastinoscopy in all its indications: Experience with 96 patients and 101 procedures. European Journal of Cardio-thoracic Surgery. 2011;39(6):1022-1027. NRP. [pmid: 21112217].
Camilleri, Lewis A, Eldeeb H. Concurrent chemoradiotherapy for NSCLC with cisplatin and etoposide - A single centre experience. Clinical Oncology. 2011;23(3):S32. NRD.
Cappuzzo, De Marinis F, Nelli F, Calandri C, Maestri A, Benedetti G, Migliorino MR, Cortesi E, Rastelli F, Martelli O, Andruccetti M, Bartolini S, Crino L. Phase II study of gemcitabine-cisplatin-paclitaxel triplet as induction chemotherapy in inoperable, locally-advanced non-small cell lung cancer. Lung Cancer. 2003;42(3):355-61. NRP. [pmid: 14644524].
Cappuzzo, Selvaggi G, Gregorc V, Mazzoni F, Betti M, Rita M, Novello Migliorino S, Maestri A, De Marinis F, Darwish S, De Angelis V, Nelli F, Bartolini S, Scagliotti GV, Tonato M, Crino L. Gemcitabine and cisplatin as induction chemotherapy for patients with unresectable Stage IIIA-bulky N2 and Stage IIIB nonsmall cell lung carcinoma: an Italian Lung Cancer Project Observational Study. Cancer. 2003;98(1):128-34. NRP. [pmid: 12833465].
Cardenal, Arnaiz MD, Moran T, Jove J, Nadal E, Porta R, Sole JM, Brao I, Palmero R, Fuentes R, Nunez I, Caveda E, Cassinello A. Phase I study of concurrent chemoradiation with pemetrexed and cisplatin followed by consolidation pemetrexed for patients with unresectable stage III non-small cell lung cancer. Lung Cancer. 2011;74(1):69-74. NRP. [pmid: 21353323].
Carter, Garfield D, Hathorn J, Mundis R, Boehm KA, Ilegbodu D, Asmar L, Reynolds C. A Randomized Phase III Trial of Combined Paclitaxel, Carboplatin, and Radiation Therapy Followed by Weekly Paclitaxel or Observation for Patients With Locally Advanced Inoperable Non-Small-Cell Lung Cancer. Clin Lung Cancer. 2011. NRP.
Casal, Varela S, Anido U, Lazaro M, Firvida JL, Vazquez S, Caeiro M, Calvo P, Huidobro G, Amenedo M. Induction chemotherapy with docetaxel (D) and cisplatin (C) followed by concurrent thoracic radiotherapy with biweekly d and C for stage III non-small cell lung cancer (NSCLC) - A galician lung cancer group study. European Journal of Cancer. 2011;47:S603. NRD.
Casas, Vinolas N, Ferrer F, Agusti C, Sanchez M, Maria J, Lomena Gimferrer F, Campayo M, Jeremic B. Long-term results of a phase II trial of induction paclitaxel-carboplatin followed by concurrent radiation therapy and weekly paclitaxel and consolidation paclitaxel-carboplatin in stage III non-small cell lung cancer. J Thorac Oncol. 2011;6(1):79-85. NRP. [pmid: 21150466].
Casas, Arguis P, Vinolas N, Lomena P, Marrades R, Catalan M. Radiofrequency ablation combined with conventional radiotherapy - A treatment option for patients with medically inoperable lung cancer. European Journal of Cancer. 2011;47:S603. NRD.
Catalano, Jereczek-Fossa BA, De Pas T, Leon ME, Cattani F, Spaggiari L, Veronesi G, de Braud F, Orecchia R. Three-times-daily radiotherapy with induction chemotherapy in locally advanced non-small cell lung cancer. Feasibility and toxicity study. Strahlenther Onkol. 2005;181(6):363-71. NRP. [pmid: 15925978].
Catalano, De Pas T, Spaggiari L, Gandini S, Jereczek-Fossa BA, De Braud F, Leo F, Veronesi G, Orecchia R. Three-times daily radiotherapy after chemotherapy in stage III non-small cell lung cancer. Single-institution prospective study. Anticancer Res. 2008;28(6B):4121-7. NRP. [pmid: 19192671].
Center, Petty WJ, Ayala D, Hinson WH, Lovato J, Capellari J, Oaks T, Miller AA, Blackstock AW. A phase I study of gefitinib with concurrent dose-escalated weekly docetaxel and conformal three-dimensional thoracic radiation followed by consolidative docetaxel and maintenance gefitinib for patients with stage III non-small cell lung cancer. J Thorac Oncol. 2010;5(1):69-74. NRP. [pmid: 20035186].
Ceresoli, Gregorc V, Cordio S, Bencardino KB, Schipani S, Cozzarini C, Bordonaro R, Villa E. Phase II study of weekly paclitaxel as second-line therapy in patients with advanced non-small cell lung cancer. Lung Cancer. 2004;44(2):231-9. NRP. [pmid: 15084388].
Cerfolio, Bryant AS, Scott E, Sharma M, Robert F, Spencer SA, Garver RI. Women with pathologic stage I, II, and III non-small cell lung cancer have better survival than men. Chest. 2006;130(6):1796-1802. NRP. [pmid: 17166999].
Cesario, Margaritora S, Trodella L, Valente S, Corbo GM, Macis G, Galetta D, d’Angelillo RM, Porziella V, Ramella S, Mangiacotti MG, Granone P. Incidental surgical findings of a phase I trial of weekly gemcitabine and concurrent radiotherapy in patients with unresectable non-small cell lung cancer. Lung Cancer. 2002;37(2):207-12. NRP. [pmid: 12140144].
Cetingoz, Kentli S, Ataman OU, Kinay M. Is hypofractionated reirradiation effective after symptomatic local recurrence in non-small cell lung cancer?. Journal of BUON. 2000;5(4):421-425. NRP.
Cetingoz, Kentli S, Uruk O, Demirtas E, Sen M, Kinay M. The role of palliative radiotherapy in locally advanced non-small cell lung cancer. Neoplasma. 2001;48(6):506-10. NRP. [pmid: 11949846].
Chakravarthy, Choy H. A phase I trial of outpatient weekly irinotecan/carboplatin and concurrent radiation for stage III unresectable non small-cell lung cancer: a Vanderbilt-Ingram Cancer Center Affiliate Network Trial. Clin Lung Cancer. 2000;1(4):310-1. NRP. [pmid: 14733637].
Chan, Dupuy DE, Mayo-Smith WW, Ng T, DiPetrillo TA. Combined radiofrequency ablation and high-dose rate brachytherapy for early-stage non-small-cell lung cancer. Brachytherapy. 2011;10(3):253-9. NRI. [pmid: 20739227].
Chang, Chi KH, Kao SJ, Hsu PS, Tsang YW, Chang HJ, Yeh YW, Hsieh YS, Jiang JS. Upfront gefitinib/erlotinib treatment followed by concomitant radiotherapy for advanced lung cancer: a mono-institutional experience. Lung Cancer. 2011;73(2):189-94. NRP. [pmid: 21247653].
Chang, Balter PA, Dong L, Yang Q, Liao Z, Jeter M, Bucci MK, McAleer MF, Mehran RJ, Roth JA, Komaki R. Stereotactic body radiation therapy in centrally and superiorly located stage I or isolated recurrent non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2008;72(4):967-71. NRP. [pmid: 18954709].
Chang, Komaki R, Lu C, Wen HY, Allen PK, Tsao A, Gillin M, Mohan R, Cox JD. Phase 2 study of high-dose proton therapy with concurrent chemotherapy for unresectable stage III nonsmall cell lung cancer. Cancer. 2011;117(20):4707-4713. NRP. [pmid: 21437893].
Chang, Komaki R, Wen HY, De Gracia B, Bluett JB, McAleer MF, Swisher SG, Gillin M, Mohan R, Cox JD. Toxicity and patterns of failure of adaptive/ablative proton therapy for early-stage, medically inoperable non-small cell lung cancer. Int J Radiat Oncol Biol Phys. 2011;80(5):1350-7. NRP. [pmid: 21251767].
Chang, Komaki R, Sasaki R, Liao Z, Stevens CW, Lu C, Fossella FV, Allen PK, Cox JD, Spitz MR, Wu X. High mutagen sensitivity in peripheral blood lymphocytes predicts poor overall and disease-specific survival in patients with stage III non-small cell lung cancer treated with radiotherapy and chemotherapy. Clin Cancer Res. 2005;11(8):2894-8. NRP. [pmid: 15837739].
Chapet, Kong FM, Lee JS, Hayman JA, Ten Haken RK. Normal tissue complication probability modeling for acute esophagitis in patients treated with conformal radiation therapy for non-small cell lung cancer. Radiother Oncol. 2005;77(2):176-81. NRP. [pmid: 16256230].
Chen, Neville BA, Sher DJ, Chen K, Schrag D. Survival outcomes after radiation therapy for stage III non-small-cell lung cancer after adoption of computed tomography-based simulation. J Clin Oncol. 2011;29(17):2305-11. NRP. [pmid: 21537034].
Chen, Jiang GL, Qian H, Wang LJ, Yang HJ, Fu XL, Wu KL, Zang Z, Zhao S. Escalated hyperfractionated accelerated radiation therapy for locally advanced non-small cell lung cancer: a clinical phase II trial. Radiother Oncol. 2004;71(2):157-62. NRP. [pmid: 15110448].
Chen, Jiang GL, Fu XL, Wang LJ, Qian H, Zhao S, Liu TF. Prognostic factors for local control in non-small-cell lung cancer treated with definitive radiation therapy. Am J Clin Oncol. 2002;25(1):76-80. NRP. [pmid: 11823702].
Chen, Hayman JA, Ten RK, Tatro Haken D, Fernando S, Kong FM. Long-term results of high-dose conformal radiotherapy for patients with medically inoperable T1-3N0 non-small-cell lung cancer: is low incidence of regional failure due to incidental nodal irradiation?. Int J Radiat Oncol Biol Phys. 2006;64(1):120-6. NRP. [pmid: 16198503].
Chen, Chen JH, Shih JY, Yang CH, Yu CJ, Yang PC. Octogenarians with advanced non-small cell lung cancer: treatment modalities, survival, and prognostic factors. J Thorac Oncol. 2010;5(1):82-9. NRP. [pmid: 19884854].
Chen, Chao JY, Tsai CM, Shiau CY, Liang MJ, Yen SH, Perng RP. Treatment of non-small-cell lung cancer: the Chinese experience in a general teaching hospital. Zhonghua Yi Xue Za Zhi (Taipei). 2000;63(6):459-66. NRD. [pmid: 10925536].
Chen, Pandya KJ, Hyrien O, Keng PC, Smudzin T, Anderson J, Qazi R, Smith B, Watson TJ, Feins RH, Johnstone DW. Preclinical and pilot clinical studies of docetaxel chemoradiation for Stage III non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2011;80(5):1358-64. NRP. [pmid: 20708854].
Chen, Ignacio L, Jacobs R, Kozloff M, Telfer M, Elahi R, Evans R, Vijayakumar S. Results of a phase II concurrent chemoradiotherapy study using three-dimensional conformal radiotherapy with cisplatin and oral etoposide in stage III nonsmall-cell lung cancer. Radiat Oncol Investig. 1999;7(1):49-53. NRP.
Chen, Matsuo Y, Yoshizawa A, Sato T, Sakai H, Bando T, Okubo K, Shibuya K, Date H. Salvage lung resection for non-small cell lung cancer after stereotactic body radiotherapy in initially operable patients. J Thorac Oncol. 2010;5(12):1999-2002. NRI. [pmid: 21102261].
Chen, Chen YY, Bao Y, Xian CG, Liu GZ, Zhang L, Xu GC, Deng XW, Lu TX, Qian JY, Cui NJ. Neoadjuvant chemotherapy followed by late-course accelerated hyperfractionated radiation therapy for locally advanced non-small-cell lung cancer: long-term results of a phase I/II clinical trial. Clin Lung Cancer. 2005;6(5):304-9. NRP. [pmid: 15845182].
Cheruvu, Metcalfe SK, Metcalfe J, Chen Y, Okunieff P, Milano MT. Comparison of outcomes in patients with stage III versus limited stage IV non-small cell lung cancer. Radiat Oncol. 2011;6:80. NRP. [pmid: 21718501].
Cheung, Yeung LT, Basrur V, Ung YC, Balogh J, Danjoux CE. Accelerated hypofractionation for early-stage non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2002;54(4):1014-23. NRI. [pmid: 12419427].
Cheung, Mackillop WJ, Dixon P, Brundage MD, Youssef YM, Zhou S. Involved-field radiotherapy alone for early-stage non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2000;48(3):703-10. NRI. [pmid: 11020567].
Chidel, Suh JH, Greskovich JF, Kupelian PA, Barnett GH. Treatment outcome for patients with primary nonsmall-cell lung cancer and synchronous brain metastasis. Radiat Oncol Investig. 1999;7(5):313-9. NRP.
Chien, Chen SW, Hsieh CY, Liang JA, Yang SN, Huang CY, Lin FJ. Intra-thoracic failure pattern and survival status following 3D conformal radiotherapy for non-small cell lung cancer: a preliminary report. Jpn J Clin Oncol. 2001;31(2):55-60. NRP. [pmid: 11302342].
Chien, Hsu YC, Wang YC, Ting LL. Clinical risk factors of radiation pneumonitis after 3D conformal radiotherapy for lung cancer. Chinese Journal of Radiology. 2005;30(1):25-29. NRP.
Chikamori, Kishino D, Takigawa N, Hotta K, Nogami N, Kamei H, Kuyama S, Gemba K, Takemoto M, Kanazawa S, Ueoka H, Segawa Y, Takata S, Tabata M, Kiura K, Tanimoto M. A phase I study of combination S-1 plus cisplatin chemotherapy with concurrent thoracic radiation for locally advanced non-small cell lung cancer. Lung Cancer. 2009;65(1):74-9. NRP. [pmid: 19056143].
Cho, Ahn SJ, Pyo HR, Kim KS, Kim YC, Moon SH, Han JY, Kim HT, Koom WS, Lee JS. A Phase II study of synchronous three-dimensional conformal boost to the gross tumor volume for patients with unresectable Stage III non-small-cell lung cancer: results of Korean Radiation Oncology Group 0301 study. Int J Radiat Oncol Biol Phys. 2009;74(5):1397-404. NRP. [pmid: 19117690].
Choong, Mauer AM, Haraf DJ, Lester E, Hoffman PC, Kozloff M, Lin S, Dancey JE, Szeto L, Grushko T, Olopade OI, Salgia R, Vokes EE. Phase I trial of erlotinib-based multimodality therapy for inoperable stage III non-small cell lung cancer. J Thorac Oncol. 2008;3(9):1003-11. NRP. [pmid: 18758303].
Choong, Vokes EE, Haraf DJ, Tothy PK, Ferguson MK, Kasza K, Rudin CM, Hoffman PC, Krauss SA, Szeto L, Mauer AM. Phase I study of induction chemotherapy and concomitant chemoradiotherapy with irinotecan, carboplatin, and paclitaxel for stage III non-small cell lung cancer. J Thorac Oncol. 2008;3(1):59-67. NRP. [pmid: 18166842].
Choy, Chakravarthy A, Devore RF 3rd, Jagasia M, Hande KR, Roberts JR, Johnson DH, Yunus F. Weekly irinotecan and concurrent radiation therapy for stage III unresectable NSCLC. Oncology (Williston Park). 2000;14(7 Suppl 5):43-6. NRP. [pmid: 10981290].
Choy, Jain AK, Moughan J, Curran W, Whipple G, Demas WF, Ettinger DS. RTOG 0017: a phase I trial of concurrent gemcitabine/carboplatin or gemcitabine/paclitaxel and radiation therapy (“ping-pong trial”) followed by adjuvant chemotherapy for patients with favorable prognosis inoperable stage IIIA/B non-small cell lung cancer. J Thorac Oncol. 2009;4(1):80-6. NRP. [pmid: 19096311].
Choy, Nabid A, Stea B, Scott C, Roa W, Kleinberg L, Ayoub J, Smith C, Souhami L, Hamburg S, Spanos W, Kreisman H, Boyd AP, Cagnoni PJ, Curran WJ. Phase II multicenter study of induction chemotherapy followed by concurrent efaproxiral (RSR13) and thoracic radiotherapy for patients with locally advanced non-small-cell lung cancer. J Clin Oncol. 2005;23(25):5918-28. NRD. [pmid: 16135463].
Choy, Safran H, Akerley W, Graziano SL, Bogart JA, Cole BF. Phase II trial of weekly paclitaxel and concurrent radiation therapy for locally advanced non-small cell lung cancer. Clin Cancer Res. 1998;4(8):1931-6. NRP. [pmid: 9717821].
Choy, Yee L, Cole BF. Combined-modality therapy for advanced non-small cell lung cancer: paclitaxel and thoracic irradiation. Semin Oncol. 1995;22(6 Suppl 15):38-44. NRP. [pmid: 8643969].
Choy, Devore RF 3rd, Hande KR, Porter LL, Rosenblatt P, Yunus F, Schlabach L, Smith C, Shyr Y, Johnson DH. A phase II study of paclitaxel, carboplatin, and hyperfractionated radiation therapy for locally advanced inoperable non-small-cell lung cancer (a Vanderbilt Cancer Center Affiliate Network Study). Int J Radiat Oncol Biol Phys. 2000;47(4):931-7. NRP. [pmid: 10863062].
Choy, DeVore RF 3rd, Hande KR, Porter LL, Rosenblatt P, Yunus F, Schlabach L, Smith C, Shyr Y, LaPorte K, Johnson DH. Preliminary analysis of a phase II study of paclitaxel, carboplatin, and hyperfractionated radiation therapy for locally advanced inoperable non-small cell lung cancer. Semin Oncol. 1997;24(4 Suppl 12):S12-21-S12-26. NRP.
Choy, DeVore RF, Hande KR, Porter LL, Rosenblatt PA, Slovis B, Laporte K, Shyr Y, Johnson DH. Phase I trial of outpatient weekly docetaxel, carboplatin and concurrent thoracic radiation therapy for stage III unresectable non-small-cell lung cancer: a Vanderbilt cancer center affiliate network (VCCAN) trial. Lung Cancer. 2001;34(3):441-9. NRP. [pmid: 11714542].
Clamon, Herndon J, Cooper R, Chang AY, Rosenman J, Green MR. Radiosensitization with carboplatin for patients with unresectable stage III non-small-cell lung cancer: a phase III trial of the Cancer and Leukemia Group B and the Eastern Cooperative Oncology Group. J Clin Oncol. 1999;17(1):4-11. NRP. [pmid: 10458211].
Coate, Massey C, Hope A, Sacher A, Barrett K, Pierre A, Leighl N, Brade A, de Perrot M, Waddell T, Liu G, Feld R, Burkes R, Cho BC, Darling G, Sun A, Keshavjee S, Bezjak A, Shepherd FA. Treatment of the elderly when cure is the goal: the influence of age on treatment selection and efficacy for stage III non-small cell lung cancer. J Thorac Oncol. 2011;6(3):537-44. NRP. [pmid: 21258243].
Coen, Van Lancker M, De W, Storme Neve G. Prognostic factors in locoregional non-small cell lung cancer treated with radiotherapy. Am J Clin Oncol. 1995;18(2):111-7. NRI. [pmid: 7900702].
Collen, Van Brummelen D, Versmessen H, Bral S, Schallier D, De J, De Ridder Greve M. Concurrent chemoradiation in locally advanced, Unresectable non small-Cell lung cancer (LA-NSCLC): Comparison of efficacy and treatment tolerance in the elderly. European Journal of Cancer. 2011;47:S276. NRD.
Collins, Erickson K, Reichner CA, Collins SP, Gagnon GJ, Dieterich S, McRae DA, Zhang Y, Yousefi S, Levy E, Chang T, Jamis-Dow C, Banovac F, Anderson ED. Radical stereotactic radiosurgery with real-time tumor motion tracking in the treatment of small peripheral lung tumors. Radiat Oncol. 2007;2:39. NRI. [pmid: 17953752].
Collins, Vahdat S, Erickson K, Collins SP, Suy S, Yu X, Zhang Y, Subramaniam D, Reichner CA, Sarikaya I, Esposito G, Yousefi S, Jamis-Dow C, Banovac F, Anderson ED. Radical cyberknife radiosurgery with tumor tracking: an effective treatment for inoperable small peripheral stage I non-small cell lung cancer. J Hematol Oncol. 2009;2:1. NRI. [pmid: 19149899].
Collins, Vahdat S, Collins SP, Oermann EK, Xia Y, Reichner C, Anderson E, Gharagozloo F, Margolis M. Cyberknife radiosurgery for inoperable patients with peripheral stage IA. International Journal of Medical Robotics and Computer Assisted Surgery. 2011;7:1. NRD.
Comella, Frasci G, Scoppa G, Guida C, Gravina A, Fiore F, Casaretti R, Daponte A, Ruffolo P, Comella P. Weekly paclitaxel/cisplatin with concurrent radiotherapy in patients with locally advanced non-small cell lung cancer: a phase I study. Semin Oncol. 1997;24(4 Suppl 12):S12-113-S12-116. NRP. [pmid: 9331134].
Concurrent chemoradiotherapy followed by consolidation docetaxel in stage IIIB non-small-cell-lung cancer (SWOG 9504). Clinical Lung Cancer. 2000;2(1):25-26. NRP. [pmid: 14731334].
Correa, Sharma V, Rangarajan V, Sunder S, Dinshaw KA. Can 99mTc-DTPA aerosol scanning predict radiation pneumonitis?. Int J Radiat Oncol Biol Phys. 2003;56(2):367-74. NRP. [pmid: 12738311].
Cortesi, Moscetti L, Nelli F, De Marinis F, De Paula U, Bangrazi C, Migliorino MR, Donato V. Induction therapy with paclitaxel and carboplatin followed by hyperfractionated radiotherapy plus weekly concurrent chemotherapy and subsequent consolidation therapy in unresectable locally advanced non-small-cell lung cancer. Tumori. 2007;93(2):133-7. NRP. [pmid: 17557558].
Corti, Toniolo L, Boso C, Colaut F, Fiore D, Muzzio PC, Koukourakis MI, Mazzarotto R, Pignataro M, Loreggian L, Sotti G. Long-term survival of patients treated with photodynamic therapy for carcinoma in situ and early non-small-cell lung carcinoma. Lasers Surg Med. 2007;39(5):394-402. NRP. [pmid: 17565719].
Crabtree, Denlinger CE, Meyers BF, El Naqa I, Zoole J, Krupnick AS, Kreisel D, Patterson GA, Bradley JD. Stereotactic body radiation therapy versus surgical resection for stage I non-small cell lung cancer. J Thorac Cardiovasc Surg. 2010;140(2):377-86. USD. [pmid: 20400121].
Cross, Berman S, Buswell L, Johnson B, Baldini EH. Prospective study of palliative hypofractionated radiotherapy (8.5 Gy x 2) for patients with symptomatic non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2004;58(4):1098-105. NRP. [pmid: 15001250].
Cruciani, Vergnenegre A, Blasco-Colmenares E, Thomas M, Medina J, Carrato A. Clinical management and treatment outcomes in patients receiving treatment for non-small cell lung cancer (NSCLC) across Europe - Epiclin-lung study. European Journal of Cancer. 2011;47:S609. NRD.
Crvenkova, Krstevska V. Sequential chemoradiotherapy compared with concurrent chemoradiotherapy in locally advanced non-small cell lung cancer: our experience. Prilozi. 2009;30(2):197-207. NRP. [pmid: 20087260].
Ulutin Cuneyt, Pak Y. Preliminary results of radiotherapy with or without weekly paclitaxel in locally advanced non-small cell lung cancer. J Cancer Res Clin Oncol. 2003;129(1):52-6. NRP. [pmid: 12618901].
Curran Jr, Choy H. Optimizing chemoradiation in locally advanced non-small-cell lung cancer. Oncology (Williston Park). 2001;15(3 Suppl 6):43-5. NRP. [pmid: 11301848].
Curran Jr, Paulus R, Langer CJ, Komaki R, Lee JS, Hauser S, Movsas B, Wasserman T, Rosenthal SA, Gore E, Machtay M, Sause W, Cox JD. Sequential vs. concurrent chemoradiation for stage III non-small cell lung cancer: randomized phase III trial RTOG 9410. J Natl Cancer Inst. 2011;103(19):1452-60. NRP. [pmid: 21903745].
Cyjon, Nili M, Fink G, Kramer MR, Fenig E, Sandbank J, Sulkes A, Rakowsky E. Advanced non-small cell lung cancer: induction chemotherapy and chemoradiation before operation. Ann Thorac Surg. 2002;74(2):342-7. NRP. [pmid: 12173811].
Dahele, Brade A, Pearson S, Bezjak A. Stereotactic radiation therapy for inoperable, early-stage non-small-cell lung cancer. CMAJ. 2009;180(13):1326-8. NRD. [pmid: 19546457].
Dahele, Palma D, Lagerwaard F, Slotman B, Senan S. Radiological changes after stereotactic radiotherapy for stage I lung cancer. J Thorac Oncol. 2011;6(7):1221-8. NRO. [pmid: 21623237].
Dai, Jiang W, Yuan J, Wei R. A randomized study on the effects of paclitaxel liposme and cisplatin induction chemotherapy followed concurrent chemoradiotherapy and sequential radiotherapy on locally advanced non-small cell lung cancer patients. 2011;14:137-40. FLA.
Dale, Harsaker V, Kristoffersen DT, Bruland O, Olsen DR. CT density in lung cancer patients after radiotherapy sensitized by metoclopramide. A subgroup analysis of a randomized trial. Strahlenther Onkol. 2010;186(3):163-8. NRP. [pmid: 20165821].
Dang, Li G, Lu X, Yao L, Zhang S, Yu Z. Analysis of related factors associated with radiation pneumonitis in patients with locally advanced non-small-cell lung cancer treated with three-dimensional conformal radiotherapy. J Cancer Res Clin Oncol. 2010;136(8):1169-78. NRP. [pmid: 20130912].
D’Angelillo, Trodella L, Ciresa M, Cellini F, Fiore M, Greco C, Pompeo E, Mineo TC, Paleari L, Granone P, Ramella S, Cesario A. Multimodality treatment of stage III non-small cell lung cancer: analysis of a phase II trial using preoperative cisplatin and gemcitabine with concurrent radiotherapy. J Thorac Oncol. 2009;4(12):1517-23. NRP. [pmid: 19875976].
Dasgupta, Dasgupta C, Basu S, Majumdar A. A prospective and randomized study of radiotherapy, sequential chemotherapy radiotherapy and concomitant chemotherapy-radiotherapy in unresectable non small cell carcinoma of the lung. J Cancer Res Ther. 2006;2(2):47-51. NRP. [pmid: 17998674].
Davies, Chansky K, Lau DH, Leigh BR, Gaspar LE, Weiss GR, Wozniak AJ, Crowley JJ, Gandara DR. Phase II study of consolidation paclitaxel after concurrent chemoradiation in poor-risk stage III non-small-cell lung cancer: SWOG S9712. J Clin Oncol. 2006;24(33):5242-6. NRP. [pmid: 17114656].
De Candis, Stani SC, Bidoli P, Bedini VA, Potepan P, Navarria P, Aglione S, Bajetta E. Induction chemotherapy with carboplatin/paclitaxel followed by surgery or standard radiotherapy and concurrent daily low-dose cisplatin for locally advanced non-small cell lung cancer (NSCLC). Am J Clin Oncol. 2003;26(3):265-9. NRP. [pmid: 12796598].
De Giorgi, Blaise D, Lange A, Viens P, Marangolo M, Madroszyk A, Brune M, Afanassiev BV, Rosti G, Demirer T. High-dose chemotherapy with peripheral blood progenitor cell support for patients with non-small cell lung cancer: the experience of the European Group for Bone Marrow Transplantation (EBMT) Solid Tumours Working Party. Bone Marrow Transplant. 2007;40(11):1045-8. NRP. [pmid: 17922037].
De Jaeger, Seppenwoolde Y, Boersma LJ, Muller SH, Baas P, Belderbos JS, Lebesque JV. Pulmonary function following high-dose radiotherapy of non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2003;55(5):1331-40. USD. [pmid: 12654445].
De Leyn, Vansteenkiste J, Lievens Y, Van Raemdonck D, Nafteux P, Decker G, Coosemans W, Decaluwe H, Moons J, Lerut T. Survival after trimodality treatment for superior sulcus and central T4 non-small cell lung cancer. J Thorac Oncol. 2009;4(1):62-8. NRP. [pmid: 19096308].
De Marinis, Nelli F, Migliorino MR, Martelli O, Cortesi E, Treggiari S, Portalone L, Crispino C, Brancaccio L, Gridelli C. Gemcitabine, paclitaxel, and cisplatin as induction chemotherapy for patients with biopsy-proven Stage IIIA(N2) nonsmall cell lung carcinoma: a Phase II multicenter study. Cancer. 2003;98(8):1707-15. NRP. [pmid: 14534888].
De Pas, Curigliano G, Veronesi G, Catalano G, Catania C, Jereczek-Fossa B, Orecchia R, Spaggiari L, de Braud F. Optimization of the schedule of gemcitabine-cisplatin combination as induction regimen for patients with biopsy-proven stage IIIa N2 - stage IIIb non-small-cell lung cancer: a prospective phase-II study. Bull Cancer. 2004;91(9):E273-7. NRP. [pmid: 15582897].
De Pauw, Van Meerbeeck JP. Resection vs radiotherapy following induction chemotherapy in stage IIIA-N2 non-small cell lung cancer: Randomized controlled trial. American Journal of Hematology/ Oncology. 2007;6(9):509-512. NRP.
De Petris, Lax I, Sirzen F, Friesland S. Role of gross tumor volume on outcome and of dose parameters on toxicity of patients undergoing chemoradiotherapy for locally advanced non-small cell lung cancer. Med Oncol. 2005;22(4):375-81. NRP. [pmid: 16260855].
De Ruysscher, Houben A, Aerts HJ, Dehing C, Wanders R, Ollers M, Dingemans AM, Hochstenbag M, Boersma L, Borger J, Dekker A, Lambin P. Increased (18)F-deoxyglucose uptake in the lung during the first weeks of radiotherapy is correlated with subsequent Radiation-Induced Lung Toxicity (RILT): a prospective pilot study. Radiother Oncol. 2009;91(3):415-20. NRP. [pmid: 19195730].
De Ruysscher, van Baardwijk A, Steevens J, Botterweck A, Bosmans G, Reymen B, Wanders R, Borger J, Dingemans AMC, Bootsma G, Pitz C, Lunde R, Geraedts W, Oellers M, Dekker A, Lambin P. Individualised isotoxic accelerated radiotherapy and chemotherapy are associated with improved long-term survival of patients with stage III NSCLC: A prospective population-based study. Radiotherapy and Oncology. 2011. NRP.
De Ruysscher, Dehing C, Yu S, Wanders R, Ollers M, Dingemans AM, Bootsma G, Hochstenbag M, Geraedts W, Pitz C, Simons J, Boersma L, Borger J, Dekker A, Lambin P. Dyspnea evolution after high-dose radiotherapy in patients with non-small cell lung cancer. Radiother Oncol. 2009;91(3):353-9. USD. [pmid: 19012981].
De Ruysscher, Wanders R, van Haren E, Hochstenbag M, Geraedts W, Pitz C, Simons J, Boersma L, Verschueren T, Minken A, Bentzen SM, Lambin P. HI-CHART: a phase I/II study on the feasibility of high-dose continuous hyperfractionated accelerated radiotherapy in patients with inoperable non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2008;71(1):132-8. NRP. [pmid: 18037581].
De Ruysscher, Wanders S, van Haren E, Hochstenbag M, Geeraedts W, Utama I, Simons J, Dohmen J, Rhami A, Buell U, Thimister P, Snoep G, Boersma L, Verschueren T, van Baardwijk A, Minken A, Bentzen SM, Lambin P. Selective mediastinal node irradiation based on FDG-PET scan data in patients with non-small-cell lung cancer: a prospective clinical study. Int J Radiat Oncol Biol Phys. 2005;62(4):988-94. NRP. [pmid: 15989999].
De Ruysscher, Lievens Y, Van den Brande P, Nackaerts K, Vansteenkiste J. Dose-intensified accelerated vindesine-ifosfamide-cisplatin (VIP) chemotherapy followed by high-dose accelerated hyperfractionated radiotherapy in patients with pathologically proven stage IIIB non-small cell lung cancer: a feasibility study. Radiother Oncol. 2002;64(1):33-6. NRP. [pmid: 12208572].
De Waele, Serra-Mitjans M, Hendriks J, Lauwers P, Belda-Sanchis J, Van P, Rami-Porta Schil R. Accuracy and survival of repeat mediastinoscopy after induction therapy for non-small cell lung cancer in a combined series of 104 patients. Eur J Cardiothorac Surg. 2008;33(5):824-8. NRP. [pmid: 18342528].
DeArmond, Mahtabifard A, Fuller CB, McKenna RJ Jr. Photodynamic therapy followed by thoracoscopic sleeve lobectomy for locally advanced lung cancer. Ann Thorac Surg. 2008;85(5):e24-6. NRD. [pmid: 18442525].
Debevec, Debeljak A, Erzen J, Kovac V, Kern I. Characterization of lung cancer patients, their actual treatment and survival: Experience in Slovenia. Radiology and Oncology. 2005;39(2):115-121+161. NRP.
DeCamp, Rice TW, Adelstein DJ, Chidel MA, Rybicki LA, Murthy SC, Blackstone EH. Value of accelerated multimodality therapy in stage IIIA and IIIB non-small cell lung cancer. J Thorac Cardiovasc Surg. 2003;126(1):17-27. NRP. [pmid: 12878935].
Decoster, Schallier D, Everaert H, Nieboer K, Meysman M, Neyns B, De J, De Greve Mey J. Complete metabolic tumour response, assessed by 18-fluorodeoxyglucose positron emission tomography (18FDG-PET), after induction chemotherapy predicts a favourable outcome in patients with locally advanced non-small cell lung cancer (NSCLC). Lung Cancer. 2008;62(1):55-61. NRP. [pmid: 18394750].
Dediu, Tarlea A, Iorga P, Radut M, Alexandru A, Miron G, Cornila C, Bailesteanu P. Split course radiation with concurrent vinorelbine and cisplatin in locally advanced non-small cell lung cancer. A phase II study. J BUON. 2004;9(2):167-72. NRP. [pmid: 17415809].
Dediu, Crisan E, Radut M, Tarlea A, Median D, Alexandru A, Vremes G, Gal C. The favorable prognostic significance of atelectasis in patients with advanced non-small cell lung cancer: Results of a prospective observational study. Lung Cancer. 2009;63(2):271-276. NRP. [pmid: 18565617].
Dehing-Oberije, De Ruysscher D, van der Weide H, Hochstenbag M, Bootsma G, Geraedts W, Pitz C, Simons J, Teule J, Rahmy A, Thimister P, Steck H, Lambin P. Tumor volume combined with number of positive lymph node stations is a more important prognostic factor than TNM stage for survival of non-small-cell lung cancer patients treated with (chemo)radiotherapy. Int J Radiat Oncol Biol Phys. 2008;70(4):1039-44. NRP. [pmid: 17889446].
Dehing-Oberije, De Ruysscher D, Petit S, Van Meerbeeck J, Vandecasteele K, De Neve W, Dingemans AM, El Naqa I, Deasy J, Bradley J, Huang E, Lambin P. Development, external validation and clinical usefulness of a practical prediction model for radiation-induced dysphagia in lung cancer patients. Radiother Oncol. 2010;97(3):455-61. NRO. [pmid: 21084125].
Dehing-Oberije, Yu S, De Ruysscher D, Meersschout S, Van Beek K, Lievens Y, Van Meerbeeck J, De Neve W, Rao B, van der Weide H, Lambin P. Development and external validation of prognostic model for 2-year survival of non-small-cell lung cancer patients treated with chemoradiotherapy. Int J Radiat Oncol Biol Phys. 2009;74(2):355-62. USD. [pmid: 19095367].
Descourt, Vergnenegre A, Barlesi F, Lena H, Fournel P, Falchero L, Berard H, Hureaux J, Le Caer H, Chavaillon JM, Geriniere L, Monnet I, Chouabe S, Robinet G. Oral vinorelbine and cisplatin with concurrent radiotherapy after induction chemotherapy with cisplatin and docetaxel for patients with locally advanced non-small cell lung cancer: the GFPC 05-03 study. J Thorac Oncol. 2011;6(2):351-7. NRP. [pmid: 21164367].
Dillman, Herndon J, Seagren SL, Eaton WL Jr, Green MR. Improved survival in stage III non-small-cell lung cancer: seven-year follow-up of cancer and leukemia group B (CALGB) 8433 trial. J Natl Cancer Inst. 1996;88(17):1210-5. NRP. [pmid: 8780630].
Din, Lester J, Cameron A, Ironside J, Gee A, Falk S, Morgan SA, Worvill J, Hatton MQ. Routine use of continuous, hyperfractionated, accelerated radiotherapy for non-small-cell lung cancer: a five-center experience. Int J Radiat Oncol Biol Phys. 2008;72(3):716-22. USD. [pmid: 18355975].
Dingemans, Bootsma G, Van Baardwijk A, Reijmen B, Wanders R, Hochstenbag M, Van Belle A, Houben R, Lambin P, De Ruysscher D. Determination of standard dose cetuximab together with concurrent individualised, isotoxic accelerated radiotherapy (RT) and cisplatin-vinorelbine for patients (pts) with stage III non-small cell lung cancer (NSCLC): A phase I study (NCT00522886). European Journal of Cancer. 2011;47:S602. NRD.
Divers, Spencer SA, Carey D, Busby EM, Hyatt MD, Robert F. Phase I/IIa study of cisplatin and gemcitabine as induction chemotherapy followed by concurrent chemoradiotherapy with gemcitabine and paclitaxel for locally advanced non-small-cell lung cancer. J Clin Oncol. 2005;23(27):6664-73. NRP. [pmid: 16170174].
Donato, Zurlo A, Bonfili P, Petrongari M, Santarelli M, Costa A, Enrici RM. Hypofractionated radiation therapy for inoperable advanced stage non-small cell lung cancer. Tumori. 1999;85(3):174-6. NRP. [pmid: 10426127].
Dowell, Sinard R, Yardley DA, Aviles V, Machtay M, Weber RS, Weinstein GS, Chalian AA, Carbone DP, Rosenthal DI. Seven-week continuous-infusion paclitaxel concurrent with radiation therapy for locally advanced non-small cell lung and head and neck cancers. Semin Radiat Oncol. 1999;9(2 Suppl 1):97-101. NRP. [pmid: 10210547].
Dupuy, DiPetrillo T, Gandhi S, Ready N, Ng T, Donat W, Mayo-Smith WW. Radiofrequency ablation followed by conventional radiotherapy for medically inoperable stage I non-small cell lung cancer. Chest. 2006;129(3):738-45. NRI. [pmid: 16537876].
Dworzecki, Idasiak A, Sygula D, Dworzecka U, Suwinski R. Stereotactic radiotherapy (SBRT) as asole or salvage therapy in non-small cell lung cancer patients. Neoplasma. 2012;59(1):114-20. USD. [pmid: 22103905].
Eberhardt, Stamatis G, Stuschke M, Wilke H, Muller MR, Kolks S, Flasshove M, Schutte J, Stahl M, Schlenger L, Budach V, Greschuchna D, Stuben G, Teschler H, Sack H, Seeber S. Prognostically orientated multimodality treatment including surgery for selected patients of small-cell lung cancer patients stages IB to IIIB: long-term results of a phase II trial. Br J Cancer. 1999;81(7):1206-12. NRP. [pmid: 10584883].
Eberhardt, Wilke H, Stamatis G, Stuschke M, Harstrick A, Menker H, Krause B, Mueller MR, Stahl M, Flasshove M, Budach V, Greschuchna D, Konietzko N, Sack H, Seeber S. Preoperative chemotherapy followed by concurrent chemoradiation therapy based on hyperfractionated accelerated radiotherapy and definitive surgery in locally advanced non-small-cell lung cancer: mature results of a phase II trial. J Clin Oncol. 1998;16(2):622-34. NRP. [pmid: 9469351].
Edelman, Suntharalingam M, Burrows W, Kwong KF, Mitra N, Gamliel Z, Riley M, Cooper LB, Kennedy NL, Buskirk S, Hausner P, Doyle LA, Krasna MJ. Phase I/II trial of hyperfractionated radiation and chemotherapy followed by surgery in stage III lung cancer. Ann Thorac Surg. 2008;86(3):903-10. NRP. [pmid: 18721580].
El Sharouni, Kal HB, Battermann JJ. Tumour control probability of stage III inoperable non-small cell lung tumours after sequential chemo-radiotherapy. Anticancer Res. 2005;25(6C):4655-61. NRP. [pmid: 16334157].
Elias, Skarin AT, Leong T, Mentzer S, Strauss G, Lynch T, Shulman L, Jacobs C, Abner A, Baldini EH, Frei E 3rd, Sugarbaker DJ. Neoadjuvant therapy for surgically staged IIIA N2 non-small cell lung cancer (NSCLC). Lung Cancer. 1997;17(1):147-61. NRP. [pmid: 9194034].
Endo, Takada Y, Obayashi K, Kotani Y, Satouchi M, Kado T, Sugimura K. Weekly paclitaxel and carboplatin with concurrent radiation therapy in locally advanced non-small cell lung cancer: phase I study. Radiat Med. 2005;23(5):331-5. NRP. [pmid: 16342905].
Erridge, Gaze MN, Price A, Kelly CG, Kerr GR, Cull A, MacDougall RH, Howard GC, Cowie VJ, Gregor A. Symptom control and quality of life in people with lung cancer: a randomised trial of two palliative radiotherapy fractionation schedules. 2005;17:61-7. NRP.
Eschmann, Friedel G, Paulsen F, Reimold M, Hehr T, Budach W, Scheiderbauer J, Machulla HJ, Dittmann H, Vonthein R, Bares R. Is standardised 18F-FDG uptake value an outcome predictor in patients with stage III non-small cell lung cancer?. European Journal of Nuclear Medicine and Molecular Imaging. 2006;33(3):263-269. NRP. [pmid: 16270214].
Etiz, Marks LB, Zhou SM, Bentel GC, Clough R, Hernando ML, Lind PA. Influence of tumor volume on survival in patients irradiated for non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2002;53(4):835-46. USD. [pmid: 12095548].
Fakiris, McGarry RC, Yiannoutsos CT, Papiez L, Williams M, Henderson MA, Timmerman R. Stereotactic body radiation therapy for early-stage non-small-cell lung carcinoma: four-year results of a prospective phase II study. Int J Radiat Oncol Biol Phys. 2009;75(3):677-82. NRI, USD. [pmid: 19251380].
Falk, Girling DJ, White RJ, Hopwood P, Harvey A, Qian W, Stephens RJ. Immediate versus delayed palliative thoracic radiotherapy in patients with unresectable locally advanced non-small cell lung cancer and minimal thoracic symptoms: randomised controlled trial. BMJ. 2002;325(7362):465. NRP. [pmid: 12202326].
Fang, Komaki R, Allen P, Guerrero T, Mohan R, Cox JD. Comparison of outcomes for patients with medically inoperable Stage I non-small-cell lung cancer treated with two-dimensional vs. three-dimensional radiotherapy. Int J Radiat Oncol Biol Phys. 2006;66(1):108-16. NRP. [pmid: 16904517].
Faria, Souhami L, Portelance L, Duclos M, Vuong T, Small D, Freeman CR. Absence of toxicity with hypofractionated 3-dimensional radiation therapy for inoperable, early stage non-small cell lung cancer. Radiat Oncol. 2006;1:42. NRP. [pmid: 17078878].
Farr, Khalil A, Knap M, Grau C. Radiation pneumonitis and treatment outcome in radical radiotherapy of stage III non small cell lung cancer. European Journal of Cancer. 2011;47:S605-S606. NRD.
Favaretto, Paccagnella A, Tomio L, Sartori F, Cipriani A, Zuin R, Reffosco L, Calabro F, Rea F, Ghiotto C, Chiarion-Sileni V, Oniga F, Loreggian L, Fiorentino MV. Pre-operative chemoradiotherapy in non-small cell lung cancer stage III patients. Feasibility, toxicity and long-term results of a phase II study. Eur J Cancer. 1996;32A(12):2064-9. NRP. [pmid: 9014746].
Felip, Del Campo JM, Bodi R, Vera R, Casado S, Rubio D. Cisplatin and vinorelbine followed by radiotherapy in the treatment of stage III-B non-small-cell lung cancer patients. Am J Clin Oncol. 1997;20(4):404-6. NRP. [pmid: 9256899].
Fernandes, Shen J, Finlay J, Mitra N, Evans T, Stevenson J, Langer C, Lin L, Hahn S, Glatstein E, Rengan R. Elective nodal irradiation (ENI) vs. involved field radiotherapy (IFRT) for locally advanced non-small cell lung cancer (NSCLC): A comparative analysis of toxicities and clinical outcomes. Radiother Oncol. 2010;95(2):178-84. NRP. [pmid: 20356642].
Fernandes, Mitra N, Xanthopoulos E, Evans T, Stevenson J, Langer C, Kucharczuk JC, Lin L, Rengan R. The Impact of Extent and Location of Mediastinal Lymph Node Involvement on Survival in Stage III Non-Small-Cell Lung Cancer Patients Treated with Definitive Radiotherapy. Int J Radiat Oncol Biol Phys. 2011. NRP.
Fernando, De Hoyos A, Landreneau RJ, Gilbert S, Gooding WE, Buenaventura PO, Christie NA, Belani C, Luketich JD. Radiofrequency ablation for the treatment of non-small cell lung cancer in marginal surgical candidates. J Thorac Cardiovasc Surg. 2005;129(3):639-44. OPP. [pmid: 15746749].
Fiorica, Cartei F, Ursino S, Stefanelli A, Zagatti Y, Berretta S, Figura S, Maugeri D, Zanet E, Sparta D, La Morella C, Tirelli U, Berretta M. Safety and feasibility of radiotherapy treatment in elderly non-small-cell lung cancer (NSCLC) patients. Arch Gerontol Geriatr. 2010;50(2):185-91. NRP. [pmid: 19410305].
Firat, Pleister A, Byhardt RW, Gore E. Age is independent of comorbidity influencing patient selection for combined modality therapy for treatment of stage III nonsmall cell lung cancer (NSCLC). Am J Clin Oncol. 2006;29(3):252-7. NRP. [pmid: 16755178].
Firat, Bousamra M, Gore E, Byhardt RW. Comorbidity and KPS are independent prognostic factors in stage I non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2002;52(4):1047-57. NRP. [pmid: 11958901].
Firat, Byhardt RW, Gore E. Comorbidity and Karnofksy performance score are independent prognostic factors in stage III non-small-cell lung cancer: an institutional analysis of patients treated on four RTOG studies. Radiation Therapy Oncology Group. Int J Radiat Oncol Biol Phys. 2002;54(2):357-64. NRP. [pmid: 12243808].
Fischer, Soberman M, Randolph P, Crawford K, Perry DJ. Phase II trial of concurrent paclitaxel, carboplatin, and external-beam radiation followed by surgical resection in locally advanced non-small-cell lung cancer, protocol 99-444. Clin Lung Cancer. 2006;8(1):56-61. NRP. [pmid: 16870047].
Forquer, Fakiris AJ, Timmerman RD, Lo SS, Perkins SM, McGarry RC, Johnstone PA. Brachial plexopathy from stereotactic body radiotherapy in early-stage NSCLC: dose-limiting toxicity in apical tumor sites. Radiother Oncol. 2009;93(3):408-13. NRP. [pmid: 19454366].
Fournel, Robinet G, Thomas P, Souquet PJ, Lena H, Vergnenegre A, Delhoume JY, Le Treut J, Silvani JA, Dansin E, Bozonnat MC, Daures JP, Mornex F, Perol M. Randomized phase III trial of sequential chemoradiotherapy compared with concurrent chemoradiotherapy in locally advanced non-small-cell lung cancer: Groupe Lyon-Saint-Etienne d’Oncologie Thoracique-Groupe Francais de Pneumo-Cancerologie NPC 95-01 Study. J Clin Oncol. 2005;23(25):5910-7. NRP. [pmid: 16087956].
Frasci, Comella P, Scoppa G, Guida C, Gravina A, Fiore F, Casaretti R, Daponte A, Parziale A, Comella G. Weekly paclitaxel and cisplatin with concurrent radiotherapy in locally advanced non-small-cell lung cancer: a phase I study. J Clin Oncol. 1997;15(4):1409-17. NRP. [pmid: 9193333].
Friedel, Hruska D, Budach W, Wolf M, Kyriss T, Hurtgen M, Eulenbruch HP, Dierkesmann R, Toomes H. Neoadjuvant chemoradiotherapy of stage III non-small-cell lung cancer. Lung Cancer. 2000;30(3):175-85. NRP. [pmid: 11137202].
Friedel, Budach W, Dippon J, Spengler W, Eschmann SM, Pfannenberg C, Al-Kamash F, Walles T, Aebert H, Kyriss T, Veit S, Kimmich M, Bamberg M, Kohlhaeufl M, Steger V, Hehr T. Phase II trial of a trimodality regimen for stage III non-small-cell lung cancer using chemotherapy as induction treatment with concurrent hyperfractionated chemoradiation with carboplatin and paclitaxel followed by subsequent resection: a single-center study. J Clin Oncol. 2010;28(6):942-8. NRP. [pmid: 20100967].
Fritz, Kraus HJ, Muhlnickel W, Hammer U, Dolken W, Engel-Riedel W, Chemaissani A, Stoelben E. Stereotactic, single-dose irradiation of stage I non-small cell lung cancer and lung metastases. Radiat Oncol. 2006;1:30. USD. [pmid: 16919172].
Fromm, Rottenfusser A, Berger D, Pirker R, Potter R, Pokrajac B. 3D-conformal radiotherapy for inoperable non-small-cell lung cancer - A single centre experience. Radiology and Oncology. 2007;41(3):133-143. USD.
Fujii, Kunikane H, Okamoto H, Watanabe K, Kunitoh H, Mori K, Yokoyama A, Fukuda H, Tamura T, Saijo N. A phase II study of cisplatin and irinotecan as induction chemotherapy followed by accelerated hyperfractionated thoracic radiotherapy with daily low-dose carboplatin in unresectable stage III non-small cell lung cancer: JCOG 9510. Jpn J Clin Oncol. 2009;39(12):784-90. NRP. [pmid: 19770129].
Fujino, Shirato H, Onishi H, Kawamura H, Takayama K, Koto M, Onimaru R, Nagata Y, Hiraoka M. Characteristics of patients who developed radiation pneumonitis requiring steroid therapy after stereotactic irradiation for lung tumors. Cancer J. 2006;12(1):41-6. NRP. [pmid: 16613661].
Fukuda, Soda H, Kinoshita A, Nakamura Y, Nagashima S, Takatani H, Tsukamoto K, Kohno S, Oka M. Irinotecan and cisplatin with concurrent split-course radiotherapy in locally advanced nonsmall-cell lung cancer: a multiinstitutional phase 2 study. Cancer. 2007;110(3):606-13. NRP. [pmid: 17577234].
Fukumoto, Shirato H, Shimzu S, Ogura S, Onimaru R, Kitamura K, Yamazaki K, Miyasaka K, Nishimura M, Dosaka-Akita H. Small-volume image-guided radiotherapy using hypofractionated, coplanar, and noncoplanar multiple fields for patients with inoperable Stage I nonsmall cell lung carcinomas. Cancer. 2002;95(7):1546-53. USD. [pmid: 12237924].
Furuse, Kubota K, Kawahara M, Kodama N, Ogawara M, Akira M, Nakajima S, Takada M, Kusunoki Y, Negoro S, et al. Phase II study of concurrent radiotherapy and chemotherapy for unresectable stage III non-small-cell lung cancer. Southern Osaka Lung Cancer Study Group. J Clin Oncol. 1995;13(4):869-75. NRP. [pmid: 7707113].
Furuse, Fukuoka M, Kawahara M, Nishikawa H, Takada Y, Kudoh S, Katagami N, Ariyoshi Y. Phase III study of concurrent versus sequential thoracic radiotherapy in combination with mitomycin, vindesine, and cisplatin in unresectable stage III non-small-cell lung cancer. J Clin Oncol. 1999;17(9):2692-9. NRP. [pmid: 10561343].
Furuta, Hayakawa K, Katano S, Saito Y, Nakayama Y, Takahashi T, Imai R, Ebara T, Mitsuhashi N, Niibe H. Radiation therapy for stage I–II non-small cell lung cancer in patients aged 75 years and older. Jpn J Clin Oncol. 1996;26(2):95-8. NRI. [pmid: 8609701].
Gadaleta, Catino A, Mattioli V. Radiofrequency thermal ablation in the treatment of lung malignancies. In Vivo. 2006;20(6A):765-7. NRP. [pmid: 17203764].
Gadgeel, Ruckdeschel JC, Patel BB, Wozniak A, Konski A, Valdivieso M, Hackstock D, Chen W, Belzer K, Burger AM, Marquette L, Turrisi A. Phase II study of pemetrexed and cisplatin, with chest radiotherapy followed by docetaxel in patients with stage III non-small cell lung cancer. J Thorac Oncol. 2011;6(5):927-33. NRP. [pmid: 21415776].
Gagel, Piroth M, Pinkawa M, Reinartz P, Zimny M, Fischedik K, Stanzel S, Breuer C, Skobel E, Asadpour B, Schmachtenberg A, Buell U, Eble MJ. Gemcitabine concurrent with thoracic radiotherapy after induction chemotherapy with gemcitabine/vinorelbine in locally advanced non-small cell lung cancer: a phase I study. Strahlenther Onkol. 2006;182(5):263-9. NRP. [pmid: 16673059].
Gagel, Piroth M, Pinkawa M, Reinartz P, Krohn T, Kaiser HJ, Stanzel S, Breuer C, Asadpour B, Schmachtenberg A, Eble MJ. Sequential (gemcitabine/vinorelbine) and concurrent (gemcitabine) radiochemotherapy with FDG-PET-based target volume definition in locally advanced non-small cell lung cancer: first results of a phase I/II study. BMC Cancer. 2007;7:112. NRP. [pmid: 17598906].
Galetta, Cesario A, Margaritora S, Porziella V, Piraino A, D’Angelillo RM, Gambacorta MA, Ramella S, Trodella L, Valente S, Corbo GM, Macis G, Mule A, Cardaci V, Sterzi S, Granone P, Russo P. Multimodality treatment of unresectable stage III non-small cell lung cancer: interim analysis of a phase II trial with preoperative gemcitabine and concurrent radiotherapy. J Thorac Cardiovasc Surg. 2006;131(2):314-21. NRP. [pmid: 16434259].
Galetta, Cesario A, Margaritora S, Porziella V, Macis G, D’Angelillo RM, Trodella L, Sterzi S, Granone P. Enduring challenge in the treatment of nonsmall cell lung cancer with clinical stage IIIB: results of a trimodality approach. Ann Thorac Surg. 2003;76(6):1802-8. discussion 1808–9. NRP. [pmid: 14667587].
Gandara, Chansky K, Albain KS, Leigh BR, Gaspar LE, Lara PN Jr, Burris H, Gumerlock P, Kuebler JP, Bearden JD 3rd, Crowley J, Livingston R. Consolidation docetaxel after concurrent chemoradiotherapy in stage IIIB non-small-cell lung cancer: phase II Southwest Oncology Group Study S9504. J Clin Oncol. 2003;21(10):2004-10. NRP. [pmid: 12743155].
Gandara, Chansky K, Albain KS, Gaspar LE, Lara PN Jr, Kelly K, Crowley J, Livingston R. Long-term survival with concurrent chemoradiation therapy followed by consolidation docetaxel in stage IIIB non-small-cell lung cancer: a phase II Southwest Oncology Group Study (S9504). Clin Lung Cancer. 2006;8(2):116-21. NRP. [pmid: 17026812].
Garrido, Rosell R, Massuti B, Cardenal F, Alberola V, Domine M, Maeztu I, Ramos A, Arellano A. Predictors of long-term survival in patients with lung cancer included in the randomized Spanish Lung Cancer Group 0008 phase II trial using concomitant chemoradiation with docetaxel and carboplatin plus induction or consolidation chemotherapy. Clin Lung Cancer. 2009;10(3):180-6. NRP. [pmid: 19443338].
Gaspar, Teixeira E, Sotto-Mayor R, Ortiz M, Susano R. Sequential chemo-radiation in non-small cell lung cancer: A retrospective study of 100 patients. Revista Portuguesa de Pneumologia. 2003;9(3):215-223. FLA. [pmid: 14685632].
Gauden, Tripcony L. The curative treatment by radiation therapy alone of Stage I non-small cell lung cancer in a geriatric population. Lung Cancer. 2001;32(1):71-9. NRI. [pmid: 11282431].
Gauden, Ramsay J, Tripcony L. The curative treatment by radiotherapy alone of stage I non-small cell carcinoma of the lung. Chest. 1995;108(5):1278-82. NRI. [pmid: 7587429].
Ghosh, Sujendran V, Alexiou C, Beggs L, Beggs D. Long term results of surgery versus continuous hyperfractionated accelerated radiotherapy (CHART) in patients aged >70 years with stage 1 non-small cell lung cancer. Eur J Cardiothorac Surg. 2003;24(6):1002-7. NRI. [pmid: 14643820].
Giannitto, Giuffrida D, Pappalardo A, Russo A, Vincenzi B, Saita S, Potenza E, Marletta F, La Venia G, Castorina S, Bordonaro R. Paclitaxel, carboplatin and gemcitabine combination as induction chemotherapy for stage IIIA N2 bulky non-small cell lung cancer. Oncology. 2005;69(4):295-300. NRP. [pmid: 16282709].
Gielda, Marsh JC, Zusag TW, Faber LP, Liptay M, Basu S, Warren WH, Fidler MJ, Batus M, Abrams RA, Bonomi P. Split-course chemoradiotherapy for locally advanced non-small cell lung cancer: a single-institution experience of 144 patients. J Thorac Oncol. 2011;6(6):1079-86. NRP. [pmid: 21532501].
Gielda, Mehta P, Khan A, Marsh JC, Zusag TW, Warren WH, Fidler MJ, Abrams RA, Bonomi P, Liptay M, Faber LP. Weight gain in advanced non-small-cell lung cancer patients during treatment with split-course concurrent chemoradiotherapy is associated with superior survival. Int J Radiat Oncol Biol Phys. 2011;81(4):985-91. NRP. [pmid: 20932684].
Giorgio, Pappalardo A, Russo A, Santini D, Di Rosa C, Di Salvo C, Castorina S, Marletta F, Bellissima G, Palermo N, Scuderi C, Bordonaro R. A phase II study of induction chemotherapy followed by concurrent chemoradiotherapy in elderly patients with locally advanced non-small-cell lung cancer. Anticancer Drugs. 2007;18(6):713-9. NRP. [pmid: 17762402].
Girard, Mornex F, Douillard JY, Bossard N, Quoix E, Beckendorf V, Grunenwald D, Amour E, Milleron B. Is neoadjuvant chemoradiotherapy a feasible strategy for stage IIIA-N2 non-small cell lung cancer? Mature results of the randomized IFCT-0101 phase II trial. Lung Cancer. 2010;69(1):86-93. NRP. [pmid: 19879013].
Gobitti, Franchin G, Minatel E, Gigante M, Basso B, Bujor L, Trovo MG. Thoracic radiation therapy and concomitant low-dose daily paclitaxel in non-small cell lung cancer: a phase I study. Oncol Rep. 2005;14(6):1647-53. NRP. [pmid: 16273271].
Goldsmith, Cesaretti J, Wisnivesky JP. Radiotherapy Planning Complexity and Survival after Treatment of Advanced Stage Lung Cancer in the Elderly. Cancer. 2009;115(20):4865-4873. NRP. [pmid: 21423827].
Gollins, Ryder WD, Burt PA, Barber PV, Stout R. Massive haemoptysis death and other morbidity associated with high dose rate intraluminal radiotherapy for carcinoma of the bronchus. Radiother Oncol. 1996;39(2):105-16. USD. [pmid: 8735477].
Gomez. Predictive dosimetric factors for high-grade esophagitis in patients treated for non-small cell lung cancer (NSCLC) with definitive 3D conformal therapy (3D-CRT), intensity modulated radiation therapy (IMRT), or proton beam therapy (PBT). Radiotherapy and Oncology. 2011;99:S210. NRD.
Gopal, Starkschall G, Tucker SL, Cox JD, Liao Z, Hanus M, Kelly JF, Stevens CW, Komaki R. Effects of radiotherapy and chemotherapy on lung function in patients with non-small-cell lung cancer. International Journal of Radiation Oncology Biology Physics. 2003;56(1):114-120. NRP.
Gore, Bae K, Langer C, Extermann M, Movsas B, Okunieff P, Videtic G, Choy H. Phase I/II trial of a COX-2 inhibitor with limited field radiation for intermediate prognosis patients who have locally advanced non-small-cell lung cancer: radiation therapy oncology group 0213. Clin Lung Cancer. 2011;12(2):125-30. NRP. [pmid: 21550559].
Gore, Bae K, Wong SJ, Sun A, Bonner JA, Schild SE, Gaspar LE, Bogart JA, Werner-Wasik M, Choy H. Phase III comparison of prophylactic cranial irradiation versus observation in patients with locally advanced non-small-cell lung cancer: primary analysis of radiation therapy oncology group study RTOG 0214. J Clin Oncol. 2011;29(3):272-8. NRP. [pmid: 21135270].
Gouda, Kohail HM, Eldeeb NA, Omar AM, El-Geneidy MM, Elkerm YM. Randomized study of concurrent carboplatin, paclitaxel, and radiotherapy with or without prior induction chemotherapy in patients with locally advanced non-small cell lung cancer. J Egypt Natl Canc Inst. 2006;18(1):73-81. NRP. [pmid: 17237853].
Gouders, Maingon P, Paesmans M, Rodrigus P, Hahn B, Arnaiz MD, Nguyen T, Landmann C, Bosset JF, Danhier S, Van Houtte P. Exclusive radiotherapy for non small cell lung cancer. A retrospective multicentric study. Reports of Practical Oncology and Radiotherapy. 2003;8(1):7-14. NRI.
Govindan, Bogart J, Stinchcombe T, Wang X, Hodgson L, Kratzke R, Garst J, Brotherton T, Vokes EE. Randomized phase II study of pemetrexed, carboplatin, and thoracic radiation with or without cetuximab in patients with locally advanced unresectable non-small-cell lung cancer: Cancer and Leukemia Group B trial 30407. J Clin Oncol. 2011;29(23):3120-5. NRP. [pmid: 21747084].
Graham, Clark C, Abell F, Browne L, Capp A, Clingan P, De Sousa P, Fox C, Links M. Concurrent end-phase boost high-dose radiation therapy for non-small-cell lung cancer with or without cisplatin chemotherapy. Australas Radiol. 2006;50(4):342-8. NRP. [pmid: 16884421].
Graham, Purdy JA, Emami B, Matthews JW, Harms WB. Preliminary results of a prospective trial using three dimensional radiotherapy for lung cancer. Int J Radiat Oncol Biol Phys. 1995;33(5):993-1000. NRP. [pmid: 7493861].
Graham, Jahanzeb M, Dresler CM, Cooper JD, Emami B, Mortimer JE. Results of a trial with topotecan dose escalation and concurrent thoracic radiation therapy for locally advanced, inoperable nonsmall cell lung cancer. Int J Radiat Oncol Biol Phys. 1996;36(5):1215-20. NRP. [pmid: 8985046].
Graham, Pajak TE, Herskovic AM, Emami B, Perez CA. Phase I/II study of treatment of locally advanced (T3/T4) non-oat cell lung cancer with concomitant boost radiotherapy by the Radiation Therapy Oncology Group (RTOG 83-12): long-term results. Int J Radiat Oncol Biol Phys. 1995;31(4):819-25. NRP. [pmid: 7860394].
Graham, Gebski VJ, Langlands AO. Radical radiotherapy for early nonsmall cell lung cancer. Int J Radiat Oncol Biol Phys. 1995;31(2):261-6. NRI. [pmid: 7836078].
Granone, Margaritora S, Cesario A, Bonatti P, Galetta D, Picciocchi A. Concurrent radio-chemotherapy in N2 non small cell lung cancer: Interim analysis. European Journal of Cardio-thoracic Surgery. 1997;12(3):366-371. NRP. [pmid: 9332913].
Greco, Stroup SL, Hainsworth JD. Paclitaxel by 1-hour infusion in combination chemotherapy of stage III non-small cell lung cancer. Semin Oncol. 1995;22(4 Suppl 9):75-7. NRP. [pmid: 7644932].
Greco, Stroup SL, Gray JR, Hainsworth JD. Paclitaxel in combination chemotherapy with radiotherapy in patients with unresectable stage III non-small-cell lung cancer. J Clin Oncol. 1996;14(5):1642-8. NRP. [pmid: 8622083].
Greenberger, Belani CP, Leuketich JD, Argiris A, Ramalingam SS, Gooding W, Pennathur A, Petro D, Epperly MW, Tarhini AA. A phase I study demonstrating manganese superoxide dismutase plasmid liposome complex (MNSOD-Pl) reduction of esophagitis following standard chemoradiation in surgically unresectable stage III NSCLC. International Journal of Radiation Oncology Biology Physics. 2010;78(3):S201. NRD.
Greillier, Barlesi F, Doddoli C, Durieux O, Torre JP, Gimenez C, Kleisbauer JP. Vascular stenting for palliation of superior vena cava obstruction in non-small-cell lung cancer patients: a future ‘standard’ procedure?. Respiration. 2004;71(2):178-83. NRP. [pmid: 15031575].
Gridelli, Guida C, Barletta E, Gatani T, Fiore F, Barzelloni ML, Rossi A, de Bellis M, D’Aniello R, Scognamiglio F. Thoracic radiotherapy and daily vinorelbine as radiosensitizer in locally advanced non small cell lung cancer: a phase I study. Lung Cancer. 2000;29(2):131-7. NRP. [pmid: 10963843].
Grieco, Simon CJ, Mayo-Smith WW, DiPetrillo TA, Ready NE, Dupuy DE. Percutaneous image-guided thermal ablation and radiation therapy: outcomes of combined treatment for 41 patients with inoperable stage I/II non-small-cell lung cancer. J Vasc Interv Radiol. 2006;17(7):1117-24. NRI. [pmid: 16868164].
Grills, Mangona VS, Welsh R, Chmielewski G, McInerney E, Martin S, Wloch J, Ye H, Kestin LL. Outcomes after stereotactic lung radiotherapy or wedge resection for stage I non-small-cell lung cancer. J Clin Oncol. 2010;28(6):928-35. NRI. [pmid: 20065181].
Groen, van der Leest AH, de Vries EG, Uges DR, Szabo BG, Mulder NH. Continuous carboplatin infusion during 6 weeks’ radiotherapy in locally inoperable non-small-cell lung cancer: a phase I and pharmacokinetic study. Br J Cancer. 1995;72(4):992-7. NRP. [pmid: 7547255].
Groen, van der Leest AHW, Fokkema E, Timmer PR, Nossent GD, Smit WJG, Nabers J, Hoekstra HJ, Hermans J, Otter R, van Putten JWG, de Vries EGE, Mulder NH. Continuously infused carboplatin used as radiosensitizer in locally unresectable non-small-cell lung cancer: A multicenter phase III study. Annals of Oncology. 2004;15(3):427-432. NRP. [pmid: 14998844].
Groen, van der Mark TW, van der Leest AH, de Vries EG, Mulder NH. Pulmonary function changes in lung-cancer patients treated with radiation with or without carboplatin. Am J Respir Crit Care Med. 1995;152(6 Pt 1):2044-8. NRP. [pmid: 8520774].
Grossi, Millward M, Fisher R, Porceddu S, Mac M, Ryan Manus G, Wirth A, Ball D. Combined modality treatment using concurrent radiotherapy and pharmacologically-guided carboplatin for inoperable and incompletely resected non-small cell lung cancer. Lung Cancer. 2001;31(1):73-82. NRP. [pmid: 11162869].
Grunenwald, Andre F, Le Pechoux C, Girard P, Lamer C, Laplanche A, Tarayre M, Arriagada R, Le Chevalier T. Benefit of surgery after chemoradiotherapy in stage IIIB (T4 and/or N3) non-small cell lung cancer. J Thorac Cardiovasc Surg. 2001;122(4):796-802. NRP. [pmid: 11581616].
Guckenberger, Wulf J, Mueller G, Krieger T, Baier K, Gabor M, Richter A, Wilbert J, Flentje M. Dose-response relationship for image-guided stereotactic body radiotherapy of pulmonary tumors: relevance of 4D dose calculation. Int J Radiat Oncol Biol Phys. 2009;74(1):47-54. NRP. [pmid: 18977095].
Guckenberger, Heilman K, Wulf J, Mueller G, Beckmann G, Flentje M. Pulmonary injury and tumor response after stereotactic body radiotherapy (SBRT): results of a serial follow-up CT study. Radiother Oncol. 2007;85(3):435-42. NRP. [pmid: 18053602].
Haasbeek, Lagerwaard FJ, de Jaeger K, Slotman BJ, Senan S. Outcomes of stereotactic radiotherapy for a new clinical stage I lung cancer arising postpneumonectomy. Cancer. 2009;115(3):587-94. NRP. [pmid: 19130457].
Haasbeek, Lagerwaard FJ, Antonisse ME, Slotman BJ, Senan S. Stage I nonsmall cell lung cancer in patients aged > or =75 years: outcomes after stereotactic radiotherapy. Cancer. 2010;116(2):406-14. NRP. [pmid: 19950125].
Hainsworth, Vokes EE. Docetaxel (Taxotere) in combination with radiation therapy and the potential of weekly administration in elderly and/or poor performance status patients with advanced non-small cell lung cancer. Semin Oncol. 2001;28(1 Suppl 2):22-7. NRD. [pmid: 11284621].
Hainsworth, Gray JR, Litchy S, Bearden JD, Shaffer DW, Houston GA, Greco FA. A phase II trial of preoperative concurrent radiation therapy and weekly paclitaxel/carboplatin for patients with locally advanced non-small-cell lung cancer. Clin Lung Cancer. 2004;6(1):33-42. NRP. [pmid: 15310415].
Hallqvist, Wagenius G, Rylander H, Brodin O, Holmberg E, Loden B, Ewers SB, Bergstrom S, Wichardt-Johansson G, Nilsson K, Ekberg L, Sederholm C, Nyman J. Concurrent cetuximab and radiotherapy after docetaxel-cisplatin induction chemotherapy in stage III NSCLC: Satellite-A phase II study from the Swedish Lung Cancer Study Group. Lung Cancer. 2011;71(2):166-172. NRP. [pmid: 20541833].
Hamamoto, Sugawara Y, Inoue T, Kataoka M, Ochi T, Takahashi T, Sakai S. Relationship between pretreatment FDG uptake and local control after stereotactic body radiotherapy in stage I non-small-cell lung cancer: the preliminary results. Jpn J Clin Oncol. 2011;41(4):543-7. USD. [pmid: 21262874].
Hamouda, Dorgham Y, Yosry A, Abdel Wahab M. Neoadjuvant chemotherapy in locally advanced non-small cell lung cancer. Gulf J Oncolog. 2007;(2):55-64. NRP. [pmid: 20084725].
Han, Prasetyo D, Wright GM. Endobronchial palliation using Nd:YAG laser is associated with improved survival when combined with multimodal adjuvant treatments. Journal of Thoracic Oncology. 2007;2(1):59-64. USD. [pmid: 17410011].
Hanna, Neubauer M, Yiannoutsos C, McGarry R, Arseneau J, Ansari R, Reynolds C, Govindan R, Melnyk A, Fisher W, Richards D, Bruetman D, Anderson T, Chowhan N, Nattam S, Mantravadi P, Johnson C, Breen T, White A, Einhorn L. Phase III study of cisplatin, etoposide, and concurrent chest radiation with or without consolidation docetaxel in patients with inoperable stage III non-small-cell lung cancer: the Hoosier Oncology Group and U.S. Oncology J Clin Oncol. 2008;26(35):5755-60. NRP.
Harada, Yamamoto N, Takahashi T, Endo M, Murakami H, Tsuya A, Nakamura Y, Ono A, Igawa S, Shukuya T, Tamiya A, Nishimura T. Comparison of chemotherapy regimens for concurrent chemoradiotherapy in unresectable stage III non-small cell lung cancer. Int J Clin Oncol. 2009;14(6):507-12. NRP. [pmid: 19967486].
Harada, Seto T, Igawa S, Tsuya A, Wada M, Kaira K, Naito T, Hayakawa K, Nishimura T, Masuda N, Yamamoto N. Phase I Results of Vinorelbine with Concurrent Radiotherapy in Elderly Patients with Unresectable, Locally Advanced Non-Small-Cell Lung Cancer: West Japan Thoracic Oncology Group (WJTOG3005-DI). Int J Radiat Oncol Biol Phys. 2011. NRP.
Harms, Schraube P, Becker H, Latz D, Herth F, Fritz P, Wannenmacher M. Effect and toxicity of endoluminal high-dose-rate (HDR) brachytherapy in centrally located tumors of the upper respiratory tract. Strahlenther Onkol. 2000;176(2):60-6. USD. [pmid: 10697652].
Hartsell, Scott CB, Dundas GS, Mohiuddin M, Meredith RF, Rubin P, Weigensberg IJ. Can serum markers be used to predict acute and late toxicity in patients with lung cancer? Analysis of RTOG 91-03. Am J Clin Oncol. 2007;30(4):368-76. NRP. [pmid: 17762437].
Hasegawa, Takanashi S, Okudera K, Aoki M, Basaki K, Kondo H, Takahata T, Yasui-Furukori N, Tateishi T, Abe Y, Okumura K. Weekly paclitaxel and nedaplatin with concurrent radiotherapy for locally advanced non-small-cell lung cancer: a phase I/II study. Jpn J Clin Oncol. 2004;34(11):647-53. NRP. [pmid: 15613553].
Hata, Tokuuye K, Kagei K, Sugahara S, Nakayama H, Fukumitsu N, Hashimoto T, Mizumoto M, Ohara K, Akine Y. Hypofractionated high-dose proton beam therapy for stage I non-small-cell lung cancer: preliminary results of a phase I/II clinical study. Int J Radiat Oncol Biol Phys. 2007;68(3):786-93. NRP. [pmid: 17379439].
Hatton, Nankivell M, Lyn E, Falk S, Pugh C, Navani N, Stephens R, Parmar M. Induction chemotherapy and continuous hyperfractionated accelerated radiotherapy (chart) for patients with locally advanced inoperable non-small-cell lung cancer: the MRC INCH randomized trial. Int J Radiat Oncol Biol Phys. 2011;81(3):712-8. NRP. [pmid: 20932667].
Havemann, Wolf M, Goerg C, Faoro C, Pfab R, Diergarten K. Paclitaxel and simultaneous radiation in the treatment of stage III A/B non-small cell lung cancer. Semin Oncol. 1995;22(6 Suppl 14):19-22. NRP. [pmid: 8553078].
Hayakawa, Mitsuhashi N, Furuta M, Saito Y, Nakayama Y, Katano S, Yamakawa M, Hashida I, Niibe. High-dose radiation therapy for inoperable non-small cell lung cancer without mediastinal involvement (clinical stage N0, N1). Strahlenther Onkol. 1996;172(9):489-95. NRI. [pmid: 8830811].
Hayakawa, Mitsuhashi N, Katano S, Saito Y, Nakayama Y, Sakurai H, Akimoto T, Hasegawa M, Yamakawa M, Niibe H. High-dose radiation therapy for elderly patients with inoperable or unresectable non-small cell lung cancer. Lung Cancer. 2001;32(1):81-8. NRP. [pmid: 11282432].
Hayakawa, Mitsuhashi N, Saito Y, Furuta M, Nakayama Y, Katano S, Sakurai H, Takahashi T, Mitomo O, Niibe H. Impact of tumor extent and location on treatment outcome in patients with stage III non-small cell lung cancer treated with radiation therapy. Jpn J Clin Oncol. 1996;26(4):221-8. NRP. [pmid: 8765179].
Hayakawa, Mitsuhashi N, Saito Y, Nakayama Y, Furuta M, Sakurai H, Kawashima M, Ohno T, Nasu S, Niibe H. Limited field irradiation for medically inoperable patients with peripheral stage I non-small cell lung cancer. Lung Cancer. 1999;26(3):137-42. NRI. [pmid: 10598923].
Hayakawa, Mitsuhashi N, Saito Y, Nakayama Y, Furuta M, Nakamoto S, Kawashima M, Niibe H. Effect of Krestin as adjuvant treatment following radical radiotherapy in non-small cell lung cancer patients. Cancer Detect Prev. 1997;21(1):71-7. NRP. [pmid: 9043766].
Hayakawa, Mitsuhashi N, Saito Y, Nakayama Y, Katano S, Furuta M, Sakurai H, Takahashi T, Niibe H. Definitive radiation therapy for medically inoperable patients with stage I and II non-small cell lung cancer. Radiation Oncology Investigations. 1996;4(4):165-170. NRI.
Hayman, Martel MK, Ten RK, Normolle Haken DP, Todd RF 3rd, Littles JF, Sullivan MA, Possert PW, Turrisi AT, Lichter AS. Dose escalation in non-small-cell lung cancer using three-dimensional conformal radiation therapy: update of a phase I trial. J Clin Oncol. 2001;19(1):127-36. NRP. [pmid: 11134205].
Hayman, Abrahamse PH, Lakhani I, Earle CC, Katz SJ. Use of palliative radiotherapy among patients with metastatic non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2007;69(4):1001-7. NRP. [pmid: 17689029].
Hehr, Friedel G, Steger V, Spengler W, Eschmann SM, Bamberg M, Budach W. Neoadjuvant chemoradiation with paclitaxel/carboplatin for selected Stage III non-small-cell lung cancer: long-term results of a trimodality Phase II protocol. Int J Radiat Oncol Biol Phys. 2010;76(5):1376-81. NRP. [pmid: 19864078].
Heinzerling, Choy H, Hughes RS, Govindan R, Bradley JD, Schwartzberg LS, Peng G, Treat J, Tran T, Obasaju C. Toxicity and response of pemetrexed plus carboplatin or cisplatin with concurrent chest radiation therapy for patients with locally advanced non-small cell lung cancer: A phase i trial. Journal of Thoracic Oncology. 2010;5(9):1391-1396. NRP.
Henderson, Hoopes DJ, Fletcher JW, Lin PF, Tann M, Yiannoutsos CT, Williams MD, Fakiris AJ, McGarry RC, Timmerman RD. A pilot trial of serial 18F-fluorodeoxyglucose positron emission tomography in patients with medically inoperable stage I non-small-cell lung cancer treated with hypofractionated stereotactic body radiotherapy. Int J Radiat Oncol Biol Phys. 2010;76(3):789-95. OPP. [pmid: 19473777].
Henderson, McGarry R, Yiannoutsos C, Fakiris A, Hoopes D, Williams M, Timmerman R. Baseline pulmonary function as a predictor for survival and decline in pulmonary function over time in patients undergoing stereotactic body radiotherapy for the treatment of stage I non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2008;72(2):404-9. OPP. [pmid: 18394819].
Hennequin, Trédaniel J, Durdux C, Salemkour A, Zalcman G, Hirsch A, Housset M, Maylin C. Concomitant radiochemotherapy in inoperable non-small cell lung cancer. 1997;1:143-7. FLA.
Hepp, Pottgen C, Gauler T, Erichsen P, Le Pechoux C, Grunenwald D, Welter S, Stamatis G, Stuschke M, Eberhardt WEE. Long-term survival results and prognostic factor analysis of two consecutive trimodality Phase-II trials in stage IIIA(N2) and selected stage IIIB non-small-cell lung cancer (NSCLC). Strahlentherapie und Onkologie. 2011;187:68-69. NRD.
Herse, Dalichau H, Wormann B, Hemmerlein B, Schmidberger H, Hess CF, Hannemann P, Criee CP, Hiddemann W, Griesinger F. Induction combination chemotherapy with docetaxel and carboplatin in advanced non-small-cell lung cancer. Thorac Cardiovasc Surg. 1998;46(5):298-302. NRP. [pmid: 9885122].
Herskovic, Scott C, Demas W, Gaspar L, Trotti A. Accelerated hyperfractionation for bronchogenic cancer: Radiation Therapy Oncology Group 9205. Am J Clin Oncol. 2000;23(2):207-12. NRP. [pmid: 10776986].
Herth, Peter S, Baty F, Eberhardt R, Leuppi JD, Chhajed PN. Combined airway and oesophageal stenting in malignant airway-oesophageal fistulas: A prospective study. European Respiratory Journal. 2010;36(6):1370-1374. NRP. [pmid: 20525708].
Hicks, Mac MP, Matthews Manus JP, Hogg A, Binns D, Rischin D, Ball DL, Peters LJ. Early FDG-PET imaging after radical radiotherapy for non-small-cell lung cancer: inflammatory changes in normal tissues correlate with tumor response and do not confound therapeutic response evaluation. Int J Radiat Oncol Biol Phys. 2004;60(2):412-8. NRP. [pmid: 15380574].
Higgins, Chino JP, Marks LB, Ready N, D’Amico TA, Clough RW, Kelsey CR. Preoperative chemotherapy versus preoperative chemoradiotherapy for stage III (N2) non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2009;75(5):1462-7. NRP. [pmid: 19467798].
Hill, Nwogu CE, Loewen G, Pelow J, Dougherty TJ, Anderson TM. Off-Label Management of Primary and Metastatic Endobronchial Tumors with Photodynamic Therapy. Clinical Pulmonary Medicine. 2004;11(2):107-111. NRP.
Hillas, Bakakos P, Trichas M, Vlastos F. The disparity of health facilities in an urban area discourages proposed treatment application in inoperable lung cancer patients. Cancer Manag Res. 2010;2:287-91. NRP. [pmid: 21301588].
Hiraki, Gobara H, Mimura H, Toyooka S, Fujiwara H, Yasui K, Sano Y, Iguchi T, Sakurai J, Tajiri N, Mukai T, Matsui Y, Kanazawa S. Radiofrequency ablation of lung cancer at Okayama University Hospital: a review of 10 years of experience. Acta Med Okayama. 2011;65(5):287-97. NRD. [pmid: 22037265].
Hiraki, Gobara H, Mimura H, Matsui Y, Toyooka S, Kanazawa S. Percutaneous radiofrequency ablation of clinical stage I non-small cell lung cancer. J Thorac Cardiovasc Surg. 2011;142(1):24-30. USD. [pmid: 21529847].
Hiraki, Gobara H, Iishi T, Sano Y, Iguchi T, Fujiwara H, Tajiri N, Sakurai J, Date H, Mimura H, Kanazawa S. Percutaneous radiofrequency ablation for clinical stage I non-small cell lung cancer: results in 20 nonsurgical candidates. J Thorac Cardiovasc Surg. 2007;134(5):1306-12. NRP. [pmid: 17976467].
Hiraoka, Ishikura S. A Japan clinical oncology group trial for stereotactic body radiation therapy of non-small cell lung cancer. Journal of Thoracic Oncology. 2007;2(7 SUPPL 3):S115-S117. NRD. [pmid: 17603306].
Hiraoka, Nagata Y. Stereotactic body radiation therapy for early-stage non-small-cell lung cancer: the Japanese experience. Int J Clin Oncol. 2004;9(5):352-5. NRD. [pmid: 15549583].
Hiraoka, Matsuo Y, Nagata Y. Stereotactic body radiation therapy (SBRT) for early-stage lung cancer. Cancer Radiother. 2007;11(1–2):32-5. NRD. [pmid: 17158081].
Hirose, Mizutani Y, Ohmori T, Ishida H, Hosaka T, Ando K, Shirai T, Okuda K, Ohnishi T, Horichi N, Kubota H, Adachi M. The combination of cisplatin and vinorelbine with concurrent thoracic radiation therapy for locally advanced stage IIIA or IIIB non-small-cell lung cancer. Cancer Chemother Pharmacol. 2006;58(3):361-7. NRP. [pmid: 16331494].
Hirsh, Soulieres D, Duclos M, Faria S, Del Vecchio P, Ofiara L, Ayoub JP, Charpentier D, Gruber J, Portelance L, Souhami L. Phase II multicenter trial with carboplatin and gemcitabine induction chemotherapy followed by radiotherapy concomitantly with low-dose paclitaxel and gemcitabine for stage IIIA and IIIB non-small cell lung cancer. J Thorac Oncol. 2007;2(10):927-32. NRP. [pmid: 17909355].
Hodge, Tome WA, Jaradat HA, Orton NP, Khuntia D, Traynor A, Weigel T, Mehta MP. Feasibility report of image guided stereotactic body radiotherapy (IG-SBRT) with tomotherapy for early stage medically inoperable lung cancer using extreme hypofractionation. Acta Oncol. 2006;45(7):890-6. NRO. [pmid: 16982555].
Hoekstra, Stroobants SC, Smit EF, Vansteenkiste J, Van Tinteren H, Postmus PE, Golding RP, Biesma B, Schramel FJHM, Van Zandwijk N, Lammertsma AA, Hoekstra OS. Prognostic relevance of response evaluation using [18F]-2- fluoro-2-deoxy-D-glucose positron emission tomography in patients with locally advanced non-small-cell lung cancer. Journal of Clinical Oncology. 2005;23(33):8362-8370. NRP. [pmid: 16293866].
Hof, Herfarth KK, Munter M, Hoess A, Motsch J, Wannenmacher M, Debus JJ. Stereotactic single-dose radiotherapy of stage I non-small-cell lung cancer (NSCLC). Int J Radiat Oncol Biol Phys. 2003;56(2):335-41. USD. [pmid: 12738306].
Hof, Muenter M, Oetzel D, Hoess A, Debus J, Herfarth K. Stereotactic single-dose radiotherapy (radiosurgery) of early stage nonsmall-cell lung cancer (NSCLC). Cancer. 2007;110(1):148-55. NRP. [pmid: 17516437].
Hoffman, Cohen EE, Masters GA, Haraf DJ, Mauer AM, Rudin CM, Krauss SA, Huo D, Vokes EE. Carboplatin plus vinorelbine with concomitant radiation therapy in advanced non-small cell lung cancer: a phase I study. Lung Cancer. 2002;38(1):65-71. NRP. [pmid: 12367795].
Hongwu, Yunzhi Z, Dongmei L, Hang Z, Lingfei L. Place of cryotherapy, argon plasma coagulation? Photodynamic therapy and stents in therapeutic bronchoscopy of lung cancers. Photodiagnosis and Photodynamic Therapy. 2011;8(2):176. NRD.
Hoopes, Tann M, Fletcher JW, Forquer JA, Lin PF, Lo SS, Timmerman RD, McGarry RC. FDG-PET and stereotactic body radiotherapy (SBRT) for stage I non-small-cell lung cancer. Lung Cancer. 2007;56(2):229-34. NRI, USD. [pmid: 17353064].
Hoppe, Laser B, Kowalski AV, Fontenla SC, Pena-Greenberg E, Yorke ED, Lovelock DM, Hunt MA, Rosenzweig KE. Acute skin toxicity following stereotactic body radiation therapy for stage I non-small-cell lung cancer: who’s at risk?. Int J Radiat Oncol Biol Phys. 2008;72(5):1283-6. NRP. [pmid: 19028267].
Hoyer, Roed H, Hansen AT, Ohlhuis L, Petersen J, Nellemann H, Berthelsen AK, Grau C, Engelholm SA, von der Maase H. Prospective study on stereotactic radiotherapy of limited-stage non-small-cell lung cancer. International Journal of Radiation Oncology Biology Physics. 2006;66(4 SUPPL):S128-S135. NRP.
Hsie, Morbidini-Gaffney S, Kohman LJ, Dexter E, Scalzetti EM, Bogart JA. Definitive treatment of poor-risk patients with stage I lung cancer: a single institution experience. J Thorac Oncol. 2009;4(1):69-73. USD. [pmid: 19096309].
Hu, Chang EL, Hassenbusch SJ 3rd, Allen PK, Woo SY, Mahajan A, Komaki R, Liao Z. Nonsmall cell lung cancer presenting with synchronous solitary brain metastasis. Cancer. 2006;106(9):1998-2004. NRP. [pmid: 16572401].
Huang, Liao Z, Cox JD, Guerrero TM, Chang JY, Jeter M, Borghero Y, Wei X, Fossella F, Herbst RS, Blumenschein GR Jr, Moran C, Allen PK, Komaki R. Comparison of outcomes for patients with unresectable, locally advanced non-small-cell lung cancer treated with induction chemotherapy followed by concurrent chemoradiation vs. concurrent chemoradiation alone. Int J Radiat Oncol Biol Phys. 2007;68(3):779-85. NRP. [pmid: 17418967].
Huber, Borgmeier A, Flentje M, Willner J, Schmidt M, Manegold C, Bramlage P, Debus J. Concurrent chemoradiation therapy with docetaxel/cisplatin followed by docetaxel consolidation therapy in inoperable stage IIIA/B non-small-cell lung cancer: results of a phase I study. Clin Lung Cancer. 2010;11(1):45-50. NRP. [pmid: 20085867].
Huber, Flentje M, Schmidt M, Pollinger B, Gosse H, Willner J, Ulm K. Simultaneous chemoradiotherapy compared with radiotherapy alone after induction chemotherapy in inoperable stage IIIA or IIIB non-small-cell lung cancer: study CTRT99/97 by the Bronchial Carcinoma Therapy Group. J Clin Oncol. 2006;24(27):4397-404. NRP. [pmid: 16983107].
Huber, Fischer R, Hautmann H, Pollinger B, Haussinger K, Wendt T. Does additional brachytherapy improve the effect of external irradiation? A prospective, randomized study in central lung tumors. Int J Radiat Oncol Biol Phys. 1997;38(3):533-40. NRD. [pmid: 9231677].
Hughes, Liong J, Miah A, Ahmad S, Leslie M, Harper P, Prendiville J, Shamash J, Subramaniam R, Gaya A, Spicer J, Landau D. A brief report on the safety study of induction chemotherapy followed by synchronous radiotherapy and cetuximab in stage III non-small cell lung cancer (NSCLC): SCRATCH study. J Thorac Oncol. 2008;3(6):648-51. NRP. [pmid: 18520806].
Huisman, Giaccone G, van Groeningen CJ, Sutedja G, Postmus PE, Smit EF. Combination of gemcitabine and cisplatin for advanced non-small cell lung cancer: a phase II study with emphasis on scheduling. Lung Cancer. 2001;33(2–3):267-75. NRP. [pmid: 11551422].
Iaffaioli, Caponigro F, Tortoriello A, Facchini G, Ravo V, Maccauro M, Dimitri P, Crovella F, Muto P. Accelerated split-course (type B) thoracic radiation therapy plus vinorelbine/carboplatin combination chemotherapy in stage III inoperable non-small cell lung cancer. Eur J Cancer. 1996;32A(11):1901-4. NRP. [pmid: 8943672].
Ichinose, Seto T, Sasaki T, Yamanaka T, Okamoto I, Takeda K, Tanaka M, Katakami N, Sawa T, Kudoh S, Saka H, Nishimura Y, Nakagawa K, Fukuoka M. S-1 Plus Cisplatin with Concurrent Radiotherapy for Locally Advanced Non-small Cell Lung Cancer: A Multi-Institutional Phase II Trial (West Japan Thoracic Oncology Group 3706). J Thorac Oncol. 2011;6(12):2069-2075. NRP. [pmid: 22052226].
Ichinose, Yano T, Asoh H, Yokoyama H, Maruyama R, Ushijima C, Uehara T, Kanematsu T, Yohena T, Wada S. UFT plus cisplatin with concurrent radiotherapy for locally advanced non-small-cell lung cancer. Oncology (Williston Park). 1999;13(7 Suppl 3):98-101. NRP. [pmid: 10442374].
Ichinose, Fukuyama Y, Asoh H, Ushijima C, Okamoto T, Ikeda J, Okamoto J, Sakai M. Induction chemoradiotherapy and surgical resection for selected stage IIIB non-small-cell lung cancer. Ann Thorac Surg. 2003;76(6):1810-4. discussion 1815. NRP. [pmid: 14667588].
Ichinose, Nakai Y, Kudoh S, Semba H, Yoshida S, Nukiwa T, Yamamoto H, Yamane Y, Niitani H. Uracil/tegafur plus cisplatin with concurrent radiotherapy for locally advanced non-small-cell lung cancer: a multi-institutional phase II trial. Clin Cancer Res. 2004;10(13):4369-73. NRP. [pmid: 15240524].
Iranzo, Bremnes RM, Almendros P, Gavila J, Blasco A, Sirera R, Camps C. Induction chemotherapy followed by concurrent chemoradiation for patients with non-operable stage III non-small-cell lung cancer. Lung Cancer. 2009;63(1):63-7. NRP. [pmid: 18550204].
Isakovic-Vidovic, Radosevic-Jelic L, Borojevic N. Combined chemoradiotherapy in the treatment of locally advanced non-small cell lung cancer. J BUON. 2002;7(1):47-51. NRP. [pmid: 17577260].
Ishikawa, Nakayama Y, Kitamoto Y, Nonaka T, Kawamura H, Shirai K, Sakurai H, Hayakawa K, Niibe H, Nakano T. Effect of histologic type on recurrence pattern in radiation therapy for medically inoperable patients with stage I non-small-cell lung cancer. Lung. 2006;184(6):347-53. NRI. [pmid: 17086466].
Ishikura, Ohe Y, Nihei K, Kubota K, Kakinuma R, Ohmatsu H, Goto K, Niho S, Nishiwaki Y, Ogino T. A phase II study of hyperfractionated accelerated radiotherapy (HART) after induction cisplatin (CDDP) and vinorelbine (VNR) for stage III non-small-cell lung cancer (NSCLC). Int J Radiat Oncol Biol Phys. 2005;61(4):1117-22. NRP. [pmid: 15752891].
Isokangas, Joensuu H, Halme M, Jekunen A, Mattson K. Paclitaxel (Taxol) and carboplatin followed by concomitant paclitaxel, cisplatin and radiotherapy for inoperable stage III NSCLC. Lung Cancer. 1998;20(2):127-33. NRP. [pmid: 9711531].
Itoh, Fuwa N, Matumoto A, Asano A, Morita K. Continuous infusion low-dose CDDP/5-FU plus radiation in inoperable or recurrent non-small-cell lung cancer: preliminary experience. Am J Clin Oncol. 2002;25(3):230-4. NRP. [pmid: 12040278].
Iwasaki, Ohsugi S, Natsuhara A, Tsubokura T, Harada H, Ueda M, Arimoto T, Hara H, Yamada T, Takesako T, Kohno K, Hosogi S, Nakanishi M, Marunaka Y, Nishimura T. Phase I/II trial of biweekly docetaxel and cisplatin with concurrent thoracic radiation for stage III non-small-cell lung cancer. Cancer Chemother Pharmacol. 2006;58(6):735-41. NRP. [pmid: 16565832].
Iwata, Shibamoto Y, Baba F, Sugie C, Ogino H, Murata R, Yanagi T, Otsuka S, Kosaki K, Murai T, Miyakawa A. Correlation between the serum KL-6 level and the grade of radiation pneumonitis after stereotactic body radiotherapy for stage i lung cancer or small lung metastasis. Radiotherapy and Oncology. 2011;101(2):267-270. NRO. [pmid: 21640420].
Izmirli, Yaman F, Buyukpolat MY, Yoney A, Unsal M. An accelerated radiotherapy scheme using a concomitant boost technique for the treatment of unresectable stage III non-small cell lung cancer. Jpn J Clin Oncol. 2005;35(5):239-44. NRP. [pmid: 15886271].
Jager, Groen HJ, van der Leest A, van Putten JW, Pieterman RM, de Vries EG, Piers DA. L-3-[123I]iodo-alpha-methyl-tyrosine SPECT in non-small cell lung cancer: preliminary observations. J Nucl Med. 2001;42(4):579-85. NRP. [pmid: 11337545].
Jain, Hughes RS, Sandler AB, Dowlati A, Schwartzberg LS, Dobbs T, Schlabach L, Wu J, Muldowney NJ, Choy H. A phase II study of concurrent chemoradiation with weekly docetaxel, carboplatin, and radiation therapy followed by consolidation chemotherapy with docetaxel and carboplatin for locally advanced inoperable non-small cell lung cancer (NSCLC). J Thorac Oncol. 2009;4(6):722-7. NRP. [pmid: 19404213].
Jakse, Kapp KS, Geyer E, Oechs A, Maier A, Gabor S, Juttner FM. IORT and external beam irradiation (EBI) in clinical stage I–II NSCLC patients with severely compromised pulmonary function: an 52-patient single-institutional experience. Strahlenther Onkol. 2007;183(Spec No 2()):24-5. NRI. [pmid: 18167003].
Jatoi, Schild SE, Foster N, Henning GT, Dornfeld KJ, Flynn PJ, Fitch TR, Dakhil SR, Rowland KM, Stella PJ, Soori GS, Adjei AA. A phase II study of cetuximab and radiation in elderly and/or poor performance status patients with locally advanced non-small-cell lung cancer (N0422). Ann Oncol. 2010;21(10):2040-4. NRP. [pmid: 20570832].
Jazieh, Younas A, Safa M, Redmond K, Buncher R, Howington J. Phase I clinical trial of concurrent paclitaxel, carboplatin, and external beam chest irradiation with glutamine in patients with locally advanced non-small cell lung cancer. Cancer Invest. 2007;25(5):294-8. NRP. [pmid: 17661203].
Jenkins, Anderson S, Wronski S, Ashton A. A phase II trial of induction chemotherapy followed by continuous hyperfractionated accelerated radiotherapy in locally advanced non-small-cell lung cancer. Radiother Oncol. 2009;93(3):396-401. NRP. [pmid: 19435642].
Jensen, Munter MW, Bischoff HG, Haselmann R, Haberkorn U, Huber PE, Thomas M, Debus J, Herfarth KK. Combined treatment of nonsmall cell lung cancer NSCLC stage III with intensity-modulated RT radiotherapy and cetuximab: the NEAR trial. Cancer. 2011;117(13):2986-94. NRP. [pmid: 21264838].
Jeong, Jung JH, Han JH, Kim JH, Choi YW, Lee HW, Kang SY, Hwang YH, Ahn MS, Choi JH, Oh YT, Chun M, Kang S, Park KJ, Hwang SC, Sheen SS. Expression of Bcl-2 predicts outcome in locally advanced non-small cell lung cancer patients treated with cisplatin-based concurrent chemoradiotherapy. Lung Cancer. 2010;68(2):288-94. NRP. [pmid: 19560836].
Jeremic, Milicic B. From conventionally fractionated radiation therapy to hyperfractionated radiation therapy alone and with concurrent chemotherapy in patients with early-stage nonsmall cell lung cancer. Cancer. 2008;112(4):876-84. NRI. [pmid: 18172901].
Jeremic, Shibamoto Y. Effect of interfraction interval in hyperfractionated radiotherapy with or without concurrent chemotherapy for stage III nonsmall cell lung cancer. Int J Radiat Oncol Biol Phys. 1996;34(2):303-8. NRP. [pmid: 8567330].
Jeremic, Shibamoto Y. Pre-treatment prognostic factors in patients with stage III non-small cell lung cancer treated with hyperfractionated radiation therapy with or without concurrent chemotherapy. Lung Cancer. 1995;13(1):21-30. NRP. [pmid: 8528637].
Jeremic, Milicic B, Milisavljevic S. Clinical prognostic factors in patients with locally advanced (stage III) nonsmall cell lung cancer treated with hyperfractionated radiation therapy with and without concurrent chemotherapy: single-Institution Experience in 600 Patients. Cancer. 2011;117(13):2995-3003. NRP. [pmid: 21692056].
Jeremic, Milicic B, Milisavljevic S. Concurrent Hyperfractionated Radiation Therapy and Chemotherapy in Locally Advanced (Stage III) non-Small-cell lung Cancer: Single Institution Experience with 600 Patients. Int J Radiat Oncol Biol Phys. 2011. NRP.
Jeremic, Milicic B, Dagovic A, Aleksandrovic J, Milisavljevic S. Interfraction interval in patients with stage III non-small-cell lung cancer treated with hyperfractionated radiation therapy with or without concurrent chemotherapy: final results in 536 patients. Am J Clin Oncol. 2004;27(6):616-25. NRP. [pmid: 15577441].
Jeremic, Milicic B, Dagovic A, Aleksandrovic J, Milisavljevic S. Stage III non-small-cell lung cancer treated with high-dose hyperfractionated radiation therapy and concurrent low-dose daily chemotherapy with or without weekend chemotherapy: retrospective analysis of 301 patients. Am J Clin Oncol. 2004;27(4):350-60. NRP. [pmid: 15289727].
Jeremic, Milicic B, Dagovic A, Acimovic L, Milisavljevic S. Pretreatment prognostic factors in patients with early-stage (I/II) non-small-cell lung cancer treated with hyperfractionated radiation therapy alone. Int J Radiat Oncol Biol Phys. 2006;65(4):1112-9. NRI. [pmid: 16682148].
Jeremic, Milicic B, Acimovic L, Milisavljevic S. Concurrent hyperfractionated radiotherapy and low-dose daily carboplatin and paclitaxel in patients with stage III non-small-cell lung cancer: long-term results of a phase II study. J Clin Oncol. 2005;23(6):1144-51. NRP. [pmid: 15718310].
Jeremic, Zimmermann FB, Nieder C, Molls MM. Radiation therapy alone as an alternative to surgery in patients with early stage non-small-cell lung cancer having cardiovascular (and other) comorbidity. Eur J Cardiothorac Surg. 2004;25(2):297. NRD. [pmid: 14747136].
Jeremic, Shibamoto Y, Milicic B, Dagovic A, Aleksandrovic J, Nikolic N, Igrutinovic I. No thoracic radiation myelitis after spinal cord dose > or = 50.4 Gy using 1.2. Gy b.i.d. fractionation in patients with Stage III non-small cell lung cancer treated with hyperfractionated radiation therapy with and without concurrent chemotherapy. Lung Cancer. 2002;35(3):287-92. NRP. [pmid: 11844603].
Jeremic, Shibamoto Y, Milicic B, Dagovic A, Nikolic N, Aleksandrovic J, Acimovic L, Milisavljevic S. Impact of treatment interruptions due to toxicity on outcome of patients with early stage (I/II) non-small-cell lung cancer (NSCLC) treated with hyperfractionated radiation therapy alone. Lung Cancer. 2003;40(3):317-23. NRI. [pmid: 12781431].
Jeremic, Shibamoto Y, Milicic B, Acimovic L, Milisavljevic S. Absence of thoracic radiation myelitis after hyperfractionated radiation therapy with and without concurrent chemotherapy for Stage III nonsmall-cell lung cancer. Int J Radiat Oncol Biol Phys. 1998;40(2):343-6. NRP. [pmid: 9457819].
Jeremic, Shibamoto Y, Milicic B, Nikolic N, Dagovic A, Milisavljevic S. Concurrent radiochemotherapy for patients with stage III non-small-cell lung cancer (NSCLC): long-term results of a phase II study. Int J Radiat Oncol Biol Phys. 1998;42(5):1091-6. NRP. [pmid: 9869234].
Jeremic, Shibamoto Y, Milicic B, Milisavljevic S, Nikolic N, Dagovic A, Radosavljevic-Asic G. Short-term chemotherapy and palliative radiotherapy for elderly patients with stage IV non-small cell lung cancer: a phase II study. Lung Cancer. 1999;24(1):1-9. NRP. [pmid: 10403688].
Jeremic, Shibamoto Y, Milicic B, Milisavljevic S, Nikolic N, Dagovic A, Aleksandrovic J, Radosavljevic-Asic G. A phase II study of concurrent accelerated hyperfractionated radiotherapy and carboplatin/oral etoposide for elderly patients with stage III non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 1999;44(2):343-8. NRP. [pmid: 10760429].
Jeremic, Shibamoto Y, Acimovic L, Djuric L. Randomized trial of hyperfractionated radiation therapy with or without concurrent chemotherapy for stage III non-small-cell lung cancer. J Clin Oncol. 1995;13(2):452-8. NRP. [pmid: 7844608].
Jeremic, Shibamoto Y, Acimovic L, Milisavljevic S. Hyperfractionated radiation therapy with or without concurrent low-dose daily carboplatin/etoposide for stage III non-small-cell lung cancer: a randomized study. J Clin Oncol. 1996;14(4):1065-70. NRP. [pmid: 8648358].
Jeremic, Shibamoto Y, Acimovic L, Milisavljevic S. Hyperfractionated radiotherapy alone for clinical stage I nonsmall cell lung cancer. Int J Radiat Oncol Biol Phys. 1997;38(3):521-5. NRI. [pmid: 9231675].
Jeremic, Shibamoto Y, Acimovic L, Milicic B, Milisavljevic S, Nikolic N, Dagovic A, Aleksandrovic J, Radosavljevic-Asic G. Hyperfractionated radiation therapy and concurrent low-dose, daily carboplatin/etoposide with or without weekend carboplatin/etoposide chemotherapy in stage III non-small-cell lung cancer: a randomized trial. Int J Radiat Oncol Biol Phys. 2001;50(1):19-25. NRP. [pmid: 11316542].
Jiang, Yang K, Komaki R, Wei X, Tucker SL, Zhuang Y, Martel MK, Vedam S, Balter P, Zhu G, Gomez D, Lu C, Mohan R, Cox JD, Liao Z. Long-Term Clinical Outcome of Intensity-Modulated Radiotherapy for Inoperable Non-Small-Cell Lung Cancer: The MD Anderson Experience. Int J Radiat Oncol Biol Phys. 2011. NRP.
Jiang, Yan W, Ming J, Yu Y. Docetaxel weekly regimen in conjunction with RF hyperthermia for pretreated locally advanced non-small cell lung cancer: a preliminary study. BMC Cancer. 2007;7:189. NRP. [pmid: 17919338].
Jin, Ji HS, Song HY, Ohm JY, Jae ML, Dae HL, Kim SW. Palliative treatment of inoperable malignant tracheobronchial obstruction: Temporary stenting combined with radiation therapy and/or chemotherapy. American Journal of Roentgenology. 2009;193(1):W38-W42. USD. [pmid: 19542381].
Jin, Tucker SL, Liu HH, Wei X, Yom SS, Wang S, Komaki R, Chen Y, Martel MK, Mohan R, Cox JD, Liao Z. Dose-volume thresholds and smoking status for the risk of treatment-related pneumonitis in inoperable non-small cell lung cancer treated with definitive radiotherapy. Radiother Oncol. 2009;91(3):427-32. NRO. [pmid: 18937989].
Jin, Han YM, Lee YS, Lee YC. Radiofrequency ablation using a monopolar wet electrode for the treatment of inoperable non-small cell lung cancer: a preliminary report. Korean J Radiol. 2008;9(2):140-7. NRO. [pmid: 18385561].
Jiwnani, Karimundackal G, Pramesh CS. Stereotactic radiotherapy versus sublobar lung resection in medically unfit patients with early-stage non-small-cell lung cancer. J Clin Oncol. 2010;28(29):e569-70. author reply e571–2. NRD. [pmid: 20660829].
Johnstone, Byhardt RW, Ettinger D, Scott CB. Phase III study comparing chemotherapy and radiotherapy with preoperative chemotherapy and surgical resection in patients with non-small-cell lung cancer with spread to mediastinal lymph nodes (N2); final report of RTOG 89-01. Radiation Therapy Oncology Group. Int J Radiat Oncol Biol Phys. 2002;54(2):365-9. NRP. [pmid: 12243809].
Kadono, Homma T, Kamahara K, Nakayama M, Satoh H, Sekizawa K, Miyamoto T. Effect of heavy-ion radiotherapy on pulmonary function in stage I non-small cell lung cancer patients. Chest. 2002;122(6):1925-32. NRI. [pmid: 12475828].
Kaira, Sunaga N, Yanagitani N, Kawata T, Utsugi M, Shimizu K, Ebara T, Kawamura H, Nonaka T, Ishikawa H, Sakurai H, Suga T, Hara K, Hisada T, Ishizuka T, Nakano T, Mori M. Phase I study of oral S-1 plus Cisplatin with concurrent radiotherapy for locally advanced non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2009;75(1):109-14. NRP. [pmid: 18929446].
Kalemkerian, Belzer K, Wozniak AJ, Gaspar LE, Valdivieso M, Kraut MJ. Phase I trial of concurrent thoracic radiation and continuous infusion cisplatin and etoposide in stage III non-small cell lung cancer. Lung Cancer. 1999;25(3):175-82. NRP. [pmid: 10512128].
Kang, Ahn YC, Lim DH, Park K, Park JO, Shim YM, Kim J, Kim K. Preoperative concurrent radiochemotherapy and surgery for stage IIIA non-small cell lung cancer. J Korean Med Sci. 2006;21(2):229-35. NRP. [pmid: 16614506].
Kaplan, Altynbas M, Eroglu C, Karahacioglu E, Er O, Ozkan M, Bilgin M, Canoz O, Gulmez I, Gulec M. Preliminary results of a phase II study of weekly paclitaxel (PTX) and carboplatin (CBDCA) administered concurrently with thoracic radiation therapy (TRT) followed by consolidation chemotherapy with PTX/CBDCA for stage III unresectable non-small-cell lung cancer (NSCLC). Am J Clin Oncol. 2004;27(6):603-10. NRP. [pmid: 15577439].
Kappers, Belderbos JS, Burgers JA, van Zandwijk N, Groen HJ, Klomp HM. Non-small cell lung carcinoma of the superior sulcus: favourable outcomes of combined modality treatment in carefully selected patients. Lung Cancer. 2008;59(3):385-90. NRP. [pmid: 17913281].
Kappers, van Sandick JW, Burgers JA, Belderbos JS, Wouters MW, van Zandwijk N, Klomp HM. Results of combined modality treatment in patients with non-small-cell lung cancer of the superior sulcus and the rationale for surgical resection. Eur J Cardiothorac Surg. 2009;36(4):741-6. NRP. [pmid: 19699647].
Kappers, van Sandick JW, Burgers SA, Belderbos JS, van Zandwijk N, Klomp HM. Surgery after induction chemotherapy in stage IIIA-N2 non-small cell lung cancer: why pneumonectomy should be avoided. Lung Cancer. 2010;68(2):222-7. NRP. [pmid: 19664843].
Karasawa, Okano N, Machitori Y, Chang TC, Kuga G, Mitsui N, Hanyu N, Kunishima N. 3-D noncoplanar conformal radiotherapy for the treatment of stage I NSCLC - Its usefulness for central tumors. Radiotherapy and Oncology. 2011;99:S340-S341. NRD.
Katakami, Okazaki M, Nishiuchi S, Fukuda H, Horikawa T, Nishiyama H, Inui H, Bando K. Induction chemoradiotherapy for advanced stage III non-small cell lung cancer: long-term follow-up in 42 patients. Lung Cancer. 1998;22(2):127-37. NRP. [pmid: 10022220].
Katayama, Ueoka H, Kiura K, Tabata M, Kozuki T, Tanimoto M, Fujiwara T, Tanaka N, Date H, Aoe M, Shimizu N, Takemoto M, Hiraki Y. Preoperative concurrent chemoradiotherapy with cisplatin and docetaxel in patients with locally advanced non-small-cell lung cancer. Br J Cancer. 2004;90(5):979-84. NRP. [pmid: 14997193].
Kato, Nambu A, Onishi H, Saito A, Kuriyama K, Komiyama T, Marino K, Araki T. Computed tomography appearances of local recurrence after stereotactic body radiation therapy for stage I non-small-cell lung carcinoma. Jpn J Radiol. 2010;28(4):259-65. NRO. [pmid: 20512542].
Kawaguchi, Takada M, Ando M, Okishio K, Atagi S, Fujita Y, Tomizawa Y, Hayashihara K, Okano Y, Takahashi F, Saito R, Matsumura A, Tamura A. A multi-institutional phase II trial of consolidation S-1 after concurrent chemoradiotherapy with cisplatin and vinorelbine for locally advanced non-small cell lung cancer. European Journal of Cancer. 2011. NRP.
Kaya, Buyukberber S, Benekli M, Coskun U, Sevinc A, Akmansu M, Yildiz R, Ozturk B, Yaman E, Kalender ME, Orhan O, Yamac D, Uner A. Concomitant chemoradiotherapy with cisplatin and docetaxel followed by surgery and consolidation chemotherapy in patients with unresectable locally advanced non-small cell lung cancer. Med Oncol. 2010;27(1):152-7. NRP. [pmid: 19242825].
Ke, Fu G, Bian Y, Jiang D, Yang J. Concurrent gemcitabine and cisplatin combined with 3D conformal radiotherapy for stage III non-small cell lung cancer. Chinese-German Journal of Clinical Oncology. 2009;8(3):156-159. NRP.
Keene, Harman EM, Knauf DG, McCarley D, Zlotecki RA. Five-year results of a phase II trial of hyperfractionated radiotherapy and concurrent daily cisplatin chemotherapy for stage III non-small-cell lung cancer. Am J Clin Oncol. 2005;28(3):217-22. NRP. [pmid: 15923791].
Kelly, Chansky K, Gaspar LE, Albain KS, Jett J, Ung YC, Lau DH, Crowley JJ, Gandara DR. Phase III trial of maintenance gefitinib or placebo after concurrent chemoradiotherapy and docetaxel consolidation in inoperable stage III non-small-cell lung cancer: SWOG S0023. J Clin Oncol. 2008;26(15):2450-6. NRP. [pmid: 18378568].
Kelly, Hazuka M, Pan Z, Murphy J, Caskey J, Leonard C, Bunn PA Jr. A phase I study of daily carboplatin and simultaneous accelerated, hyperfractionated chest irradiation in patients with regionally inoperable non-small cell lung cancer. Int J Radiat Oncol Biol Phys. 1998;40(3):559-67. NRP. [pmid: 9486605].
Kelly, Balter PA, Rebueno N, Sharp HJ, Liao Z, Komaki R, Chang JY. Stereotactic body radiation therapy for patients with lung cancer previously treated with thoracic radiation. Int J Radiat Oncol Biol Phys. 2010;78(5):1387-93. NRP. [pmid: 20381271].
Kepka, Tyc-Szczepaniak D, Bujko K. Dose-per-fraction escalation of accelerated hypofractionated three-dimensional conformal radiotherapy in locally advanced non-small cell lung cancer. J Thorac Oncol. 2009;4(7):853-61. NRP. [pmid: 19487965].
Kepka, Bujko K, Zolciak-Siwinska A. Risk of isolated nodal failure for non-small cell lung cancer (NSCLC) treated with the elective nodal irradiation (ENI) using 3D-conformal radiotherapy (3D-CRT) techniques--a retrospective analysis. Acta Oncol. 2008;47(1):95-103. NRP. [pmid: 17851862].
Kerner, Van Dullemen LFA, Wiegman EM, Van Der AHD, Widder Leest J, Ubbels JF, Hiltermann TJN, Groen HJM. Gemcitabine and cisplatin followed by concurrent gemcitabine and radiotherapy or sequential radiotherapy alone in unresectable stage III non-small cell lung cancer (NSCLC). European Journal of Cancer. 2011;47:S600. NRD.
Kim, Han HJ, Park SJ, Min KH, Lee MH, Chung CR, Kim MH, Jin GY, Lee YC. Comparison between surgery and radiofrequency ablation for stage I non-small cell lung cancer. Eur J Radiol. 2011. USD.
Kim, Yang SH, Lee SH, Park YS, Im YH, Kang WK, Ha SH, Park CI, Heo DS, Bang YJ, Kim NK. A phase III randomized trial of combined chemoradiotherapy versus radiotherapy alone in locally advanced non-small-cell lung cancer. Am J Clin Oncol. 2002;25(3):238-43. NRP. [pmid: 12040280].
Kim, Yoon SM, Choi EK, Yi BY, Kim JH, Ahn SD, Lee SW, Shin SS, Lee JS, Suh C, Kim SW, Kim DS, Kim WS, Park HJ, Park CI. Phase II study of radiotherapy with three-dimensional conformal boost concurrent with paclitaxel and cisplatin for Stage IIIB non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2005;62(1):76-81. NRP. [pmid: 15850905].
Kim, Ahn YC, Park HC, Lim do H, Nam H. Results and prognostic factors of hypofractionated stereotactic radiation therapy for primary or metastatic lung cancer. J Thorac Oncol. 2010;5(4):526-32. USD. [pmid: 20104193].
Kim, Ahn YC, Lim do H, Nam HR. High-dose thoracic radiation therapy at 3.0 Gy/fraction in inoperable stage I/II non-small cell lung cancer. Jpn J Clin Oncol. 2008;38(2):92-8. NRI. [pmid: 18267986].
Kim, Ahn YC, Lim do H, Han J, Park K, Park JO, Kim K, Kim J, Shim YM. Analyses on prognostic factors following tri-modality therapy for stage IIIa non-small cell lung cancer. Lung Cancer. 2007;55(3):329-36. NRP. [pmid: 17157950].
Kim, Kim YJ, Seo MD, Yi HG, Lee SH, Lee SM, Kim DW, Yang SC, Lee CT, Lee JS, Kim YW, Heo DS. Patterns of palliative procedures and clinical outcomes in patients with advanced non-small cell lung cancer. Lung Cancer. 2009;65(2):242-6. NRP. [pmid: 19147252].
Kim, Shyr Y, Shaktour B, Akerley W, Johnson DH, Choy H. Long term follow up and analysis of long term survivors in patients treated with paclitaxel-based concurrent chemo/radiation therapy for locally advanced non-small cell lung cancer. Lung Cancer. 2005;50(2):235-45. NRP. [pmid: 16043262].
Kim, Shyr Y, Chen H, Akerley W, Johnson DH, Choy H. Response to combined modality therapy correlates with survival in locally advanced non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2005;63(4):1029-36. NRP. [pmid: 15913910].
King, Acker JC, Kussin PS, Marks LB, Weeks KJ, Leopold KA. High-dose, hyperfractionated, accelerated radiotherapy using a concurrent boost for the treatment of nonsmall cell lung cancer: unusual toxicity and promising early results. Int J Radiat Oncol Biol Phys. 1996;36(3):593-9. NRI. [pmid: 8948343].
Kirkbride, Gelmon K, Eisenhauer E. Paclitaxel and concurrent radiotherapy in locally advanced non-small cell lung cancer: the Canadian experience. Semin Radiat Oncol. 1999;9(2 Suppl 1):102-7. NRP. [pmid: 10210548].
Kirkbride, Gelmon K, Eisenhauer E, Fisher B, Dulude H. A phase I/II study of paclitaxel (TAXOL) and concurrent radiotherapy in advanced nonsmall cell lung cancer. Int J Radiat Oncol Biol Phys. 1997;39(5):1107-11. NRP. [pmid: 9392551].
Kishida, Hirose T, Shirai T, Sugiyama T, Kusumoto S, Yamaoka T, Okuda K, Adachi M, Nakamura A. Myelosuppression induced by concurrent hemoradiotherapy as a prognostic factor for patients with locally advanced non-small cell lung cancer. Oncology Letters. 2011;2(5):949-955. NRP. [pmid: 22866156].
Kiura, Ueoka H, Segawa Y, Tabata M, Kamei H, Takigawa N, Hiraki S, Watanabe Y, Bessho A, Eguchi K, Okimoto N, Harita S, Takemoto M, Hiraki Y, Harada M, Tanimoto M. Phase I/II study of docetaxel and cisplatin with concurrent thoracic radiation therapy for locally advanced non-small-cell lung cancer. Br J Cancer. 2003;89(5):795-802. NRP. [pmid: 12942107].
Kobayashi, Matsui K, Hirashima T, Nitta T, Sasada S, Tada T, Minakuchi K, Furukawa M, Ogata Y, Kawase I. Phase I study of weekly cisplatin, vinorelbine, and concurrent thoracic radiation therapy in patients with locally advanced non-small-cell lung cancer. Int J Clin Oncol. 2006;11(4):314-9. NRP. [pmid: 16937306].
Kobayashi, Uno T, Isobe K, Ueno N, Watanabe M, Harada R, Takiguchi Y, Tatsumi K, Ito H. Radiation pneumonitis following twice-daily radiotherapy with concurrent carboplatin and paclitaxel in patients with stage III non-small-cell lung cancer. Jpn J Clin Oncol. 2010;40(5):464-9. NRP. [pmid: 20085905].
Koc, Onuk MD, Koruk M, Memik F. Therapeutic effect of oral recombinant human granulocyte macrophage-colony stimulating factor in radiotherapy-induced esophagitis. Hepatogastroenterology. 2003;50(53):1297-300. NRP. [pmid: 14571722].
Kocak, Ozkan A, Mayadagli A, Parlak C, Bilici A, Seker M, Oven BB, Gumus Ustaalioglu M, Eren M, Karabulut SG, Oruc F. Induction chemotherapy and chemoradiation therapy for inoperable locally advanced non-small-cell lung cancer: a single-institution review of two different regimens. Clin Lung Cancer. 2009;10(2):124-9. NRP. [pmid: 19362956].
Koeppler, Heymanns J, Thomalla J, Kleboth K, Mergenthaler U, Weide R. Treatment of advanced non small cell lung cancer in routine care: a retrospective analysis of 212 consecutive patients treated in a community based oncology group practice. Clin Med Oncol. 2009;3:63-70. NRP. [pmid: 20689611].
Komaki, Scott CB, Sause WT, Johnson DH, Taylor SGt, Lee JS, Emami B, Byhardt RW, Curran WJ Jr, Dar AR, Cox JD. Induction cisplatin/vinblastine and irradiation vs. irradiation in unresectable squamous cell lung cancer: failure patterns by cell type in RTOG 88-08/ECOG 4588. Radiation Therapy Oncology Group Eastern Cooperative Oncology Group. Int J Radiat Oncol Biol Phys. 1997;39(3):537-44. NRP. [pmid: 9336129].
Komaki, Scott C, Ettinger D, Lee JS, Fossella FV, Curran W, Evans RF, Rubin P, Byhardt RW. Randomized study of chemotherapy/radiation therapy combinations for favorable patients with locally advanced inoperable nonsmall cell lung cancer: Radiation Therapy Oncology Group (RTOG) 92-04. Int J Radiat Oncol Biol Phys. 1997;38(1):149-55. NRP. [pmid: 9212017].
Komaki, Scott C, Lee JS, Urtasun RC, Byhardt RW, Emami B, Andras EJ, Asbell SO, Rotman M, Cox JD. Impact of adding concurrent chemotherapy to hyperfractionated radiotherapy for locally advanced non-small cell lung cancer (NSCLC): comparison of RTOG 83-11 and RTOG 91-06. Am J Clin Oncol. 1997;20(5):435-40. NRI. [pmid: 9345325].
Komaki, Roth JA, Walsh GL, Putnam JB, Vaporciyan A, Lee JS, Fossella FV, Chasen M, Delclos ME, Cox JD. Outcome predictors for 143 patients with superior sulcus tumors treated by multidisciplinary approach at the University of Texas M. D. Anderson Cancer Center. Int J Radiat Oncol Biol Phys. 2000;48(2):347-54. NRP. [pmid: 10974447].
Komaki, Lee JS, Kaplan B, Allen P, Kelly JF, Liao Z, Stevens CW, Fossella FV, Zinner R, Papadimitrakopoulou V, Khuri F, Glisson B, Pisters K, Kurie J, Herbst R, Milas L, Ro J, Thames HD, Hong WK, Cox JD. Randomized phase III study of chemoradiation with or without amifostine for patients with favorable performance status inoperable stage II–III non-small cell lung cancer: preliminary results. Semin Radiat Oncol. 2002;12(1 Suppl 1):46-9. NRP. [pmid: 11917284].
Komaki, Lee JS, Milas L, Lee HK, Fossella FV, Herbst RS, Allen PK, Liao Z, Stevens CW, Lu C, Zinner RG, Papadimitrakopoulou VA, Kies MS, Blumenschein GR Jr, Pisters KM, Glisson BS, Kurie J, Kaplan B, Garza VP, Mooring D, Tucker SL, Cox JD. Effects of amifostine on acute toxicity from concurrent chemotherapy and radiotherapy for inoperable non-small-cell lung cancer: report of a randomized comparative trial. Int J Radiat Oncol Biol Phys. 2004;58(5):1369-77. NRP. [pmid: 15050312].
Komaki, Chang JY, Wu X, Allen PK, Milas L, Liao Z, Fossella FV, Travis E, Spitz MR. Mutagen sensitivity may predict lung protection by amifostine for patients with locally advanced non-small cell lung cancer treated by chemoradiotherapy. Semin Oncol. 2005;32(2 Suppl 3):S92-8. NRP. [pmid: 16015542].
Komaki, Seiferheld W, Ettinger D, Lee JS, Movsas B, Sause W. Randomized phase II chemotherapy and radiotherapy trial for patients with locally advanced inoperable non-small-cell lung cancer: long-term follow-up of RTOG 92-04. Int J Radiat Oncol Biol Phys. 2002;53(3):548-57. NRP. [pmid: 12062596].
Komaki, Wei X, Allen PK, Amos R, Mohan R, Chang JY, Liao Z, Dong L, Cox JD. Protons compared to X-IMRT compared to 3D in locally advanced NSCLC. Radiotherapy and Oncology. 2011;99:S89-S90. NRD.
Kong, Hayman JA, Griffith KA, Kalemkerian GP, Arenberg D, Lyons S, Turrisi A, Lichter A, Fraass B, Eisbruch A, Lawrence TS, Ten Haken RK. Final toxicity results of a radiation-dose escalation study in patients with non-small-cell lung cancer (NSCLC): predictors for radiation pneumonitis and fibrosis. Int J Radiat Oncol Biol Phys. 2006;65(4):1075-86. NRO. [pmid: 16647222].
Kong, Ten RK, Schipper Haken MJ, Sullivan MA, Chen M, Lopez C, Kalemkerian GP, Hayman JA. High-dose radiation improved local tumor control and overall survival in patients with inoperable/unresectable non-small-cell lung cancer: long-term results of a radiation dose escalation study. Int J Radiat Oncol Biol Phys. 2005;63(2):324-33. NRP. [pmid: 16168827].
Koshy, Goloubeva O, Suntharalingam M. Impact of neoadjuvant radiation on survival in stage III non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2011;79(5):1388-94. NRP. [pmid: 20605359].
Kosmidis, Fountzilas G, Baka S, Samantas E, Dimopoulos AM, Gogas H, Skarlos D, Papacostas P, Boukovinas J, Bakogiannis C, Pantelakos P, Athanasiou H, Misailidou D, Tsekeris P, Pavlidis N. Combination chemotherapy with paclitaxel and gemcitabine followed by concurrent chemoradiotherapy in non-operable localized non-small cell lung cancer. A hellenic cooperative oncology group (HeCOG) phase II study. Anticancer Res. 2007;27(6C):4391-5. NRP. [pmid: 18214050].
Koto, Takai Y, Ogawa Y, Matsushita H, Takeda K, Takahashi C, Britton KR, Jingu K, Takai K, Mitsuya M, Nemoto K, Yamada S. A phase II study on stereotactic body radiotherapy for stage I non-small cell lung cancer. Radiother Oncol. 2007;85(3):429-34. USD. [pmid: 18022720].
Koukourakis, Kourousis C, Kamilaki M, Koukouraki S, Giatromanolaki A, Kakolyris S, Kotsakis A, Androulakis N, Bahlitzanakis N, Georgoulias V. Weekly docetaxel and concomitant boost radiotherapy for non-small cell lung cancer. A phase I/II dose escalation trial. Eur J Cancer. 1998;34(6):838-44. NRP. [pmid: 9797695].
Koukourakis, Patlakas G, Froudarakis ME, Kyrgias G, Skarlatos J, Abatzoglou I, Bougioukas G, Bouros D. Hypofractionated accelerated radiochemotherapy with cytoprotection (Chemo-HypoARC) for inoperable non-small cell lung carcinoma. Anticancer Res. 2007;27(5B):3625-31. NRP. [pmid: 17972527].
Koukourakis, Skarlatos J, Kosma L, Giatromanolaki A, Yannakakis D. Radiotherapy alone for non-small cell lung carcinoma. Five-year disease-free survival and patterns of failure. Acta Oncol. 1995;34(4):525-30. NRI. [pmid: 7605662].
Koukourakis, Bahlitzanakis N, Froudarakis M, Giatromanolaki A, Georgoulias V, Koumiotaki S, Christodoulou M, Kyrias G, Skarlatos J, Kostantelos J, Beroukas K. Concurrent conventionally factionated radiotherapy and weekly docetaxel in the treatment of stage IIIb non-small-cell lung carcinoma. Br J Cancer. 1999;80(11):1792-6. NRP. [pmid: 10468298].
Koukourakis, Tsoutsou PG, Abatzoglou I. Computed tomography assessment of lung density in patients with lung cancer treated with accelerated hypofractionated radio-chemotherapy supported with amifostine. Am J Clin Oncol. 2009;32(3):258-61. NRP. [pmid: 19349852].
Koukourakis, Koukouraki S, Giatromanolaki A, Archimandritis SC, Skarlatos J, Beroukas K, Bizakis JG, Retalis G, Karkavitsas N, Helidonis ES. Liposomal doxorubicin and conventionally fractionated radiotherapy in the treatment of locally advanced non-small-cell lung cancer and head and neck cancer. J Clin Oncol. 1999;17(11):3512-21. NRP. [pmid: 10550149].
Koutaissoff, Wellmann D, Coucke P, Ozsahin M, Pampallona S, Mirimanoff RO. Hyperfractionated accelerated radiotherapy (HART) for inoperable, nonmetastatic non-small cell lung carcinoma of the lung (NSCLC): results of a phase II study for patients ineligible for combination radiochemotherapy. Int J Radiat Oncol Biol Phys. 1999;45(5):1151-6. NRI. [pmid: 10613307].
Kozak, Murphy JD, Schipper ML, Donington JS, Zhou L, Whyte RI, Shrager JB, Hoang CD, Bazan J, Maxim PG, Graves EE, Diehn M, Hara WY, Quon A, Le QT, Wakelee HA, Loo BW Jr. Tumor volume as a potential imaging-based risk-stratification factor in trimodality therapy for locally advanced non-small cell lung cancer. J Thorac Oncol. 2011;6(5):920-6. NRP. [pmid: 21774104].
Kramer, Wanders SL, Noordijk EM, Vonk EJ, van Houwelingen HC, van den Hout WB, Geskus RB, Scholten M, Leer JW. Results of the Dutch National study of the palliative effect of irradiation using two different treatment schemes for non-small-cell lung cancer. J Clin Oncol. 2005;23(13):2962-70. NRP. [pmid: 15860852].
Krol, Aussems P, Noordijk EM, Hermans J, Leer JW. Local irradiation alone for peripheral stage I lung cancer: could we omit the elective regional nodal irradiation?. Int J Radiat Oncol Biol Phys. 1996;34(2):297-302. NRI. [pmid: 8567329].
Krzakowski, Provencio M, Utracka-Hutka B, Villa E, Codes M, Kuten A, Henke M, Lopez M, Bell D, Biti G, Merimsky O, Beorchia A, Riggi M, Caux NR, Pouget JC, Dubray B, David P. Oral vinorelbine and cisplatin as induction chemotherapy and concomitant chemo-radiotherapy in stage III non-small cell lung cancer: final results of an international phase II trial. J Thorac Oncol. 2008;3(9):994-1002. NRP. [pmid: 18758302].
Kubota, Tamura T, Fukuoka M, Furuse K, Ikegami H, Ariyoshi Y, Kurita Y, Saijo N. Phase II study of concurrent chemotherapy and radiotherapy for unresectable stage III non-small-cell lung cancer: long-term follow-up results. Japan Clinical Oncology Group Protocol 8902. Ann Oncol. 2000;11(4):445-50. NRP. [pmid: 10847464].
Kumar, Herndon J 2nd, Langer M, Kohman LJ, Elias AD, Kass FC, Eaton WL, Seagren SL, Green MR, Sugarbaker DJ. Patterns of disease failure after trimodality therapy of nonsmall cell lung carcinoma pathologic stage IIIA (N2). Analysis of Cancer and Leukemia Group B Protocol 8935. Cancer. 1996;77(11):2393-9. NRP. [pmid: 8635112].
Kunitoh, Watanabe K, Nagatomo A, Okamoto H, Kimbara K. Concurrent daily carboplatin and accelerated hyperfractionated thoracic radiotherapy in locally advanced nonsmall cell lung cancer. Int J Radiat Oncol Biol Phys. 1997;37(1):103-9. NRP. [pmid: 9054883].
Kupelian, Komaki R, Allen P. Prognostic factors in the treatment of node-negative nonsmall cell lung carcinoma with radiotherapy alone. Int J Radiat Oncol Biol Phys. 1996;36(3):607-13. NRI. [pmid: 8948345].
Kusumoto, Hirose T, Fukayama M, Kataoka D, Hamada K, Sugiyama T, Shirai T, Yamaoka T, Okuda K, Ohnishi T, Ohmori T, Kadokura M, Adachi M. Induction chemoradiotherapy followed by surgery for locally advanced non-small cell lung cancer. Oncol Rep. 2009;22(5):1157-62. NRP. [pmid: 19787234].
Kuten, Anacak Y, Abdah-Bortnyak R, Chetver L, Zen I, Deen Al, Daoud K, Nijem R, Billan S, Best L. Neoadjuvant radiotherapy concurrent with weekly paclitaxel and carboplatin and followed by surgery in locally advanced non-small-cell lung cancer. Am J Clin Oncol. 2003;26(2):184-7. NRP. [pmid: 12714893].
Kwak, Kim WC, Kim HJ. Treatment results of cyberknife radiosurgery for patients with primary or recurrent non-small cell lung cancer. Respirology. 2011;16:163-164. NRD.
Kwon, Kim SK, Chung WK, Cho MJ, Kim JS, Moon SR, Park WY, Ahn SJ, Oh YK, Yun HG, Na BS. Effect of pentoxifylline on radiation response of non-small cell lung cancer: a phase III randomized multicenter trial. Radiother Oncol. 2000;56(2):175-9. NRP. [pmid: 10927136].
Kyasa, Jazieh AR. Characteristics and outcomes of patients with unresected early-stage non-small cell lung cancer. South Med J. 2002;95(10):1149-52. NRI. [pmid: 12425499].
Lafitte, Ribet ME, Prevost BM, Gosselin BH, Copin MC, Brichet AH. Postresection irradiation for T2 N0 M0 non-small cell carcinoma: a prospective, randomized study. Ann Thorac Surg. 1996;62(3):830-4. NRI. [pmid: 8784014].
Lagerwaard, Haasbeek CJ, Smit EF, Slotman BJ, Senan S. Outcomes of risk-adapted fractionated stereotactic radiotherapy for stage I non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2008;70(3):685-92. USD. [pmid: 18164849].
Lagerwaard, Senan S, van Meerbeeck JP, Graveland WJ. Has 3-D conformal radiotherapy (3D CRT) improved the local tumour control for stage I non-small cell lung cancer?. Radiother Oncol. 2002;63(2):151-7. NRP. [pmid: 12063004].
Lam, Berman S, Thurer R, Ashiku S, DeCamp M, Goldstein M, Schumer S, Halmos B, Karp D, Coute D, Bergman M, Boyd-Sirard C, Ou SH, Muzikansky A, Woodard C, Huberman M. Phase II trial of sequential chemotherapy followed by chemoradiation, surgery, and postoperative chemotherapy for the treatment of stage IIIA/IIIB non-small-cell lung cancer. Clin Lung Cancer. 2006;8(2):122-9. NRP. [pmid: 17026813].
Lan, Jiang Y. The therapeutic effects of the radiotherapy plus TCM treatment observed in senile non-parvicellular lung cancer patients at the late stage. J Tradit Chin Med. 2003;23(1):32-4. NRP. [pmid: 12747193].
Langendijk, Thunnissen FB, Lamers RJ, de Jong JM, ten Velde GP, Wouters EF. The prognostic significance of accumulation of p53 protein in stage III non-small cell lung cancer treated by radiotherapy. Radiother Oncol. 1995;36(3):218-24. NRP. [pmid: 8532909].
Langendijk, ten Velde GP, Aaronson NK, de Jong JM, Muller MJ, Wouters EF. Quality of life after palliative radiotherapy in non-small cell lung cancer: a prospective study. Int J Radiat Oncol Biol Phys. 2000;47(1):149-55. NRI. [pmid: 10758317].
Langendijk, de Jong J, Wanders R, Lambin P, Slotman B. The importance of pre-treatment haemoglobin level in inoperable non-small cell lung carcinoma treated with radical radiotherapy. Radiother Oncol. 2003;67(3):321-5. NRI. [pmid: 12865181].
Langendijk, Tjwa MK, de Jong JM, ten Velde GP, Wouters EF. Massive haemoptysis after radiotherapy in inoperable non-small cell lung carcinoma: is endobronchial brachytherapy really a risk factor?. Radiother Oncol. 1998;49(2):175-83. NRP. [pmid: 10052884].
Langendijk, Aaronson NK, ten Velde GP, de Jong JM, Muller MJ, Wouters EF. Pretreatment quality of life of inoperable non-small cell lung cancer patients referred for primary radiotherapy. Acta Oncol. 2000;39(8):949-58. NRI. [pmid: 11207002].
Langendijk, Aaronson NK, de Jong JM, ten Velde GP, Muller MJ, Wouters M. The prognostic impact of quality of life assessed with the EORTC QLQ-C30 in inoperable non-small cell lung carcinoma treated with radiotherapy. Radiother Oncol. 2000;55(1):19-25. NRI. [pmid: 10788684].
Langendijk, Aaronson NK, de Jong JM, ten Velde GP, Muller MJ, Slotman BJ, Wouters EF. Quality of life after curative radiotherapy in Stage I non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2002;53(4):847-53. NRI. [pmid: 12095549].
Langer, Movsas B, Hudes R, Schol J, Keenan E, Kilpatrick D, Yeung C, Curran W. Induction paclitaxel and carboplatin followed by concurrent chemoradiotherapy in patients with unresectable, locally advanced non-small cell lung carcinoma: report of Fox Chase Cancer Center study 94-001. Semin Oncol. 1997;24(4 Suppl 12):S12-89-S12-95. NRP.
Langer, Somer R, Litwin S, Feigenberg S, Movsas B, Maiale C, Sherman E, Millenson M, Nicoloau N, Huang C, Treat J. Phase I study of radical thoracic radiation, weekly irinotecan, and cisplatin in locally advanced non-small cell lung carcinoma. J Thorac Oncol. 2007;2(3):203-9. NRP. [pmid: 17410043].
Langer, Curran WJ, Keller SM, Catalano RB, Litwin S, Blankstein KB, Haas N, Campli SN, Comis RL. Long-term survival results for patients with locally advanced, initially unresectable non-small cell lung cancer treated with aggressive concurrent chemoradiation. Cancer J Sci Am. 1996;2(2):99-105. NRP. [pmid: 9166507].
Langer. Concurrent chemoradiation using paclitaxel and carboplatin in locally advanced non-small cell lung cancer. Semin Radiat Oncol. 1999;9(2 Suppl 1):108-16. NRP. [pmid: 10210549].
Langer. The emerging role of gemcitabine in combination with radiation in locally advanced, unresectable non-small-cell lung cancer. Clin Lung Cancer. 2003;4(Suppl 2()):S45-9. NRD. [pmid: 14720336].
Lanni Jr, Grills IS, Kestin LL, Robertson JM. Stereotactic radiotherapy reduces treatment cost while improving overall survival and local control over standard fractionated radiation therapy for medically inoperable non-small-cell lung cancer. Am J Clin Oncol. 2011;34(5):494-8. USD. [pmid: 20805737].
Lanuti, Sharma A, Digumarthy SR, Wright CD, Donahue DM, Wain JC, Mathisen DJ, Shepard JA. Radiofrequency ablation for treatment of medically inoperable stage I non-small cell lung cancer. J Thorac Cardiovasc Surg. 2009;137(1):160-6. USD. [pmid: 19154919].
Lau, Leigh B, Gandara D, Edelman M, Morgan R, Israel V, Lara P, Wilder R, Ryu J, Doroshow J. Twice-weekly paclitaxel and weekly carboplatin with concurrent thoracic radiation followed by carboplatin/paclitaxel consolidation for stage III non-small-cell lung cancer: a California Cancer Consortium phase II trial. J Clin Oncol. 2001;19(2):442-7. NRP. [pmid: 11208837].
Lau, Crowley JJ, Gandara DR, Hazuka MB, Albain KS, Leigh B, Fletcher WS, Lanier KS, Keiser WL, Livingston RB. Southwest Oncology Group phase II trial of concurrent carboplatin, etoposide, and radiation for poor-risk stage III non-small-cell lung cancer. J Clin Oncol. 1998;16(9):3078-81. NRP. [pmid: 9738578].
Lau, Ryu JK, Gandara DR. Chemoradiotherapy for poor-risk stage III non-small cell lung cancer. Semin Oncol. 1997;24(4 Suppl 12):S12-110-S12-112. NRP.
Lau, Ryu JK, Gandara DR, Rosenthal SA. Concurrent carboplatin, etoposide and thoracic radiation for poor-risk stage III non-small-cell lung carcinoma: a pilot study. Int J Radiat Oncol Biol Phys. 1997;38(1):157-61. NRP. [pmid: 9212018].
Lau, Ryu JK, Gandara DR, Morgan R, Doroshow J, Wilder R, Leigh B. Twice-weekly paclitaxel and radiation for stage III non-small cell lung cancer. Semin Oncol. 1997;24(4 Suppl 12):S12-106-S12-109. NRP.
Lau, Ryu J, Gandara D, Morgan R, Doroshow J, Wilder R, Leigh B. Concurrent twice-weekly paclitaxel and thoracic irradiation for stage III non-small cell lung cancer. Semin Radiat Oncol. 1999;9(2 Suppl 1):117-20. NRP. [pmid: 10210550].
Law, Karp DD, Dipetrillo T, Daly BT. Emergence of increased cerebral metastasis after high-dose preoperative radiotherapy with chemotherapy in patients with locally advanced nonsmall cell lung carcinoma. Cancer. 2001;92(1):160-4. NRP. [pmid: 11443622].
Lazarov, Mihaylova I, Gesheva-Atanasova N, Bakardjiev S. Comparative analysis of two radiotherapy regimens for the treatment of patients with non-small cell lung cancer. Radiotherapy and Oncology. 2011;99:S341. NRD.
Le Pechoux, Arriagada R, Le Chevalier T, Bretel JJ, Cosset BP, Ruffie P, Baldeyrou P, Grunenwald D. Concurrent cisplatin-vindesine and hyperfractionated thoracic radiotherapy in locally advanced nonsmall cell lung cancer. Int J Radiat Oncol Biol Phys. 1996;35(3):519-25. NRP. [pmid: 8655375].
Le, Loo BW, Ho A, Cotrutz C, Koong AC, Wakelee H, Kee ST, Constantinescu D, Whyte RI, Donington J. Results of a phase I dose-escalation study using single-fraction stereotactic radiotherapy for lung tumors. J Thorac Oncol. 2006;1(8):802-9. USD. [pmid: 17409963].
Lee, Scott C, Komaki R, Fossella FV, Dundas GS, McDonald S, Byhardt RW, Curran WJ Jr. Concurrent chemoradiation therapy with oral etoposide and cisplatin for locally advanced inoperable non-small-cell lung cancer: radiation therapy oncology group protocol 91-06. J Clin Oncol. 1996;14(4):1055-64. NRP. [pmid: 8648357].
Lee, Choi EK, Lee JS, Lee SD, Suh C, Kim SW, Kim WS, Ahn SD, Yi BY, Kim JH, Noh YJ, Kim SS, Koh Y, Kim DS, Kim WD. Phase II study of three-dimensional conformal radiotherapy and concurrent mitomycin-C, vinblastine, and cisplatin chemotherapy for Stage III locally advanced, unresectable, non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2003;56(4):996-1004. NRP. [pmid: 12829135].
Lee, Jin GY, Goldberg SN, Lee YC, Chung GH, Han YM, Lee SY, Kim CS. Percutaneous radiofrequency ablation for inoperable non-small cell lung cancer and metastases: preliminary report. Radiology. 2004;230(1):125-34. USD. [pmid: 14645875].
Lee, Jin GY, Han YM, Chung GH, Lee YC, Kwon KS, Lynch D. Comparison of Survival Rate in Primary Non-Small-Cell Lung Cancer Among Elderly Patients Treated With Radiofrequency Ablation, Surgery, or Chemotherapy. Cardiovasc Intervent Radiol. 2011. NRP.
Lee, Choi JH, Lim HY, Park JS, Kim HC, Kang S, Oh YT, Chun M, Sheen SS, Oh YJ, Park KJ, Hwang SC. The addition of induction chemotherapy with etoposide, ifosfamide, and cisplatin failed to improve therapeutic outcome of concurrent chemoradiotherapy in patients with locally advanced non-small cell lung cancer -- single institution retrospective analysis. Neoplasma. 2006;53(1):30-6. NRP. [pmid: 16416010].
Lee, Han JY, Cho KH, Pyo HR, Kim HY, Yoon SJ, Lee JS. Phase II study of induction chemotherapy with gemcitabine and vinorelbine followed by concurrent chemoradiotherapy with oral etoposide and cisplatin in patients with inoperable stage III non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2005;63(4):1037-44. NRP. [pmid: 16024178].
Lee, Komaki R, Fossella FV, Glisson BS, Hong WK, Cox JD. A pilot trial of hyperfractionated thoracic radiation therapy with concurrent cisplatin and oral etoposide for locally advanced inoperable non-small-cell lung cancer: a 5-year follow-up report. Int J Radiat Oncol Biol Phys. 1998;42(3):479-86. NRP. [pmid: 9806504].
Lee, Stinchcombe TE, Moore DT, Morris DE, Hayes DN, Halle J, Rosenman JG, Rivera MP, Socinski MA. Late complications of high-dose (>/=66 Gy) thoracic conformal radiation therapy in combined modality trials in unresectable stage III non-small cell lung cancer. J Thorac Oncol. 2009;4(1):74-9. NRP. [pmid: 19096310].
Lee, Kim YS, Kang JH, Lee SN, Kim YK, Ahn MI, Han DH, Yoo R, Wang Ie YP, Park JG, Yoon SC, Jang HS, Choi BO. Clinical Responses and Prognostic Indicators of Concurrent Chemoradiation for Non-small Cell Lung Cancer. Cancer Res Treat. 2011;43(1):32-41. NRP. [pmid: 21509161].
Leon, Cueva-Banuelos JF, Huidobro G, Firvida JL, Amenedo M, Lazaro M, Romero C, Estevez SV, Baron FJ, Grande C, Garcia J, Gonzalez Mata A, Castellanos J, Gomez A, Caeiro M, Rodriguez MR, Casal J. Gemcitabine, cisplatin and vinorelbine as induction chemotherapy followed by radical therapy in stage III non-small-cell lung cancer: a multicentre study of galician-lung-cancer-group. Lung Cancer. 2003;40(2):215-20. NRP. [pmid: 12711124].
Leong, Tan EH, Fong KW, Wilder-Smith E, Ong YK, Tai BC, Chew L, Lim SH, Wee J, Lee KM, Foo KF, Ang P, Ang PT. Randomized double-blind trial of combined modality treatment with or without amifostine in unresectable stage III non-small-cell lung cancer. J Clin Oncol. 2003;21(9):1767-74. NRP. [pmid: 12721253].
Leong, Fong KW, Lim WT, Toh CK, Yap SP, Hee SW, Tan EH. A phase II trial of induction gemcitabine and vinorelbine followed by concurrent vinorelbine and radiotherapy in locally advanced non-small cell lung cancer. Lung Cancer. 2010;67(3):325-9. NRP. [pmid: 19481290].
Leong, Fong KW, Ong YK, Foo KF, Ang P, Wee J, Lee KM, Tan EH. Chemo-radiotherapy for stage III unresectable non-small cell lung cancer long-term results of a prospective study. Respir Med. 2004;98(11):1080-6. NRP. [pmid: 15526808].
Lester, Macbeth FR, Brewster AE, Court JB, Iqbal N. CT-planned accelerated hypofractionated radiotherapy in the radical treatment of non-small cell lung cancer. Lung Cancer. 2004;45(2):237-42. USD. [pmid: 15246196].
Li, Shi AH, Li FH, Yu R, Zhu GY. Phase i study to determine MTD of docetaxel and cisplatin with concurrent radiation therapy for stage III non-small cell lung cancer. Chinese Journal of Cancer Research. 2011;23(2):129-133. NRP. [pmid: 23482452].
Li, Dai CH, Yu LC, Chen P, Li XQ, Shi SB, Wu JR. Results of trimodality therapy in patients with stage IIIA (N2-bulky) and stage IIIB non-small-cell lung cancer. Clin Lung Cancer. 2009;10(5):353-9. NRP. [pmid: 19808194].
Li, Dai CH, Shi SB, Chen P, Yu LC, Wu JR. Prognostic factors and long term results of neo adjuvant therapy followed by surgery in stage IIIA N2 non-small cell lung cancer patients. Annals of Thoracic Medicine. 2009;4(4):201-207. NRP. [pmid: 19881166].
Li, Bai H, Li X, Wu M, Yu R, Shi A, Yin L, Wang J, Zhu G. Role of EGFR mutation status in patients with stage III non-squamous non-small cell lung cancer treated with chemoradiotherapy. Chinese Journal of Lung Cancer. 2011;14(9):715-718. FLA. [pmid: 21924037].
Li, Gong HY, Huang W, Yi Y, Yu JM, Wang ZT, Zhang ZC, Sun HF, Li HS, Wang LY. Phase I Study of Pemetrexed, Cisplatin, and Concurrent Radiotherapy in Patients With Locally Advanced Non-small Cell Lung Cancer. Am J Clin Oncol. 2011. NRP.
Li, Yu JM, Xing LG, Yang GR, Sun XD, Xu J, Zhu H, Yue JB. Hypoxic imaging with 99mTc-HL91 single photon emission computed tomography in advanced nonsmall cell lung cancer. Chin Med J (Engl). 2006;119(17):1477-80. NRO. [pmid: 16989751].
Li, Hu M, Zhu H, Zhao W, Yang G, Yu J. Comparison of 18F-Fluoroerythronitroimidazole and 18F-fluorodeoxyglucose positron emission tomography and prognostic value in locally advanced non-small-cell lung cancer. Clin Lung Cancer. 2010;11(5):335-40. NRP. [pmid: 20837459].
Li, Zhang SH, Zhang Z, Wang RL. Efficacy of gemcitabine with concurrent radiotherapy on stage III,inoperable non-small cell lung cancer. 2007;26:1377-80. FLA.
Liao, Zhao J, Zhou Y. Multimodality therapy of late stage lung cancer. 1995;17:384-6. FLA.
Liao, Komaki R, Stevens C, Kelly J, Fossella F, Lee JS, Allen P, Cox JD. Twice daily irradiation increases locoregional control in patients with medically inoperable or surgically unresectable stage II–IIIB non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2002;53(3):558-65. NRP. [pmid: 12062597].
Liao, Komaki R, Milas L, Yuan C, Kies M, Chang JY, Jeter M, Guerrero T, Blumenschien G, Smith CM, Fossella F, Brown B, Cox JD. A phase I clinical trial of thoracic radiotherapy and concurrent celecoxib for patients with unfavorable performance status inoperable/unresectable non-small cell lung cancer. Clin Cancer Res. 2005;11(9):3342-8. NRI. [pmid: 15867233].
Liao, Komaki RR, Thames HD Jr, Liu HH, Tucker SL, Mohan R, Martel MK, Wei X, Yang K, Kim ES, Blumenschein G, Hong WK, Cox JD. Influence of technologic advances on outcomes in patients with unresectable, locally advanced non-small-cell lung cancer receiving concomitant chemoradiotherapy. Int J Radiat Oncol Biol Phys. 2010;76(3):775-81. NRP. [pmid: 19515503].
Lilenbaum, Samuels M, Taffaro-Neskey M, Cusnir M, Pizzolato J, Blaustein A. Phase II trial of combined modality therapy with myeloid growth factor support in patients with locally advanced non-small cell lung cancer. J Thorac Oncol. 2010;5(6):837-40. NRP. [pmid: 20421820].
Lin, Stewart DJ, Spitz MR, Hildebrandt MA, Lu C, Lin J, Gu J, Huang M, Lippman SM, Wu X. Genetic variations in the transforming growth factor-beta pathway as predictors of survival in advanced non-small cell lung cancer. Carcinogenesis. 2011;32(7):1050-6. NRP. [pmid: 21515830].
Lin, Wang J, Yue'E L, Su H, Wang N, Huang Y, Liu CX, Zhang P, Zhao Y, Chen K. High-dose 3-dimensional conformal radiotherapy with concomitant vinorelbine plus carboplatin in patients with non-small cell lung cancer: A feasibility study. Oncology Letters. 2011;2(4):669-674. NRP. [pmid: 22848247].
Lind, Lagerwaard FJ, Smit EF, Postmus PE, Slotman BJ, Senan S. Time for reappraisal of extracranial treatment options? Synchronous brain metastases from nonsmall cell lung cancer. Cancer. 2011;117(3):597-605. NRP. [pmid: 20872880].
Liu, Li HL, Zheng TR. Long term results of bronchial arterial infusion with chemotherapeutic agents plus radiation therapy in the teratment of locally advanced non small cell lung cancer. Chinese Journal of Cancer Research. 1999;11(1):66-69. NRP.
Livartowski, Dubray B, Dierick A, Beuzeboc P, Pouillart P, Cosset JM. A combined radiochemotherapy trial for non-small cell lung cancers: initial results. 1997;1:170-3. FLA.
Lochrin, Goss G, Stewart DJ, Cross P, Agboola O, Dahrouge S, Tomiak E, Evans WK. Concurrent chemotherapy with hyperfractionated accelerated thoracic irradiation in stage III non-small cell lung cancer. Lung Cancer. 1999;23(1):19-30. NRP. [pmid: 10100143].
Lokich, Auerbach M, Essig L, Fryer J, Fryer D. Etoposide plus cisplatin followed by thoracic radiation for stage IIIB non-small cell lung cancer: MAOP study 2188. J Infus Chemother. 1995;5(2):70-2. NRP. [pmid: 8521238].
Lonardi, Coeli M, Pavanato G, Adami F, Gioga G, Campostrini F. Radiotherapy for non-small cell lung cancer in patients aged 75 and over: safety, effectiveness and possible impact on survival. Lung Cancer. 2000;28(1):43-50. NRP. [pmid: 10704708].
Lopez-Picazo, Azinovic I, Aristu JJ, Martinez R, Moreno Monge M, Calvo Jimenez E, Beltran Aller C, Aramendia JM, Rebollo J, Brugarolas A. Induction platinum-based chemotherapy followed by radical hyperfractionated radiotherapy with concurrent chemotherapy in the treatment of locally advanced non-small-cell carcinoma of the lung. Am J Clin Oncol. 1999;22(2):203-8. NRP. [pmid: 10199463].
Louie, Rodrigues G, Hannouf M, Lagerwaard F, Palma D, Zaric GS, Haasbeek C, Senan S. Withholding stereotactic radiotherapy in elderly patients with stage I non-small cell lung cancer and co-existing COPD is not justified: outcomes of a Markov model analysis. Radiother Oncol. 2011;99(2):161-5. NRD. [pmid: 21620503].
Louie, Rodrigues G, Hannouf M, Zaric GS, Palma DA, Cao JQ, Yaremko BP, Malthaner R, Mocanu JD. Stereotactic body radiotherapy versus surgery for medically operable Stage I non-small-cell lung cancer: a Markov model-based decision analysis. Int J Radiat Oncol Biol Phys. 2011;81(4):964-73. NRD. [pmid: 20932688].
Low, Koh WY, Yap SP, Fong KW. Radical radiotherapy in stage I non-small cell lung cancer (NSCLC)--Singapore National Cancer Centre experience. Ann Acad Med Singapore. 2007;36(9):778-83. NRI. [pmid: 17925989].
Lu, Lee JJ, Komaki R, Herbst RS, Feng L, Evans WK, Choy H, Desjardins P, Esparaz BT, Truong MT, Saxman S, Kelaghan J, Bleyer A, Fisch MJ. Chemoradiotherapy with or without AE-941 in stage III non-small cell lung cancer: a randomized phase III trial. J Natl Cancer Inst. 2010;102(12):859-65. NRP. [pmid: 20505152].
Lunn, Stroud J, Tripcony L, Dauth M, Lehman M. Factors influencing survival in patients with synchronous solitary cerebral metastatic from non-small cell cancer of the lung. Journal of Thoracic Oncology. 2011;6(3):S9. NRD.
Lupattelli, Maranzano E, Bellavita R, Chionne F, Darwish S, Piro F, Latini P. Short-course palliative radiotherapy in non-small-cell lung cancer: results of a prospective study. Am J Clin Oncol. 2000;23(1):89-93. NRP. [pmid: 10683087].
Lupattelli, Massetti M, Bellavita R, Falcinelli L, Capezzali G, Leogrande MP, Salustri P, Saccia S, Aristei C. High dose-rate (HDR) brachitherapy in non-small cell lung cancer: A monoistitutional experience. Radiotherapy and Oncology. 2011;99:S342. NRD.
Lutz, Huang DT, Ferguson CL, Kavanagh BD, Tercilla OF, Lu J. A retrospective quality of life analysis using the Lung Cancer Symptom Scale in patients treated with palliative radiotherapy for advanced nonsmall cell lung cancer. Int J Radiat Oncol Biol Phys. 1997;37(1):117-22. NRP. [pmid: 9054885].
Maas, van der Lee I, Bolt K, Zanen P, Lammers JW, Schramel FM. Lung function changes and pulmonary complications in patients with stage III non-small cell lung cancer treated with gemcitabine/cisplatin as part of combined modality treatment. Lung Cancer. 2003;41(3):345-51. NRP. [pmid: 12928125].
Maas, El Sharouni SY, Phernambucq EC, Stigt JA, Groen HJ, Herder GJ, Van Den BE, Senan Borne S, Paul MA, Smit EF, Schramel FM. Weekly chemoradiation (docetaxel/cisplatin) followed by surgery in stage III NSCLC; a multicentre phase II study. Anticancer Res. 2010;30(10):4237-43. NRP. [pmid: 21036747].
Mac Manus, Wong K, Hicks RJ, Matthews JP, Wirth A, Ball DL. Early mortality after radical radiotherapy for non-small-cell lung cancer: comparison of PET-staged and conventionally staged cohorts treated at a large tertiary referral center. Int J Radiat Oncol Biol Phys. 2002;52(2):351-61. NRP. [pmid: 11872280].
Mac Manus, Hicks RJ, Matthews JP, McKenzie A, Rischin D, Salminen EK, Ball DL. Positron emission tomography is superior to computed tomography scanning for response-assessment after radical radiotherapy or chemoradiotherapy in patients with non-small-cell lung cancer. J Clin Oncol. 2003;21(7):1285-92. NRI. [pmid: 12663716].
Macbeth, Bolger JJ, Hopwood P, Bleehen NM, Cartmell J, Girling DJ, Machin D, Stephens RJ, Bailey AJ. Randomized trial of palliative two-fraction versus more intensive 13-fraction radiotherapy for patients with inoperable non-small cell lung cancer and good performance status. Medical Research Council. Lung Cancer Working Party. Clin Oncol (R Coll Radiol). 1996;8(3):167-75. NRP. [pmid: 8814371].
Macbeth, Wheldon TE, Girling DJ, Stephens RJ, Machin D, Bleehen NM, Lamont A, Radstone DJ, Reed NS. Radiation myelopathy: estimates of risk in 1048 patients in three randomized trials of palliative radiotherapy for non-small cell lung cancer. The Medical Research Council. Lung Cancer Working Party. Clin Oncol (R Coll Radiol). 1996;8(3):176-81. NRD. [pmid: 8814372].
Macha, Wahlers B, Reichle C, von Zwehl D. Endobronchial radiation therapy for obstructing malignancies: ten years' experience with iridium-192 high-dose radiation brachytherapy afterloading technique in 365 patients. Lung. 1995;173(5):271-80. USD. [pmid: 7564485].
Machtay, Hsu C, Komaki R, Sause WT, Swann RS, Langer CJ, Byhardt RW, Curran WJ. Effect of overall treatment time on outcomes after concurrent chemoradiation for locally advanced non-small-cell lung carcinoma: analysis of the Radiation Therapy Oncology Group (RTOG) experience. Int J Radiat Oncol Biol Phys. 2005;63(3):667-71. NRP. [pmid: 15927409].
Machtay, Washam C, Devine P. Pilot study of accelerated radiotherapy with concurrent chemotherapy for stage III non-small cell lung cancer. Semin Oncol. 2005;32(2 Suppl 3):S9-12. NRP. [pmid: 16015530].
Machtay, Lee JH, Stevenson JP, Shrager JB, Algazy KM, Treat J, Kaiser LR. Two commonly used neoadjuvant chemoradiotherapy regimens for locally advanced stage III non-small cell lung carcinoma: long-term results and associations with pathologic response. J Thorac Cardiovasc Surg. 2004;127(1):108-13. NRP. [pmid: 14752420].
Machtay, Seiferheld W, Komaki R, Cox JD, Sause WT, Byhardt RW. Is prolonged survival possible for patients with supraclavicular node metastases in non-small cell lung cancer treated with chemoradiotherapy?: Analysis of the Radiation Therapy Oncology Group experience. Int J Radiat Oncol Biol Phys. 1999;44(4):847-53. NRP. [pmid: 10386642].
MacRae, Shyr Y, Johnson D, Choy H. Declining hemoglobin during chemoradiotherapy for locally advanced non-small cell lung cancer is significant. Radiother Oncol. 2002;64(1):37-40. NRP. [pmid: 12208573].
Maguire, Sibley GS, Zhou SM, Jamieson TA, Light KL, Antoine PA, Herndon JE 2nd, Anscher MS, Marks LB. Clinical and dosimetric predictors of radiation-induced esophageal toxicity. Int J Radiat Oncol Biol Phys. 1999;45(1):97-103. NRP. [pmid: 10477012].
Maiwand. The role of cryosurgery in palliation of tracheo-bronchial carcinoma. Eur J Cardiothorac Surg. 1999;15(6):764-8. NRP. [pmid: 10431856].
Mak, Doran E, Muzikansky A, Kang J, Neal JW, Baldini EH, Choi NC, Willers H, Jackman DM, Sequist LV. Outcomes after combined modality therapy for EGFR-mutant and wild-type locally advanced NSCLC. Oncologist. 2011;16(6):886-95. NRP. [pmid: 21632451].
Mallick, Sharma SC, Behera D. Endobronchial brachytherapy for symptom palliation in non-small cell lung cancer--analysis of symptom response, endoscopic improvement and quality of life. Lung Cancer. 2007;55(3):313-8. USD. [pmid: 17157949].
Manegold, Latz D. Concurrent radiochemotherapy with ifosfamide in locally advanced unresectable non-small-cell lung cancer. Onkologie. 1998;21(SUPPL 2):15-18. NRP.
Mantz, Dosoretz DE, Rubenstein JH, Blitzer PH, Katin MJ, Garton GR, Nakfoor BM, Siegel AD, Tolep KA, Hannan SE, Dosani R, Feroz A, Maas C, Bhat S, Panjikaran G, Lalla S, Belani K, Ross RH. Endobronchial brachytherapy and optimization of local disease control in medically inoperable non-small cell lung carcinoma: a matched-pair analysis. Brachytherapy. 2004;3(4):183-90. NRP. [pmid: 15607149].
Mao, Kocak Z, Zhou S, Garst J, Evans ES, Zhang J, Larrier NA, Hollis DR, Folz RJ, Marks LB. The Impact of Induction Chemotherapy and the Associated Tumor Response on Subsequent Radiation-Related Changes in Lung Function and Tumor Response. International Journal of Radiation Oncology Biology Physics. 2007;67(5):1360-1369. NRP.
Marangolo, Emiliani E, Rosti G, Giannini M, Vertogen B, Zumaglini F. Paclitaxel and radiotherapy in the treatment of advanced non-small cell lung cancer. Semin Oncol. 1996;23(6 Suppl 15):31-4. NRP. [pmid: 8996595].
Marasso, Bernardi V, Gai R, Gallo E, Massaglia GM, Onoscuri M, Cardaci SB. Radiofrequency resection of bronchial tumours in combination with cryotherapy: evaluation of a new technique. Thorax. 1998;53(2):106-9. NRP. [pmid: 9624294].
Mariotta, Sposato B, Li E, Fiorucci Bianchi F, Ricci A, Carbone F, Crescenzi M, Schmid G. Combined treatment in advanced stages (IIIb–IV) of non-small cell lung cancer. Eur Rev Med Pharmacol Sci. 2002;6(2–3):49-54. NRP. [pmid: 12708610].
Marks, Garst J, Socinski MA, Sibley G, Blackstock AW, Herndon JE, Zhou S, Shafman T, Tisch A, Clough R, Yu X, Turrisi A, Anscher M, Crawford J, Rosenman J. Carboplatin/paclitaxel or carboplatin/vinorelbine followed by accelerated hyperfractionated conformal radiation therapy: report of a prospective phase I dose escalation trial from the Carolina Conformal Therapy Consortium. J Clin Oncol. 2004;22(21):4329-40. NRP. [pmid: 15514374].
Martel, Strawderman M, Hazuka MB, Turrisi AT, Fraass BA, Lichter AS. Volume and dose parameters for survival of non-small cell lung cancer patients. Radiother Oncol. 1997;44(1):23-9. NRP. [pmid: 9288853].
Martin, Ginsberg RJ, Venkatraman ES, Bains MS, Downey RJ, Korst RJ, Kris MG, Rusch VW. Long-term results of combined-modality therapy in resectable non-small-cell lung cancer. J Clin Oncol. 2002;20(8):1989-95. NRP. [pmid: 11956257].
Martins, Dienstmann R, de Biasi P, Dantas K, Santos V, Toscano E, Roriz W, Zamboni M, Sousa A, Small IA, Moreira D, Ferreira CG, Zukin M. Phase II trial of neoadjuvant chemotherapy using alternating doublets in non-small-cell lung cancer. Clin Lung Cancer. 2007;8(4):257-63. NRP. [pmid: 17311690].
Maruyama, Hirai F, Ondo K, Kometani T, Hamatake M, Seto T, Sugio K, Ichinose Y. Concurrent chemoradiotherapy using cisplatin plus S-1, an oral fluoropyrimidine, followed by surgery for selected patients with stage III non-small cell lung cancer: a single-center feasibility study. Surg Today. 2011;41(11):1492-7. NRP. [pmid: 21969151].
Masciullo, Casamassima F, Menichelli C, Bonucci I, Masi L, Doro R. Stereotactic body radiation therapy for inoperable NSCLC with stage I–II: A mono-institutional retrospective study. Radiotherapy and Oncology. 2011;99:S346. NRD.
Massabeau, Filleron T, Wakil G, Rouquette I, Bachaud JM, Leguellec S, Delisle MB, Toulas C, Mazieres J, Moyal EC. The Prognostic Significance of Lymphovascular Invasion on Biopsy Specimens in Lung Cancer Treated With Definitive Chemoradiotherapy. Clin Lung Cancer. 2011. NRI.
Masters, Wang X, Hodgson L, Shea T, Vokes E, Green M. A phase II trial of high dose carboplatin and paclitaxel with G-CSF and peripheral blood stem cell support followed by surgery and/or chest radiation in patients with stage III non-small cell lung cancer: CALGB 9531. Lung Cancer. 2011;74(2):258-63. NRP. [pmid: 21529989].
Mathisen, Wain JC, Wright C, Choi N, Carey R, Hilgenberg A, Grossbard M, Lynch T, Grillo H. Assessment of preoperative accelerated radiotherapy and chemotherapy in stage IIIA (N2) non-small-cell lung cancer. J Thorac Cardiovasc Surg. 1996;111(1):123-31. discussion 131–3. NRP. [pmid: 8551756].
Matsuo, Shibuya K, Nagata Y, Takayama K, Norihisa Y, Mizowaki T, Narabayashi M, Sakanaka K, Hiraoka M. Prognostic factors in stereotactic body radiotherapy for non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2011;79(4):1104-11. USD. [pmid: 20472343].
Matsuura, Kimura T, Kashiwado K, Fujita K, Akagi Y, Yuki S, Murakami Y, Wadasaki K, Monzen Y, Ito A, Kagemoto M, Mori M, Ito K, Nagata Y. Results of a preliminary study using hypofractionated involved-field radiation therapy and concurrent carboplatin/paclitaxel in the treatment of locally advanced non-small-cell lung cancer. Int J Clin Oncol. 2009;14(5):408-15. NRP. [pmid: 19856048].
Mattson, Abratt RP, ten Velde G, Krofta K. Docetaxel as neoadjuvant therapy for radically treatable stage III non-small-cell lung cancer: a multinational randomised phase III study. Ann Oncol. 2003;14(1):116-22. NRP. [pmid: 12488303].
Mattson. Docetaxel (Taxotere) in the neo-adjuvant setting in non-small-cell lung cancer. Ann Oncol. 1999;10(Suppl 5()):S69-72. NRP. [pmid: 10582143].
Mattson. Neoadjuvant chemotherapy with docetaxel in non--small cell lung cancer. Semin Oncol. 2001;28(3 Suppl 9):33-6. NRP. [pmid: 11441413].
Mauer, Masters GA, Haraf DJ, Hoffman PC, Watson SM, Golomb HM, Vokes EE. Phase I study of docetaxel with concomitant thoracic radiation therapy. J Clin Oncol. 1998;16(1):159-64. NRP. [pmid: 9440738].
Maurel, Martinez-Trufero J, Artal A, Martin C, Puertolas T, Zorrrilla M, Herrero A, Anton A, Rosell R. Prognostic impact of bulky mediastinal lymph nodes (N2>2.5 cm) in patients with locally advanced non-small-cell lung cancer (LA-NSCLC) treated with platinum-based induction chemotherapy. Lung Cancer. 2000;30(2):107-16. NRP. [pmid: 11086204].
McAleer, Moughan J, Byhardt RW, Cox JD, Sause WT, Komaki R. Does response to induction chemotherapy predict survival for locally advanced non-small-cell lung cancer? Secondary analysis of RTOG 8804/8808. Int J Radiat Oncol Biol Phys. 2010;76(3):802-8. NRP. [pmid: 19540055].
McGarry, Song G, des Rosiers P, Timmerman R. Observation-only management of early stage, medically inoperable lung cancer: poor outcome. Chest. 2002;121(4):1155-8. NRI. [pmid: 11948046].
McGarry, Papiez L, Williams M, Whitford T, Timmerman RD. Stereotactic body radiation therapy of early-stage non-small-cell lung carcinoma: phase I study. Int J Radiat Oncol Biol Phys. 2005;63(4):1010-5. NRI, USD. [pmid: 16115740].
McGovern, Liao Z, Bucci MK, McAleer MF, Jeter MD, Chang JY, O'Reilly MS, Cox JD, Allen PK, Komaki R. Is sex associated with the outcome of patients treated with radiation for nonsmall cell lung cancer?. Cancer. 2009;115(14):3233-42. NRI. [pmid: 19472405].
McGrath, Warriner D, Anderson P. The Insertion of Self Expanding Metal Stents With Flexible Bronchoscopy Under Sedation for Malignant Tracheobronchial Stenosis: A Single-Center Retrospective Analysis. Arch Bronconeumol. 2011. FLA.
Mehi, Zuti B, Dizdarevi H, Lomigori ZJ. Effectiveness of gemcitabine in combination with cisplatin in a randomized study of untreated patients with advanced non-small-cell lung carcinoma. 2004;58:11-3. FLA.
Mehta, Tannehill SP, Adak S, Martin L, Petereit DG, Wagner H, Fowler JF, Johnson D. Phase II trial of hyperfractionated accelerated radiation therapy for nonresectable non-small-cell lung cancer: results of Eastern Cooperative Oncology Group 4593. J Clin Oncol. 1998;16(11):3518-23. NRP. [pmid: 9817269].
Melotti, Guaraldi M, Sperandi F, Zamagni C, Giaquinta S, Oliverio G, Martoni AA. Long-term results of a pilot study on an intensive induction regimen for unresectable stage III non-small-cell lung cancer. Tumori. 2010;96(1):42-7. NRP. [pmid: 20437856].
Merchant, Kim K, Mehta MP, Ripple GH, Larson ML, Brophy DJ, Hammes LC, Schiller JH. Pilot and safety trial of carboplatin, paclitaxel, and thalidomide in advanced non-small-cell lung cancer. Clinical Lung Cancer. 2000;2(1):48-52. NRP. [pmid: 14731337].
Metcalfe, Milano MT, Bylund K, Smudzin T, Rubin P, Chen Y. Split-course palliative radiotherapy for advanced non-small cell lung cancer. J Thorac Oncol. 2010;5(2):185-90. NRI. [pmid: 20009771].
Meydan, Cakir S, Ozbek N, Gursel B, Karaoglanoglu O. Neoadjuvant chemotherapy and concomitant boost radiotherapy in locally advanced non-small cell lung cancer. Turkish Journal of Cancer. 2006;36(4):162-168. NRP.
Michael, Wirth A, Ball DL, MacManus M, Rischin D, Mileshkin L, Solomon B, McKendrick J, Milner AD. A phase I trial of high-dose palliative radiotherapy plus concurrent weekly Vinorelbine and Cisplatin in patients with locally advanced and metastatic NSCLC. Br J Cancer. 2005;93(6):652-61. NRD. [pmid: 16222311].
Migliorino, De Marinis F, Nelli F, Facciolo F, Ammaturo MV, Cipri A, Belli R, Ariganello O, Diana F, Di M, Martelli Molfetta O. A 3-week schedule of gemcitabine plus cisplatin as induction chemotherapy for Stage III non-small cell lung cancer. Lung Cancer. 2002;35(3):319-27. NRP. [pmid: 11844608].
Milano, Chen Y, Katz AW, Philip A, Schell MC, Okunieff P. Central thoracic lesions treated with hypofractionated stereotactic body radiotherapy. Radiotherapy and Oncology. 2009;91(3):301-306. NRP. [pmid: 19329210].
Milker-Zabel, Zabel A, Manegold C, Zuna I, Wannenmacher M, Debus J. Calcification in coronary arteries as quantified by CT scans correlated with tobacco consumption in patients with inoperable non-small cell lung cancer treated with three-dimensional radiotherapy. Br J Radiol. 2003;76(912):891-6. USD. [pmid: 14711777].
Milstein, Kuten A, Saute M, Best LA, Daoud K, Zen-Al-Deen I, Dale J, Robinson E. Preoperative concurrent chemoradiotherapy for unresectable Stage III nonsmall cell lung cancer. Int J Radiat Oncol Biol Phys. 1996;34(5):1125-32. NRP. [pmid: 8600097].
Minnich, Bryant AS, Dooley A, Cerfolio RJ. Photodynamic laser therapy for lesions in the airway. Ann Thorac Surg. 2010;89(6):1744-8. discussion 1748–9. NRP. [pmid: 20494021].
Mirimanoff, Moro D, Bolla M, Michel G, Brambilla C, Mermillod B, Miralbell R, Alberto P. Alternating radiotherapy and chemotherapy for inoperable Stage III non-small-cell lung cancer: long-term results of two Phase II GOTHA trials. Groupe d'Oncologie Thoracique Alpine. Int J Radiat Oncol Biol Phys. 1998;42(3):487-94. NRP. [pmid: 9806505].
Misirlioglu, Erkal H, Elgin Y, Ugur I, Altundag K. Effect of concomitant use of pentoxifylline and alpha-tocopherol with radiotherapy on the clinical outcome of patients with stage IIIB non-small cell lung cancer: a randomized prospective clinical trial. Med Oncol. 2006;23(2):185-9. NRP. [pmid: 16720918].
Misirlioglu, Demirkasimoglu T, Kucukplakci B, Sanri E, Altundag K. Pentoxifylline and alpha-tocopherol in prevention of radiation-induced lung toxicity in patients with lung cancer. 2007;24:308-11. NRP.
Mitchell, Thursfield V, Wright G, Ball D, Richardson G, Irving L, Giles G. Management of lung cancer in Victoria: Have we made progress?. Journal of Thoracic Oncology. 2011;6(3):S8. NRD.
Mitsumori, Zeng ZF, Oliynychenko P, Park JH, Choi IB, Tatsuzaki H, Tanaka Y, Hiraoka M. Regional hyperthermia combined with radiotherapy for locally advanced non-small cell lung cancers: a multi-institutional prospective randomized trial of the International Atomic Energy Agency. Int J Clin Oncol. 2007;12(3):192-8. NRP. [pmid: 17566842].
Miyaji. Radiotherapy following bronchial artery infusion (BAI) chemotherapy for lung cancer - Analysis of long-term treatment results of 168 patients. Journal of JASTRO. 1995;7(4):331-340. NRI.
Miyamoto, Baba M, Yamamoto N, Koto M, Sugawara T, Yashiro T, Kadono K, Ezawa H, Tsujii H, Mizoe JE, Yoshikawa K, Kandatsu S, Fujisawa T. Curative treatment of Stage I non-small-cell lung cancer with carbon ion beams using a hypofractionated regimen. Int J Radiat Oncol Biol Phys. 2007;67(3):750-8. NRI. [pmid: 17293232].
Miyamoto, Baba M, Sugane T, Nakajima M, Yashiro T, Kagei K, Hirasawa N, Sugawara T, Yamamoto N, Koto M, Ezawa H, Kadono K, Tsujii H, Mizoe JE, Yoshikawa K, Kandatsu S, Fujisawa T. Carbon ion radiotherapy for stage I non-small cell lung cancer using a regimen of four fractions during 1 week. J Thorac Oncol. 2007;2(10):916-26. NRI. [pmid: 17909354].
Miyamoto, Yamamoto N, Nishimura H, Koto M, Tsujii H, Mizoe JE, Kamada T, Kato H, Yamada S, Morita S, Yoshikawa K, Kandatsu S, Fujisawa T. Carbon ion radiotherapy for stage I non-small cell lung cancer. Radiother Oncol. 2003;66(2):127-40. NRI. [pmid: 12648784].
Moghissi, Dixon K, Stringer M, Freeman T, Thorpe A, Brown S. The place of bronchoscopic photodynamic therapy in advanced unresectable lung cancer: experience of 100 cases. Eur J Cardiothorac Surg. 1999;15(1):1-6. USD. [pmid: 10077365].
Moghissi, Bond MG, Sambrook RJ, Stephens RJ, Hopwood P, Girling DJ. Treatment of endotracheal or endobronchial obstruction by non-small cell lung cancer: lack of patients in an MRC randomized trial leaves key questions unanswered. Medical Research Council Lung Cancer Working Party. 1999;11:179-83. USD.
Mohammed, Grills IS, Wong CYO, Galerani AP, Chao K, Welsh R, Chmielewski G, Yan D, Kestin LL. Radiographic and metabolic response rates following image-guided stereotactic radiotherapy for lung tumors. Radiotherapy and Oncology. 2011;99(1):18-22. NRO. [pmid: 21458087].
Momm, Kaden M, Tannock I, Schumacher M, Hasse J, Henke M. Dose escalation of gemcitabine concomitant with radiation and cisplatin for nonsmall cell lung cancer: a phase 1–2 study. Cancer. 2010;116(20):4833-9. NRP. [pmid: 20589760].
Moreno, Aristu J, Ramos LI, Arbea L, Lopez-Picazo JM, Cambeiro M, Martinez-Monge R. Predictive factors for radiation-induced pulmonary toxicity after three-dimensional conformal chemoradiation in locally advanced non-small-cell lung cancer. Clin Transl Oncol. 2007;9(9):596-602. NRP. [pmid: 17921108].
Moreno-Jimenez, Aristu J, Lopez-Picazo JM, Ramos LI, Gurpide A, Gomez-Iturriaga A, Valero J, Martinez-Monge R. Dosimetric analysis of the patterns of local failure observed in patients with locally advanced non-small cell lung cancer treated with neoadjuvant chemotherapy and concurrent conformal (3D-CRT) chemoradiation. Radiother Oncol. 2008;88(3):342-50. NRP. [pmid: 18558448].
Morita, Fuwa N, Suzuki Y, Nishio M, Sakai K, Tamaki Y, Niibe H, Chujo M, Wada S, Sugawara T, Kita M. Radical radiotherapy for medically inoperable non-small cell lung cancer in clinical stage I: a retrospective analysis of 149 patients. Radiother Oncol. 1997;42(1):31-6. NRI. [pmid: 9132823].
Morris, Budde JM, Godette KD, Kerwin TL, Miller JI Jr, Reed CE, Cerfolio RJ. Palliative management of malignant airway obstruction. Annals of Thoracic Surgery. 2002;74(6):1928-1933. USD. [pmid: 12643375].
Moscetti, Nelli F, Felici A, Rinaldi M, De Santis S, D'Auria G, Mansueto G, Tonini G, Sperduti I, Pollera FC. Up-front chemotherapy and radiation treatment in newly diagnosed nonsmall cell lung cancer with brain metastases: survey by Outcome Research Network for Evaluation of Treatment Results in Oncology. Cancer. 2007;109(2):274-81. NRP. [pmid: 17154161].
Mostafa, Khatab A, Al-Adwy ER, Al-Assal GM. Limited Field Radiotherapy Concomitant with Cisplatin/Etoposide Followed by Consolidation Docetaxel for the Treatment of Inoperable Stage III Non-Small Cell Lung Cancer. J Egypt Natl Canc Inst. 2007;19(1):28-38. NRP. [pmid: 18839033].
Movsas, Langer CJ, Ross HJ, Wang L, Jotte RM, Feigenberg S, Xu F, Huang CH, Monberg MJ, Obasaju CK. Randomized phase II trial of cisplatin, etoposide, and radiation followed by gemcitabine alone or by combined gemcitabine and docetaxel in stage III A/B unresectable non-small cell lung cancer. J Thorac Oncol. 2010;5(5):673-9. NRP. [pmid: 20354453].
Movsas, Scott C, Langer C, Werner-Wasik M, Nicolaou N, Komaki R, Machtay M, Smith C, Axelrod R, Sarna L, Wasserman T, Byhardt R. Randomized trial of amifostine in locally advanced non-small-cell lung cancer patients receiving chemotherapy and hyperfractionated radiation: radiation therapy oncology group trial 98-01. J Clin Oncol. 2005;23(10):2145-54. NRP. [pmid: 15800308].
Movsas, Scott C, Sause W, Byhardt R, Komaki R, Cox J, Johnson D, Lawton C, Dar AR, Wasserman T, Roach M, Lee JS, Andras E. The benefit of treatment intensification is age and histology-dependent in patients with locally advanced non-small cell lung cancer (NSCLC): a quality-adjusted survival analysis of radiation therapy oncology group (RTOG) chemoradiation studies. Int J Radiat Oncol Biol Phys. 1999;45(5):1143-9. NRP. [pmid: 10613306].
Movsas, Moughan J, Sarna L, Langer C, Werner-Wasik M, Nicolaou N, Komaki R, Machtay M, Wasserman T, Bruner DW. Quality of life supersedes the classic prognosticators for long-term survival in locally advanced non-small-cell lung cancer: an analysis of RTOG 9801. J Clin Oncol. 2009;27(34):5816-22. NRP. [pmid: 19858383].
Movsas, Hudes RS, Schol J, Mellenson M, Rosvold E, Nicolaou N, Litwin S, Wang H, Keenan E, Curran WJ Jr, Langer CJ. Induction and concurrent paclitaxel/carboplatin every 3 weeks with thoracic radiotherapy in locally advanced non-small-cell lung cancer: an interim report. Clin Lung Cancer. 2001;3(2):125-32. discussion 133. NRP. [pmid: 14659027].
Mudad, Ramsey M, Kovitz K, Curiel TJ, Hartz R, Nedzi LL, Weiner RS, Zakris EL. Concomitant weekly docetaxel, cisplatin and radiation therapy in locally advanced non-small cell lung cancer: a dose finding study. Lung Cancer. 2003;39(2):173-7. NRP. [pmid: 12581570].
Murai, Shibamoto Y, Baba F, Hashizume C, Mori Y, Ayakawa S, Kawai T, Takemoto S, Sugie C, Ogino H. Progression of Non-Small-Cell Lung Cancer During the Interval Before Stereotactic Body Radiotherapy. Int J Radiat Oncol Biol Phys. 2010. NRO.
Murakami, Kuroda Y, Sano A, Noma S, Kanaoka N, Ishikura S, Yamada K, Takamori M, Mori T, Okada T. Therapeutic results of non-small cell lung cancer in stage III: combined synchronous irradiation with bronchial artery infusion of CDDP. 1995;55:44-9. FLA.
Mutter, Lu B, Carbone DP, Csiki I, Moretti L, Johnson DH, Morrow JD, Sandler AB, Shyr Y, Ye F, Choy H. A phase II study of celecoxib in combination with paclitaxel, carboplatin, and radiotherapy for patients with inoperable stage IIIA/B non-small cell lung cancer. Clin Cancer Res. 2009;15(6):2158-65. NRP. [pmid: 19276291].
Naito, Kubota K, Nihei K, Fujii T, Yoh K, Niho S, Goto K, Ohmatsu H, Saijo N, Nishiwaki Y. Concurrent chemoradiotherapy with cisplatin and vinorelbine for stage III non-small cell lung cancer. J Thorac Oncol. 2008;3(6):617-22. NRP. [pmid: 18520801].
Nakamura, Fuwa N, Kodaira T, Tachibana H, Tomoda T, Nakahara R, Inokuchi H. Clinical outcome of stage III non-small-cell lung cancer patients after definitive radiotherapy. Lung. 2008;186(2):91-6. NRP. [pmid: 18097718].
Nakamura, Kawasaki N, Hagiwara M, Ogata A, Saito M, Konaka C, Kato H. Early hilar lung cancer--risk for multiple lung cancers and clinical outcome. Lung Cancer. 2001;33(1):51-7. USD. [pmid: 11429195].
Nakamura, Koizumi T, Hayasaka M, Yasuo M, Tsushima K, Kubo K, Gomi K, Shikama N. Cisplatin and weekly docetaxel with concurrent thoracic radiotherapy for locally advanced stage III non-small-cell lung cancer. Cancer Chemother Pharmacol. 2009;63(6):1091-6. NRP. [pmid: 18818921].
Nakano, Hiramoto T, Kanehara M, Doi M, Hada Y, Nakamura K. Concurrent high-dose thoracic irradiation plus daily low-dose cisplatin and vindesine in locally advanced unresectable stage III non-small cell lung cancer. Japanese Journal of Lung Cancer. 2000;40(2):111-115. FLA.
Nakayama, Satoh H, Kurishima K, Ishikawa H, Tokuuye K. High-dose conformal radiotherapy for patients with stage III non-small-cell lung carcinoma. Int J Radiat Oncol Biol Phys. 2010;78(3):645-50. NRP. [pmid: 20869582].
Nakayama, Satoh H, Sugahara S, Kurishima K, Tsuboi K, Sakurai H, Ishikawa S, Tokuuye K. Proton beam therapy of Stage II and III non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2011;81(4):979-84. NRP. [pmid: 20888140].
Nakayama, Hayakawa K, Mitsuhashi N, Saito Y, Niibe H. Long-term survivors of non-small cell lung cancer after radiation therapy: the significance of histological type. Anticancer Res. 1997;17(4A):2769-73. NRP. [pmid: 9252713].
Nath, Sandhu AP, Kim D, Bharne A, Nobiensky PD, Lawson JD, Fuster M, Bazhenova L, Song WY, Mundt AJ. Locoregional and distant failure following image-guided stereotactic body radiation for early-stage primary lung cancer. Radiotherapy and Oncology. 2011;99(1):12-17. USD. [pmid: 21429608].
Nawrocki, Krzakowski M, Wasilewska-Tesluk E, Kowalski D, Rucinska M, Dziadziuszko R, Sowa A. Concurrent chemotherapy and short course radiotherapy in patients with stage IIIA to IIIB non-small cell lung cancer not eligible for radical treatment: results of a randomized phase II study. J Thorac Oncol. 2010;5(8):1255-62. NRP. [pmid: 20592630].
Nestle, Nieder C, Walter K, Niewald M, Motaref B, Braun-Fischer A, Ukena D, Sybrecht GW, Schnabel K. Palliative accelerated irradiation for advanced non-small-cell lung bronchial carcinoma: results of a pilot study. 1999;53:385-92. FLA.
Nestle, Nieder C, Walter K, Abel U, Ukena D, Sybrecht GW, Schnabel K. A palliative accelerated irradiation regimen for advanced non-small-cell lung cancer vs. conventionally fractionated 60 GY: results of a randomized equivalence study. Int J Radiat Oncol Biol Phys. 2000;48(1):95-103. NRP. [pmid: 10924977].
Nestle, Nieder C, Abel U, Niewald M, Ukena D, Berberich W, Schnabel K. A palliative accelerated irradiation regimen (PAIR) for advanced non-small-cell lung cancer (NSCLC). Radiother Oncol. 1996;38(3):195-203. NRP. [pmid: 8693099].
Nestle, Hellwig D, Fleckenstein J, Walter K, Ukena D, Rube C, Kirsch CM, Baumann M. Comparison of early pulmonary changes in 18FDG-PET and CT after combined radiochemotherapy for advanced non-small-cell lung cancer: a study in 15 patients. Front Radiat Ther Oncol. 2002;37:26-33. NRP. [pmid: 11764664].
Ng, Tung SY, Wong VY. Hypofractionated stereotactic radiotherapy for medically inoperable stage I non-small cell lung cancer--report on clinical outcome and dose to critical organs. Radiother Oncol. 2008;87(1):24-8. USD. [pmid: 18334273].
Nguyen, Leonardo JM, Karlsson U, Vos P, Bullock L, Thomas P, Lepera P, Ludin A, Chu C, Salehpour M, Jendrasiak G, Sallah S. Efficacy of combined radiation, paclitaxel and carboplatin for locally advanced non-small cell lung carcinoma. Anticancer Res. 2002;22(6B):3429-35. NRP. [pmid: 12552935].
Nguyen, Komaki R, Allen P, Schea RA, Milas L. Effectiveness of accelerated radiotherapy for patients with inoperable non-small cell lung cancer (NSCLC) and borderline prognostic factors without distant metastasis: a retrospective review. Int J Radiat Oncol Biol Phys. 1999;44(5):1053-6. NRP. [pmid: 10421538].
Nieder, Nestle U, Walter K, Niewald M, Schnabel K. Dose-response relationships for radiotherapy of brain metastases: role of intermediate-dose stereotactic radiosurgery plus whole-brain radiotherapy. Am J Clin Oncol. 2000;23(6):584-8. NRP. [pmid: 11202802].
Nihei, Ishikura S, Kawashima M, Ogino T, Ito Y, Ikeda H. Short-course palliative radiotherapy for airway stenosis in non-small cell lung cancer. Int J Clin Oncol. 2002;7(5):284-8. NRP. [pmid: 12402061].
Nihei, Ogino T, Ishikura S, Nishimura H. High-dose proton beam therapy for Stage I non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2006;65(1):107-11. USD. [pmid: 16458447].
Nishimura, Nakagawa K, Takeda K, Tanaka M, Segawa Y, Tsujino K, Negoro S, Fuwa N, Hida T, Kawahara M, Katakami N, Hirokawa K, Yamamoto N, Fukuoka M, Ariyoshi Y. Phase I/II trial of sequential chemoradiotherapy using a novel hypoxic cell radiosensitizer, doranidazole (PR-350), in patients with locally advanced non-small-cell lung Cancer (WJTOG-0002). Int J Radiat Oncol Biol Phys. 2007;69(3):786-92. NRP. [pmid: 17512126].
Nuyttens, Prevost JB, Praag J, Hoogeman M, Van Klaveren RJ, Levendag PC, Pattynama PM. Lung tumor tracking during stereotactic radiotherapy treatment with the CyberKnife: Marker placement and early results. Acta Oncol. 2006;45(7):961-5. NRO. [pmid: 16982564].
Nyman, Bergman B, Mercke C. Accelerated hyperfractionated radiotherapy combined with induction and concomitant chemotherapy for inoperable non-small-cell lung cancer--impact of total treatment time. Acta Oncol. 1998;37(6):539-45. NRI. [pmid: 9860311].
Nyman, Friesland S, Hallqvist A, Seke M, Bergstrom S, Thaning L, Loden B, Sederholm C, Wagenius G. How to improve loco-regional control in stages IIIa–b NSCLC? Results of a three-armed randomized trial from the Swedish Lung Cancer Study Group. Lung Cancer. 2009;65(1):62-7. NRP. [pmid: 19081652].
Ohashi, Takahashi K, Miura K, Ishiwata T, Sakuraba S, Fukuchi Y. Prognostic factors in patients with inoperable non-small cell lung cancer--an analysis of long-term survival patients. Gan To Kagaku Ryoho. 2006;33(11):1595-602. NRP. [pmid: 17108725].
Ohe, Ishizuka N, Tamura T, Sekine I, Nishiwaki Y, Saijo N. Long-term follow-up of patients with unresectable locally advanced non-small cell lung cancer treated with chemoradiotherapy: a retrospective analysis of the data from the Japan Clinical Oncology Group trials (JCOG0003A). Cancer Sci. 2003;94(8):729-34. NRD. [pmid: 12901800].
Ohguri, Imada H, Yahara K, Morioka T, Nakano K, Terashima H, Korogi Y. Radiotherapy with 8-MHz radiofrequency-capacitive regional hyperthermia for stage III non-small-cell lung cancer: the radiofrequency-output power correlates with the intraesophageal temperature and clinical outcomes. Int J Radiat Oncol Biol Phys. 2009;73(1):128-35. NRP. [pmid: 18513887].
Ohnishi, Okada J, Yamaguchi M, Ogata H, Hatano K, Takizawa Y, Imai Y, Hara R, Araki T. Effect of daily administration of oral etoposide for non-small cell lung cancer treated with concurrent radiation therapy. 1997;57:510-4. FLA.
Ohyanagi, Yamamoto N, Horiike A, Harada H, Kozuka T, Murakami H, Gomi K, Takahashi T, Morota M, Nishimura T, Endo M, Nakamura Y, Tsuya A, Horai T, Nishio M. Phase II trial of S-1 and cisplatin with concurrent radiotherapy for locally advanced non-small-cell lung cancer. Br J Cancer. 2009;101(2):225-31. NRP. [pmid: 19603031].
Oka, Fukuda M, Kinoshita A, Kuba M, Ichiki M, Rikimaru T, Soda H, Takatani H, Narasaki F, Nagashima S, Nakamura Y, Hayashi N, Kohno S. Phase I study of irinotecan and cisplatin with concurrent split-course radiotherapy in unresectable and locally advanced non-small cell lung cancer. Eur J Cancer. 2001;37(11):1359-65. NRP. [pmid: 11435065].
Okamoto, Murakami M, Mizowaki T, Nakajima T, Kuroda Y. Radiotherapy for stage I–II non-small cell lung cancer. International Journal of Clinical Oncology. 1999;4(6):372-377. NRI.
Okamoto, Maruyama R, Shoji F, Asoh H, Ikeda J, Miyamoto T, Nakamura T, Miyake T, Ichinose Y. Long-term survivors in stage IV non-small cell lung cancer. Lung Cancer. 2005;47(1):85-91. NRP. [pmid: 15603858].
Okamoto, Takahashi T, Okamoto H, Nakagawa K, Watanabe K, Nakamatsu K, Nishimura Y, Fukuoka M, Yamamoto N. Single-agent gefitinib with concurrent radiotherapy for locally advanced non-small cell lung cancer harboring mutations of the epidermal growth factor receptor. Lung Cancer. 2011;72(2):199-204. NRP. [pmid: 20828860].
Ong, Palma D, Verbakel WF, Slotman BJ, Senan S. Treatment of large stage I–II lung tumors using stereotactic body radiotherapy (SBRT): planning considerations and early toxicity. Radiother Oncol. 2010;97(3):431-6. NRP. [pmid: 20971523].
Onimaru, Fujino M, Yamazaki K, Onodera Y, Taguchi H, Katoh N, Hommura F, Oizumi S, Nishimura M, Shirato H. Steep dose-response relationship for stage I non-small-cell lung cancer using hypofractionated high-dose irradiation by real-time tumor-tracking radiotherapy. Int J Radiat Oncol Biol Phys. 2008;70(2):374-81. USD. [pmid: 18029106].
Onishi, Shirato H, Nagata Y, Hiraoka M, Fujino M, Gomi K, Niibe Y, Karasawa K, Hayakawa K, Takai Y, Kimura T, Takeda A, Ouchi A, Hareyama M, Kokubo M, Hara R, Itami J, Yamada K, Araki T. Hypofractionated stereotactic radiotherapy (HypoFXSRT) for stage I non-small cell lung cancer: updated results of 257 patients in a Japanese multi-institutional study. J Thorac Oncol. 2007;2(7 Suppl 3):S94-100. USD. [pmid: 17603311].
Onishi, Kuriyama K, Yamaguchi M, Komiyama T, Tanaka S, Araki T, Nishikawa K, Ishihara H. Concurrent two-dimensional radiotherapy and weekly docetaxel in the treatment of stage III non-small cell lung cancer: a good local response but no good survival due to radiation pneumonitis. Lung Cancer. 2003;40(1):79-84. NRP. [pmid: 12660011].
Onishi, Kuriyama K, Komiyama T, Tanaka S, Sano N, Marino K, Ikenaga S, Araki T, Uematsu M. Clinical outcomes of stereotactic radiotherapy for stage I non-small cell lung cancer using a novel irradiation technique: patient self-controlled breath-hold and beam switching using a combination of linear accelerator and CT scanner. Lung Cancer. 2004;45(1):45-55. OPP. [pmid: 15196734].
Onishi, Araki T, Shirato H, Nagata Y, Hiraoka M, Gomi K, Yamashita T, Niibe Y, Karasawa K, Hayakawa K, Takai Y, Kimura T, Hirokawa Y, Takeda A, Ouchi A, Hareyama M, Kokubo M, Hara R, Itami J, Yamada K. Stereotactic hypofractionated high-dose irradiation for stage I nonsmall cell lung carcinoma: clinical outcomes in 245 subjects in a Japanese multiinstitutional study. Cancer. 2004;101(7):1623-31. OPP. [pmid: 15378503].
Oral, Aydiner A, Eralp Y, Topuz E. Induction and concurrent chemotherapy with concomitant boost radiotherapy in non-small cell lung cancer. Med Oncol. 2005;22(4):367-74. NRP. [pmid: 16260854].
Oral, Bavbek S, Kizir A, Tenececi N, Yoney A, Kaytan E, Topuz E. Preliminary analysis of a phase II study of Paclitaxel and CHART in locally advanced non-small cell lung cancer. Lung Cancer. 1999;25(3):191-8. NRP. [pmid: 10512130].
Oral. Long term results of CHART and weekly Paclitaxel in locally advanced non-small cell lung cancer. Lung Cancer. 2005;49(3):421-2. NRD. [pmid: 16102609].
Oshita, Ohe M, Honda T, Murakami S, Kondo T, Saito H, Noda K, Yamashita K, Nakayama Y, Yamada K. Phase II study of nedaplatin and irinotecan with concurrent thoracic radiotherapy in patients with locally advanced non-small-cell lung cancer. Br J Cancer. 2010;103(9):1325-30. NRP. [pmid: 20940720].
Oshita, Kato Y, Yamada K, Nomura I, Sugiyama M, Yamashita K, Kitamura T, Noda K. A feasibility study of continuous etoposide infusion combined with thoracic radiation for non-small cell lung cancer. Oncol Rep. 1999;6(2):263-8. NRP. [pmid: 10022987].
Ozkaya, Findik S, Atici AG, Dirica A. Cisplatin-based chemotherapy in elderly patients with advanced stage (IIIB and IV) non-small cell lung cancer patients. Neoplasma. 2011;58(4):348-51. NRP. [pmid: 21520993].
Ozkok, Aras AB, Esassolak MA, Arican AH, Yalman D, Haydaroglu A. Hyperfractionated radiotherapy combined with simultaneous chemotherapy in inoperable non-small cell lung cancer: a pilot study. Monaldi Arch Chest Dis. 1995;50(6):443-7. NRP. [pmid: 8834953].
Ozkok, Karakoyun-Celik O, Goksel T, Mogulkoc N, Yalman D, Gok G, Bolukbasi Y. High dose rate endobronchial brachytherapy in the management of lung cancer: response and toxicity evaluation in 158 patients. Lung Cancer. 2008;62(3):326-33. NRP. [pmid: 18482780].
Palazzi, Morrica B, Montanaro P, Cerizza L, Leoni M. Hyperfractionated radiotherapy and concomitant cisplatin in stage III non-small cell lung cancer: a phase II study by the AIRO-Lombardia Cooperative Group. Lung Cancer. 1996;15(1):85-91. NRP. [pmid: 8865126].
Pallares, Capdevila J, Paredes A, Farre N, Ciria JP, Membrive I, Basterrechea L, Gomez-Segura G, Barnadas A. Induction chemotherapy with paclitaxel plus carboplatin followed by paclitaxel with concurrent radiotherapy in stage IIIB non-small-cell lung cancer (NSCLC) patients: a phase II trial. Lung Cancer. 2007;58(2):238-45. NRP. [pmid: 17658655].
Palma, Visser O, Lagerwaard FJ, Belderbos J, Slotman BJ, Senan S. Impact of introducing stereotactic lung radiotherapy for elderly patients with stage I non-small-cell lung cancer: a population-based time-trend analysis. J Clin Oncol. 2010;28(35):5153-9. NRP. [pmid: 21041709].
Palma, Visser O, Lagerwaard FJ, Belderbos J, Slotman B, Senan S. Treatment of stage i NSCLC in elderly patients: A population-based matched-pair comparison of stereotactic radiotherapy versus surgery. Radiotherapy and Oncology. 2011;101(2):240-244. USD. [pmid: 21775007].
Palma, Tyldesley S, Sheehan F, Mohamed IG, Smith S, Wai E, Murray N, Senan S. Stage I non-small cell lung cancer (NSCLC) in patients aged 75 years and older: does age determine survival after radical treatment?. J Thorac Oncol. 2010;5(6):818-24. NRI. [pmid: 20521349].
Paludan, Traberg A, Petersen Hansen J, Grau C, Hoyer M. Aggravation of dyspnea in stage I non-small cell lung cancer patients following stereotactic body radiotherapy: Is there a dose-volume dependency?. Acta Oncol. 2006;45(7):818-22. NRO. [pmid: 16982545].
Paprota, Karczmarek-Borowska B, Budny B, Furmanik F. Efficacy of combined treatment (chemotherapy + radiotherapy) of non-small cell lung cancer in stage IIIA. Onkologia Polska. 2001;4(2):69-74. FLA.
Parashar, Edwards A, Mehta R, Pasmantier M, Wernicke AG, Sabbas A, Kerestez RS, Nori D, Chao KS. Chemotherapy significantly increases the risk of radiation pneumonitis in radiation therapy of advanced lung cancer. Am J Clin Oncol. 2011;34(2):160-4. NRP. [pmid: 20498591].
Parisi, Romeo A, Ghigi G, Bellia S, Giannini M, Micheletti S, Neri E, D'Angelo A, Fabbri C, Menghi E, Sarnelli A, Polico R. Accelerated hypofractionated radiotherapy in inoperable locally advanced lung cancer using tomotherapy: Our experience. Strahlentherapie und Onkologie. 2011;187(10):680. NRD.
Park, Park JO, Kim H, Ahn YC, Choi YS, Kim K, Kim J, Shim YM, Ahn JS, Park K. Is trimodality approach better then bimodality in stage IIIA, N2 positive non-small cell lung cancer?. Lung Cancer. 2006;53(3):323-30. NRP. [pmid: 16844258].
Park, Kim MK, Kyung SY, Lim YH, An CH, Park JW, Jeong SH, Lee JW, Lee KC, Cho EK, Bang SM, Shin DB, Lee JH. A phase II study of weekly paclitaxel, cisplatin and concurrent radiation therapy for locally-advanced unresectable non-small cell lung cancer: early closure due to lack of efficacy. Cancer Res Treat. 2004;36(5):293-7. NRP. [pmid: 20368818].
Park, Ahn YC, Kim H, Lee SH, Park SH, Lee KE, Lim DH, Kim K, Jung CW, Im YH, Kang WK, Lee MH, Park K. A phase II trial of concurrent chemoradiation therapy followed by consolidation chemotherapy with oral etoposide and cisplatin for locally advanced inoperable non-small cell lung cancers. Lung Cancer. 2003;42(2):227-35. NRP. [pmid: 14568691].
Patel, Jenkins J, Papadopolous N, Andrew M, Plager Burgess C, Gutterman J, Benjamin RS. Dose-escalating conformal thoracic radiation therapy with induction and concurrent carboplatin/paclitaxel in unresectable stage IIIA/B nonsmall cell lung carcinoma: A modified phase I/II trial. Cancer. 2001;92(5):1213-1223. NRP. [pmid: 11571735].
Patel, Ajlouni M, Chapman R, Lu M, Movsas B, Kim JH. A prospective phase II study of induction carboplatin and vinorelbine followed by concomitant topotecan and accelerated radiotherapy (ART) in locally advanced non-small cell lung cancer (NSCLC). J Thorac Oncol. 2007;2(9):831-7. NRP. [pmid: 17805061].
Patel, Edelman MJ, Kwok Y, Krasna MJ, Suntharalingam M. Predictors of acute esophagitis in patients with non-small-cell lung carcinoma treated with concurrent chemotherapy and hyperfractionated radiotherapy followed by surgery. Int J Radiat Oncol Biol Phys. 2004;60(4):1106-12. NRP. [pmid: 15519781].
Pennathur, Abbas G, Gooding WE, Schuchert MJ, Gilbert S, Christie NA, Landreneau RJ, Luketich JD. Image-guided radiofrequency ablation of lung neoplasm in 100 consecutive patients by a thoracic surgical service. Ann Thorac Surg. 2009;88(5):1601-6. discussion 1607–8. NRP. [pmid: 19853119].
Pennathur, Luketich JD, Heron DE, Schuchert MJ, Burton S, Abbas G, Gooding WE, Ferson PF, Ozhasoglu C, Gilbert S, Landreneau RJ, Christie NA. Stereotactic radiosurgery for the treatment of lung neoplasm: experience in 100 consecutive patients. Ann Thorac Surg. 2009;88(5):1594-600. discussion 1600. USD. [pmid: 19853118].
Pennathur, Luketich JD, Burton S, Abbas G, Heron DE, Fernando HC, Gooding WE, Ozhasoglu C, Ireland J, Landreneau RJ, Christie NA. Stereotactic radiosurgery for the treatment of lung neoplasm: initial experience. Ann Thorac Surg. 2007;83(5):1820-4. discussion 1824–5. USD. [pmid: 17462406].
Pergolizzi, Santacaterina A, Renzis CD, Settineri N, Gaeta M, Frosina P, Russi EG, Altavilla G. Older people with non small cell lung cancer in clinical stage IIIA and co-morbid conditions. Is curative irradiation feasible? Final results of a prospective study. Lung Cancer. 2002;37(2):201-6. NRP. [pmid: 12140143].
Pergolizzi, Settineri N, Maisano R, Santacaterina A, Faranda C, Russi E, Raffaele L, Adamo V. Curative radiotherapy (RT) using limited RT treatment fields in elderly patients with non-small cell lung cancer in clinical stage IIIA. Oncol Rep. 1997;4(5):961-5. NRP. [pmid: 21590176].
Pettersson, Nyman J, Johansson KA. Radiation-induced rib fractures after hypofractionated stereotactic body radiation therapy of non-small cell lung cancer: a dose- and volume-response analysis. Radiother Oncol. 2009;91(3):360-8. OPP. [pmid: 19410314].
Phernambucq, Biesma B, Smit EF, Paul MA, vd Tol A, Schramel FM, Bolhuis RJ, Postmus PE. Multicenter phase II trial of accelerated cisplatin and high-dose epirubicin followed by surgery or radiotherapy in patients with stage IIIa non-small-cell lung cancer with mediastinal lymph node involvement (N2-disease). Br J Cancer. 2006;95(4):470-4. NRP. [pmid: 16909132].
Phernambucq, Spoelstra FO, Paul MA, Senan S, Melissant CF, Postmus PE, Smit EF. Evaluation of a treatment strategy for optimising preoperative chemoradiotherapy in stage III non-small-cell lung cancer. Eur J Cardiothorac Surg. 2009;36(6):1052-7. NRP. [pmid: 19616442].
Phernambucq, Spoelstra FO, Verbakel WF, Postmus PE, Melissant CF, Maassen van den Brink KI, Frings V, van de Ven PM, Smit EF, Senan S. Outcomes of concurrent chemoradiotherapy in patients with stage III non-small-cell lung cancer and significant comorbidity. Ann Oncol. 2011;22(1):132-8. NRP. [pmid: 20595452].
Photodynamic therapy for palliation of locally advanced lung cancer. Oncology. 1999;13(5):608+613. NRD.
Pignon, Ruggieri S, Boutin C, Gouvernet J, Irisson M, Juin P, Astoul P. Alternating chemotherapy and accelerated split-course irradiation in locally advanced nonsmall cell lung carcinoma. Cancer. 1999;85(10):2144-50. NRP. [pmid: 10326692].
Pijls-Johannesma, Houben R, Boersma L, Grutters J, Seghers K, Lambin P, Wanders R, De Ruysscher D. High-dose radiotherapy or concurrent chemo-radiation in lung cancer patients only induces a temporary, reversible decline in QoL. Radiother Oncol. 2009;91(3):443-8. NRP. [pmid: 19297049].
Pisch, Berson AM, Malamud S, Beattie EJ, Harvey J, Vikram B. Chemoradiation in advanced nonsmall cell lung cancer. Int J Radiat Oncol Biol Phys. 1995;33(1):183-8. NRP. [pmid: 7642417].
Pisch, Harvey JC, Panigrahi N, Beattie EJ Jr. Iodine-125 volume implant in patients with medically unresectable stage I lung cancer. Endocurietherapy/Hyperthermia Oncology. 1996;12(3):165-170. NRI.
Pisch, Moskovitz T, Esik O, Homel P, Keller S. Concurrent paclitaxel-cisplatin and twice-a-day irradiation in stage IIIA and IIIB NSCLC shows improvement in local control and survival with acceptable hematologic toxicity. Pathol Oncol Res. 2002;8(3):163-9. NRP. [pmid: 12515995].
Pitz, Maas KW, Van Swieten HA, de la Riviere AB, Hofman P, Schramel FM. Surgery as part of combined modality treatment in stage IIIB non-small cell lung cancer. Ann Thorac Surg. 2002;74(1):164-9. NRP. [pmid: 12118751].
Planting, Helle P, Drings P, Dalesio O, Kirkpatrick A, McVie G, Giaccone G. A randomized study of high-dose split course radiotherapy preceded by high-dose chemotherapy versus high-dose radiotherapy only in locally advanced non-small-cell lung cancer. An EORTC Lung Cancer Cooperative Group trial. Ann Oncol. 1996;7(2):139-44. NRP. [pmid: 8777169].
Plataniotis, Kouvaris JR, Dardoufas C, Kouloulias V, Theofanopoulou MA, Vlahos L. A short radiotherapy course for locally advanced non-small cell lung cancer (NSCLC): effective palliation and patients' convenience. Lung Cancer. 2002;35(2):203-7. NRP. [pmid: 11804694].
Plumridge, Millward MJ, Rischin D, Macmanus MP, Wirth A, Michael M, Yuen K, Ball DL. Long-term survival following chemoradiation for inoperable non-small cell lung cancer. Med J Aust. 2008;189(10):557-9. NRP. [pmid: 19012553].
Pohl, Krajnik G, Malayeri R, Muller RM, Klepetko W, Eckersberger F, Schafer-Prokop C, Pokrajac B, Schmeikal S, Maier A, Ambrosch G, Woltsche M, Minar W, Pirker R. Induction chemotherapy with the TIP regimen (paclitaxel/ifosfamide/cisplatin) in stage III non-small cell lung cancer. Lung Cancer. 2006;54(1):63-7. NRP. [pmid: 16926060].
Pottgen, Eberhardt WE, Gauler T, Krbek T, Berkovic K, Jawad JA, Korfee S, Teschler H, Stamatis G, Stuschke M. Intensified high-dose chemoradiotherapy with induction chemotherapy in patients with locally advanced non-small-cell lung cancer-safety and toxicity results within a prospective trial. Int J Radiat Oncol Biol Phys. 2010;76(3):809-15. NRP. [pmid: 19427744].
Pottgen, Eberhardt W, Bildat S, Stuben G, Stamatis G, Hillejan L, Sohrab S, Teschler H, Seeber S, Sack H, Stuschke M. Induction chemotherapy followed by concurrent chemotherapy and definitive high-dose radiotherapy for patients with locally advanced non-small-cell lung cancer (stages IIIa/IIIb): a pilot phase I/II trial. Ann Oncol. 2002;13(3):403-11. NRP. [pmid: 11996471].
Pourel, Santelmo N, Naafa N, Serre A, Hilgers W, Mineur L, Molinari N, Reboul F. Concurrent cisplatin/etoposide plus 3D-conformal radiotherapy followed by surgery for stage IIB (superior sulcus T3N0)/III non-small cell lung cancer yields a high rate of pathological complete response. Eur J Cardiothorac Surg. 2008;33(5):829-36. NRP. [pmid: 18367406].
Pradier, Lederer K, Hille A, Weiss E, Christiansen H, Schmidberger H, Hess CF. Concurrent low-dose cisplatin and thoracic radiotherapy in patients with inoperable stage III non-small cell lung cancer: a phase II trial with special reference to the hemoglobin level as prognostic parameter. J Cancer Res Clin Oncol. 2005;131(4):261-9. NRP. [pmid: 15616830].
Pujol, Lafontaine T, Quantin X, Reme-Saumon M, Cupissol D, Khial F, Michel FB. Neoadjuvant etoposide, ifosfamide, and cisplatin followed by concomitant thoracic radiotherapy and continuous cisplatin infusion in stage IIIb non-small cell lung cancer. Chest. 1999;115(1):144-50. NRP. [pmid: 9925076].
Qiao, Xin L, Liu H. The combined therapy of carboplatin, fluorouracil and radiotherapy for moderate and advanced non-small cell lung cancer. 1999;22:536-7. FLA.
Qiao, Zhao YH, Zhao YB, Wang RZ. Clinical and dosimetric factors of radiation-induced esophageal injury: Radiation-induced esophageal toxicity. World Journal of Gastroenterology. 2005;11(17):2626-2629. NRP. [pmid: 15849822].
Quddus, Kerr GR, Price A, Gregor A. Long-term survival in patients with non-small cell lung cancer treated with palliative radiotherapy. Clin Oncol (R Coll Radiol). 2001;13(2):95-8. NRP. [pmid: 11373887].
Ranson, Davidson N, Nicolson M, Falk S, Carmichael J, Lopez P, Anderson H, Gustafson N, Jeynes A, Gallant G, Washington T, Thatcher N. Randomized trial of paclitaxel plus supportive care versus supportive care for patients with advanced non-small-cell lung cancer. J Natl Cancer Inst. 2000;92(13):1074-80. NRI. [pmid: 10880550].
Ratanatharathorn, Lorvidhaya V, Kraipiboon P, Sirachainan E, Maoleekoonpairoj S, Phromratanapongse P, Cheirsilpa A, Tangkaratt S, Srimuninnimit V, Pattaranutaporn P, Lertsanguansinchai P. Phase II study of concurrent chemoradiotherapy for inoperable (bulky) stage III (A/B) non-small cell lung cancer (NSCLC): a preliminary report. J Med Assoc Thai. 2000;83(1):85-92. NRP. [pmid: 10710874].
Ratanatharathorn, Lorvidhaya V, Maoleekoonpairoj S, Phromratanapongse P, Sirilerttrakul S, Kraipiboon P, Cheirsilpa A, Tangkaratt S, Srimuninnimit V, Pattaranutaporn P. Phase II trial of paclitaxel, carboplatin, and concurrent radiation therapy for locally advanced non-small-cell lung cancer. Lung Cancer. 2001;31(2–3):257-65. NRP. [pmid: 11165405].
Rathmann, Leopold KA, Rigas JR. Daily paclitaxel and thoracic radiation therapy for non-small cell lung cancer: preliminary results. Semin Radiat Oncol. 1999;9(2 Suppl 1):130-5. NRP. [pmid: 10210552].
Razi, Lebovics RS, Schwartz G, Sancheti M, Belsley S, Connery CP, Bhora FY. Timely airway stenting improves survival in patients with malignant central airway obstruction. Annals of Thoracic Surgery. 2010;90(4):1088-1093. USD. [pmid: 20868793].
Ready, Janne PA, Bogart J, Dipetrillo T, Garst J, Graziano S, Gu L, Wang X, Green MR, Vokes EE. Chemoradiotherapy and gefitinib in stage III non-small cell lung cancer with epidermal growth factor receptor and KRAS mutation analysis: cancer and leukemia group B (CALEB) 30106, a CALGB-stratified phase II trial. J Thorac Oncol. 2010;5(9):1382-90. NRP. [pmid: 20686428].
Reboul, Brewer Y, Vincent P, Chauvet B, Faure CF, Taulelle M. Concurrent cisplatin, etoposide, and radiotherapy for unresectable stage III nonsmall cell lung cancer: a phase II study. Int J Radiat Oncol Biol Phys. 1996;35(2):343-50. NRP. [pmid: 8635942].
Reckzeh, Merte H, Pfluger KH, Pfab R, Wolf M, Havemann K. Severe lymphocytopenia and interstitial pneumonia in patients treated with paclitaxel and simultaneous radiotherapy for non-small-cell lung cancer. J Clin Oncol. 1996;14(4):1071-6. NRP. [pmid: 8648359].
Reguart, Vinolas N, Casas F, Gimferrer JM, Agusti C, Molina R, Martin-Richard M, Sanchez-Reyes A, Gascon P. Integrating concurrent navelbine and cisplatin to hyperfractionated radiotherapy in locally advanced non-small cell lung cancer patients treated with induction and consolidation chemotherapy: feasibility and activity results. Lung Cancer. 2004;45(1):67-75. NRP. [pmid: 15196736].
Reinfuss, Mucha-Malecka A, Walasek T, Blecharz P, Jakubowicz J, Skotnicki P, Kowalska T. Palliative thoracic radiotherapy in non-small cell lung cancer. An analysis of 1250 patients. Palliation of symptoms, tolerance and toxicity. Lung Cancer. 2011;71(3):344-9. NRP. [pmid: 20674068].
Reinfuss, Skolyszewski J, Kowalska T, Glinski B, Dymek P, Walasek T, Kojs Z, Skotnicki P, Michalak A. Evaluation of efficacy of combined chemoradiotherapy in locoregional advanced, inoperable Non-Small Cell Lung Cancer (clinical randomized trial). Nowotwory. 2005;55(3):200-206. NRP.
Rengan, Rosenzweig KE, Venkatraman E, Koutcher LA, Fox JL, Nayak R, Amols H, Yorke E, Jackson A, Ling CC, Leibel SA. Improved local control with higher doses of radiation in large-volume stage III non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2004;60(3):741-7. NRP. [pmid: 15465190].
Rice, Adelstein DJ, Koka A, Tefft M, Kirby TJ, Van Kirk MA, Taylor ME, Olencki TE, Peereboom D, Budd GT. Accelerated induction therapy and resection for poor prognosis stage III non-small cell lung cancer. Ann Thorac Surg. 1995;60(3):586-91. discussion 591–2. NRP. [pmid: 7677484].
Rice, Adelstein DJ, Ciezki JP, Becker ME, Rybicki LA, Farver CF, Larto MA, Blackstone EH. Short-course induction chemoradiotherapy with paclitaxel for stage III non-small-cell lung cancer. Ann Thorac Surg. 1998;66(6):1909-14. NRP. [pmid: 9930467].
Robert, Spencer SA, Childs HA 3rd, Zhang R, Meredith RF, Wheeler RH, Hawkins MH, Carey D. Concurrent chemoradiation therapy with cisplatin and paclitaxel for locally advanced non-small cell lung cancer: long-term follow-up of a phase I trial. Lung Cancer. 2002;37(2):189-99. NRP. [pmid: 12140142].
Rojas, Lyn BE, Wilson EM, Williams FJ, Shah N, Dickson J, Saunders MI. Toxicity and outcome of a phase II trial of taxane-based neoadjuvant chemotherapy and 3-dimensional, conformal, accelerated radiotherapy in locally advanced nonsmall cell lung cancer. Cancer. 2006;107(6):1321-30. NRP. [pmid: 16902985].
Rosenman, Halle JS, Socinski MA, Deschesne K, Moore DT, Johnson H, Fraser R, Morris DE. High-dose conformal radiotherapy for treatment of stage IIIA/IIIB non-small-cell lung cancer: technical issues and results of a phase I/II trial. Int J Radiat Oncol Biol Phys. 2002;54(2):348-56. NRP. [pmid: 12243807].
Rosenthal, Fuller CD, Machtay M, Algazy KM, Meyer DM, Kaiser LR, Yardley DA, Loiacano ME, Carbone DP. Phase I study of Paclitaxel given by seven-week continuous infusion concurrent with radiation therapy for locally advanced non-small cell lung cancer. J Thorac Oncol. 2006;1(1):38-45. NRP. [pmid: 17409825].
Rosenzweig, Mychalczak B, Fuks Z, Hanley J, Burman C, Ling CC, Armstrong J, Ginsberg R, Kris MG, Raben A, Leibel S. Final report of the 70.2-Gy and 75.6-Gy dose levels of a phase I dose escalation study using three-dimensional conformal radiotherapy in the treatment of inoperable non-small cell lung cancer. Cancer J. 2000;6(2):82-7. NRP. [pmid: 11069224].
Rosenzweig, Fox JL, Yorke E, Amols H, Jackson A, Rusch V, Kris MG, Ling CC, Leibel SA. Results of a phase I dose-escalation study using three-dimensional conformal radiotherapy in the treatment of inoperable nonsmall cell lung carcinoma. Cancer. 2005;103(10):2118-27. USD. [pmid: 15830346].
Rosenzweig, Dladla N, Schindelheim R, Sim SE, Braban LE, Venkataraman ES, Leibel SA. Three-dimensional conformal radiation therapy (3D-CRT) for early-stage non-small-cell lung cancer. Clin Lung Cancer. 2001;3(2):141-4. NRP. [pmid: 14659030].
Rosenzweig, Sim SE, Mychalczak B, Braban LE, Schindelheim R, Leibel SA. Elective nodal irradiation in the treatment of non-small-cell lung cancer with three-dimensional conformal radiation therapy. Int J Radiat Oncol Biol Phys. 2001;50(3):681-5. NRP. [pmid: 11395236].
Rosenzweig, Sura S, Jackson A, Yorke E. Involved-field radiation therapy for inoperable non small-cell lung cancer. J Clin Oncol. 2007;25(35):5557-61. NRO. [pmid: 17984185].
Rossi, Graziano F, Ugolini M, Dennetta D, Alessandroni P, Catalano V, Giordani P, Fedeli SL, Fedeli A, Catalano G. Weekly docetaxel as second-line therapy in non-small cell lung cancer: a phase II study. Tumori. 2004;90(1):50-3. NRP. [pmid: 15143972].
Rossi, Dore R, Cascina A, Vespro V, Garbagnati F, Rosa L, Ravetta V, Azzaretti A, Di Tolla P, Orlandoni G, Pozzi E. Percutaneous computed tomography-guide radiofrequency thermal ablation of small unresectable lung tumours. European Respiratory Journal. 2006;27(3):556-563. USD. [pmid: 16507856].
Roszkowski, Pluzanska A, Krzakowski M, Smith AP, Saigi E, Aasebo U, Parisi A, Pham N, Olivares Tran R, Berille J. A multicenter, randomized, phase III study of docetaxel plus best supportive care versus best supportive care in chemotherapy-naive patients with metastatic or non-resectable localized non-small cell lung cancer (NSCLC). Lung Cancer. 2000;27(3):145-157. NRI. [pmid: 10699688].
Rothschild, Bucher SE, Bernier J, Aebersold DM, Zouhair A, Ries G, Lombrieser N, Lippuner T, Lutolf UM, Glanzmann C, Ciernik IF. Gefitinib in combination with irradiation with or without cisplatin in patients with inoperable stage III non-small cell lung cancer: a phase I trial. Int J Radiat Oncol Biol Phys. 2011;80(1):126-32. NRP. [pmid: 20646869].
Rowell, Williams CJ. Radical radiotherapy for stage I/II non-small cell lung cancer in patients not sufficiently fit for or declining surgery (medically inoperable). Cochrane Database Syst Rev. 2001;2:CD002935. NRD. [pmid: 11406051].
Rusch, Giroux DJ, Kraut MJ, Crowley J, Hazuka M, Johnson D, Goldberg M, Detterbeck F, Shepherd F, Burkes R, Winton T, Deschamps C, Livingston R, Gandara D. Induction chemoradiation and surgical resection for non-small cell lung carcinomas of the superior sulcus: Initial results of Southwest Oncology Group Trial 9416 (Intergroup Trial 0160). J Thorac Cardiovasc Surg. 2001;121(3):472-83. NRP. [pmid: 11241082].
Rusch, Giroux DJ, Kraut MJ, Crowley J, Hazuka M, Winton T, Johnson DH, Shulman L, Shepherd F, Deschamps C, Livingston RB, Gandara D. Induction chemoradiation and surgical resection for superior sulcus non-small-cell lung carcinomas: long-term results of Southwest Oncology Group Trial 9416 (Intergroup Trial 0160). J Clin Oncol. 2007;25(3):313-8. NRP. [pmid: 17235046].
Rusthoven, Hammerman SF, Kavanagh BD, Birtwhistle MJ, Stares M, Camidge DR. Is there a role for consolidative stereotactic body radiation therapy following first-line systemic therapy for metastatic lung cancer? A patterns-of-failure analysis. Acta Oncol. 2009;48(4):578-83. NRP. [pmid: 19373699].
Rusu, Ciuleanu TE, Cernea D, Pelau D, Gaal V, Cebotaru C, Guttman T, Todor N, Ghilezan N. Concurrent chemoradiotherapy with vinorelbine and a platinum compound followed by consolidation chemotherapy for unresectable stage III non-small cell lung cancer: preliminary results of a phase II study. J BUON. 2007;12(1):33-9. NRP. [pmid: 17436399].
Rusu, Ciuleanu TE, Todor N, Guttman T, Bogdan V, Cernea V. Dose escalation using 3DCRT in concurrent setting with vinorelbine and a platinum compound in locally advanced NSCLC. Radiotherapy and Oncology. 2011;99:S109-S110. NRD.
Saito, Hayakawa K, Nakayama Y, Katano S, Furuta M, Ishikawa H, Nasu S, Mitsuhashi N, Niibe H. Radiation therapy for stage III non-small cell lung cancer invading chest wall. Lung Cancer. 1997;18(2):171-8. NRP. [pmid: 9316008].
Saito, Mitsuhashi N, Hayakawa K, Nakayama Y, Kazumoto T, Furuta M, Yamakawa M, Akimoto T, Sakurai H, Takahashi T, Niibe H. Prognostic value of pretreatment serum carcinoembryonic antigen and squamous cell carcinoma antigen levels for patients with stage I–III non- small cell lung cancer treated with radiation therapy alone. International Journal of Clinical Oncology. 1998;3(1):27-30. NRD.
Saitoh, Saito Y, Kazumoto T, Kudo S, Yoshida D, Ichikawa A, Sakai H, Kurimoto F, Kato S, Shibuya K. Concurrent Chemoradiotherapy Followed by Consolidation Chemotherapy with Bi-Weekly Docetaxel and Carboplatin for Stage III Unresectable, Non-Small-Cell Lung Cancer: Clinical Application of a Protocol Used in a Previous Phase II Study. Int J Radiat Oncol Biol Phys. 2011. NRP.
Sakai, Yoneda S, Kobayashi K, Komagata H, Kosaihira S, Kazumoto T, Saito Y. Phase II study of bi-weekly docetaxel and carboplatin with concurrent thoracic radiation therapy followed by consolidation chemotherapy with docetaxel plus carboplatin for stage III unresectable non-small cell lung cancer. Lung Cancer. 2004;43(2):195-201. NRP. [pmid: 14739040].
Sakai, Matsumoto Y, Nishio M, Hirota S, Yamada S, Hirokawa Y, Inakoshi H. Combined chemoradiotherapy with daily low-dose cisplatin in stage III non-small cell lung cancer - An interim report. Journal of JASTRO. 2001;13(2):103-106. NRP.
Sakakibara-Konishi, Oizumi S, Kinoshita I, Shinagawa N, Kikuchi J, Kato M, Inoue T, Katoh N, Onimaru R, Shirato H, Dosaka-Akita H, Nishimura M. Phase I study of concurrent real-time tumor-tracking thoracic radiation therapy with paclitaxel and carboplatin in locally advanced non-small cell lung cancer. Lung Cancer. 2011;74(2):248-52. NRP. [pmid: 21397973].
Salama, Stinchcombe TE, Gu L, Wang X, Morano K, Bogart JA, Crawford JC, Socinski MA, Blackstock AW, Vokes EE. Pulmonary toxicity in Stage III non-small cell lung cancer patients treated with high-dose (74 Gy) 3-dimensional conformal thoracic radiotherapy and concurrent chemotherapy following induction chemotherapy: a secondary analysis of Cancer and Leukemia Group B (CALGB) trial 30105. Int J Radiat Oncol Biol Phys. 2011;81(4):e269-74. NRP. [pmid: 21477940].
Salazar, Sandhu TS, Lattin PB, Chang JH, Lee CK, Groshko GA, Lattin CJ. Once-weekly, high-dose stereotactic body radiotherapy for lung cancer: 6-year analysis of 60 early-stage, 42 locally advanced, and 7 metastatic lung cancers. Int J Radiat Oncol Biol Phys. 2008;72(3):707-15. NRP. [pmid: 18455322].
San Jose, Arnaiz MD, Lucas A, Navarro V, Serrano G, Zaderazjko M, Jeremic B, Guedea F. Radiation therapy alone in elderly with early stage non-small cell lung cancer. Lung Cancer. 2006;52(2):149-54. USD. [pmid: 16516336].
Sandhu, Messer K, Fuster MM, Ahmad E, Pu M, Bazhenova L, Rose M, Seagren S. Definitive radiation therapy for stage I non-small-cell lung carcinoma: institutional experience with contemporary conformal planning. Clin Lung Cancer. 2009;10(6):433-7. USD. [pmid: 19900862].
Sangha, Prestwich R, Lilley J, Needham A, Summers H, Stuart R, Turner R, Bond M, Snee M, Franks KN. Feasibility and early outcomes of stereotactic radiotherapy in early lung cancer at St James's Institute of Oncology. Clinical Oncology. 2011;23(3):S51-S52. NRD.
Santo, Pedersini R, Pasini F, Terzi A, Pari F, Cartei G, Sibau A, Molino A, Maiorino A, Panza N, Oletti MV, Maluta S, Calabro F, Cetto GL. A phase II study of induction chemotherapy with gemcitabine (G) and cisplatin (P) in locally advanced non-small cell lung cancer: interim analysis. Lung Cancer. 2001;34(Suppl 4()):S15-20. NRP. [pmid: 11742697].
Sarihan, Darendeliler E, Kizir A, Tuncel N, Oral EN, Karadeniz A, Bilge N. A phase II trial, feasibility of combination of daily cisplatinum and accelerated radiotherapy via concomitant boost in stage III non-small cell lung cancer. Lung Cancer. 1998;20(1):37-46. NRP. [pmid: 9699186].
Sarihan, Kayisogullari U, Ercan I, Engin K. Randomized phase 2 study of radiotherapy alone versus radiotherapy with paclitaxel in non-small cell lung cancer. J Int Med Res. 2004;32(4):375-83. NRP. [pmid: 15303768].
Sasaki, Komaki R, Macapinlac H, Erasmus J, Allen P, Forster K, Putnam JB, Herbst RS, Moran CA, Podoloff DA, Roth JA, Cox JD. [18F]fluorodeoxyglucose uptake by positron emission tomography predicts outcome of non-small-cell lung cancer. J Clin Oncol. 2005;23(6):1136-43. NRI. [pmid: 15718309].
Satoh, Ohara K, Fuji H, Ishikawa H, Yamashita YT, Kamma H, Ohtsuka M, Hasegawa S. Use of daily low-dose carboplatin in radiotherapy for non-small cell lung cancer. Anticancer Res. 1998;18(6B):4625-7. NRP. [pmid: 9891530].
Saunders, Rojas A, Lyn BE, Wilson E, Phillips H. Dose-escalation with CHARTWEL (continuous hyperfractionated accelerated radiotherapy week-end less) combined with neo-adjuvant chemotherapy in the treatment of locally advanced non-small cell lung cancer. Clin Oncol (R Coll Radiol). 2002;14(5):352-60. NRP. [pmid: 12555873].
Saunders, Rojas A, Lyn BE, Pigott K, Powell M, Goodchild K, Hoskin PJ, Phillips H, Verma N. Experience with dose escalation using CHARTWEL (continuous hyperfractionated accelerated radiotherapy weekend less) in non-small-cell lung cancer. Br J Cancer. 1998;78(10):1323-8. NRI. [pmid: 9823973].
Saunders, Dische S, Barrett A, Harvey A, Gibson D, Parmar M. Continuous hyperfractionated accelerated radiotherapy (CHART) versus conventional radiotherapy in non-small-cell lung cancer: a randomised multicentre trial. CHART Steering Committee. Lancet. 1997;350(9072):161-5. NRP. [pmid: 9250182].
Saunders, Dische S, Barrett A, Harvey A, Griffiths G, Palmar M. Continuous, hyperfractionated, accelerated radiotherapy (CHART) versus conventional radiotherapy in non-small cell lung cancer: mature data from the randomised multicentre trial. CHART Steering committee. Radiother Oncol. 1999;52(2):137-48. NRI. [pmid: 10577699].
Sause, Scott C, Taylor S, Johnson D, Livingston R, Komaki R, Emami B, Curran WJ, Byhardt RW, Turrisi AT, et al. Radiation Therapy Oncology Group (RTOG) 88-08 and Eastern Cooperative Oncology Group (ECOG) 4588: preliminary results of a phase III trial in regionally advanced, unresectable non-small-cell lung cancer. J Natl Cancer Inst. 1995;87(3):198-205. NRI. [pmid: 7707407].
Sause, Kolesar P, Taylor SI, Johnson D, Livingston R, Komaki R, Emami B, Curran W Jr, Byhardt R, Dar AR, Turrisi A 3rd. Final results of phase III trial in regionally advanced unresectable non-small cell lung cancer: Radiation Therapy Oncology Group, Eastern Cooperative Oncology Group, and Southwest Oncology Group. Chest. 2000;117(2):358-64. NRP. [pmid: 10669675].
Saynak, Aksu G, Fayda M, Kaytan E, Oral E, Gurocak S, Kizir A, Karadeniz A. The results of concomitant and sequential chemoradiotherapy with cisplatin and etoposide in patients with locally advanced non-small cell lung cancer. J BUON. 2005;10(2):213-8. NRP. [pmid: 17343331].
Scagliotti, Szczesna A, Ramlau R, Cardenal F, Mattson K, Van Zandwijk N, Price A, Lebeau B, Debus J, Manegold C. Docetaxel-based induction therapy prior to radiotherapy with or without docetaxel for non-small-cell lung cancer. Br J Cancer. 2006;94(10):1375-82. NRP. [pmid: 16641904].
Scagliotti, Ricardi U, Crino L, Maranzano E, De Marinis F, Morandi MG, Meacci L, Marangolo M, Emiliani E, Rosti G, Figoli F, Bolzicco G, Masiero P, Gentile A, Tonato M. Phase II study of intensive chemotherapy with carboplatin, ifosfamide and etoposide plus recombinant human granulocyte colony-stimulating factor and sequential radiotherapy in locally advanced, unresectable non-small-cell lung cancer. Cancer Chemother Pharmacol. 1996;38(6):561-5. NRP. [pmid: 8823499].
Scarda, Confalonieri M, Baghiris C, Binato S, Mazzarotto R, Palamidese A, Zuin R, Fantoni U. Out-patient high-dose-rate endobronchial brachytherapy for palliation of lung cancer: an observational study. Monaldi Arch Chest Dis. 2007;67(3):128-34. USD. [pmid: 18018751].
Schaafsma, Coy P. Response of global quality of life to high-dose palliative radiotherapy for non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2000;47(3):691-701. NRD. [pmid: 10837953].
Schallier, Neyns B, Fontaine C, Steene JV, De Mey J, Meysman M, De Greve J. A novel triplet regimen with paclitaxel, carboplatin and gemcitabine (PACCAGE) as induction chemotherapy for locally advanced unresectable non small cell lung cancer (NSCLC). Lung Cancer. 2007;56(2):247-54. NRP. [pmid: 17337086].
Schallier, Bral S, Ilsen B, Neyns B, Fontaine C, Decoster L, De Mey J, Meysman M, De Greve J. Final overall results of a study with a novel triplet induction chemotherapy regimen (PACCAGE) followed by consolidation radiotherapy in locally advanced inoperable non-small cell lung cancer (NSCLC). J Thorac Oncol. 2009;4(6):728-35. NRP. [pmid: 19404217].
Schild, Stella PJ, Geyer SM, Bonner JA, Marks RS, McGinnis WL, Goetz SP, Kuross SA, Mailliard JA, Kugler JW, Schaefer PL, Jett JR. Phase III trial comparing chemotherapy plus once-daily or twice-daily radiotherapy in Stage III non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2002;54(2):370-8. NRP. [pmid: 12243810].
Schild, Stella PJ, Geyer SM, Bonner JA, McGinnis WL, Mailliard JA, Brindle J, Jatoi A, Jett JR. The outcome of combined-modality therapy for stage III non-small-cell lung cancer in the elderly. J Clin Oncol. 2003;21(17):3201-6. NRP. [pmid: 12874270].
Schild, Mandrekar SJ, Jatoi A, McGinnis WL, Stella PJ, Deming RL, Jett JR, Garces YI, Allen KL, Adjei AA. The value of combined-modality therapy in elderly patients with stage III nonsmall cell lung cancer. Cancer. 2007;110(2):363-8. NRP. [pmid: 17542000].
Schild, Wong WW, Vora SA, Halyard MY, Wheeler RH. Phase I study of hyperfractionated accelerated radiotherapy and escalating doses of daily cisplatin for patients with locally advanced non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2002;54(3):729-34. NRP. [pmid: 12377324].
Schild, Wong WW, Vora SA, Halyard MY, Northfelt DW, Kogut HL, Wheeler RH. The long-term results of a pilot study of three times a day radiotherapy and escalating doses of daily cisplatin for locally advanced non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2005;62(5):1432-7. NRP. [pmid: 16029804].
Schilder, Goldberg M, Millenson MM, Movsas B, Rogatko A, Rogers B, Langer CJ. Phase II trial of induction high-dose chemotherapy followed by surgical resection and radiation therapy for patients with marginally resectable non-small cell carcinoma of the lung. Lung Cancer. 2000;27(1):37-45. NRP. [pmid: 10672782].
Schuette, Krzakowski MJ, Massuti B, Otterson GA, Lizambri R, Wei H, Berger DP, Chen Y. Randomized Phase II Study of Palifermin for Reducing Dysphagia in Patients Receiving Concurrent Chemoradiotherapy for Locally Advanced Unresectable Non-small Cell Lung Cancer. J Thorac Oncol. 2011. NRP.
Schuster-Uitterhoeve, van de Vaart PJ, Schaake-Koning CC, Benraadt J, Koolen MG, Gonzalez D, Bartelink Gonzalez H. Feasibility of escalating daily doses of cisplatin in combination with accelerated radiotherapy in non-small cell lung cancer. Eur J Cancer. 1996;32A(8):1314-9. NRP. [pmid: 8869092].
Schwarzenberger, Fariss A, Linares L, Nedzi L, Salazar OM. Dose escalation of once weekly oral vinorelbine concurrent with weekly split dose hypofractionated chest radiation for palliation of advanced non-small cell lung cancer: a phase I/II study. Am J Med Sci. 2011;341(6):454-9. NRP. [pmid: 21613934].
Scinto, Ferraresi V, Milella M, Tucci E, Santomaggio C, Pasquali-Lasagni R, Del Vecchio MR, Campioni N, Nardi M, Cognetti F. Ifosfamide, cisplatin and etoposide combination in locally advanced inoperable non-small-cell lung cancer: a phase II study. Br J Cancer. 1999;81(6):1031-6. NRP. [pmid: 10576661].
Scorsetti, Navarria P, Mancosu P, Alongi F, Castiglioni S, Cavina R, Cozzi L, Fogliata A, Pentimalli S, Tozzi A, Santoro A. Large volume unresectable locally advanced non-small cell lung cancer: acute toxicity and initial outcome results with rapid arc. Radiat Oncol. 2010;5:94. NRP. [pmid: 20950469].
Sculier, Lafitte JJ, Berghmans T, Van Houtte P, Lecomte J, Thiriaux J, Efremidis A, Koumakis G, Giner V, Richez M, Corhay JL, Wackenier P, Lothaire P, Paesmans M, Mommen P, Ninane V. A phase III randomised study comparing two different dose-intensity regimens as induction chemotherapy followed by thoracic irradiation in patients with advanced locoregional non-small-cell lung cancer. Ann Oncol. 2004;15(3):399-409. NRI. [pmid: 14998841].
Sculier, Paesmans M, Lafitte JJ, Baumohl J, Thiriaux J, van Cutsem O, Recloux P, Bureau G, Berchier MC, Zacharias C, Mommen P, Bosschaerts T, Berghmans T, van Houtte P, Ninane V, Klastersky J. A randomised phase III trial comparing consolidation treatment with further chemotherapy to chest irradiation in patients with initially unresectable locoregional non-small-cell lung cancer responding to induction chemotherapy. European Lung Cancer Working Party. Ann Oncol. 1999;10(3):295-303. NRD. [pmid: 10355573].
Segawa, Ueoka H, Kiura K, Kamei H, Tabata M, Sakae K, Hiraki Y, Kawahara S, Eguchi K, Hiraki S, Harada M. A phase II study of cisplatin and 5-fluorouracil with concurrent hyperfractionated thoracic radiation for locally advanced non-small-cell lung cancer: a preliminary report from the Okayama Lung Cancer Study Group. Br J Cancer. 2000;82(1):104-11. NRP. [pmid: 10638975].
Segawa, Kiura K, Takigawa N, Kamei H, Harita S, Hiraki S, Watanabe Y, Sugimoto K, Shibayama T, Yonei T, Ueoka H, Takemoto M, Kanazawa S, Takata I, Nogami N, Hotta K, Hiraki A, Tabata M, Matsuo K, Tanimoto M. Phase III trial comparing docetaxel and cisplatin combination chemotherapy with mitomycin, vindesine, and cisplatin combination chemotherapy with concurrent thoracic radiotherapy in locally advanced non-small-cell lung cancer: OLCSG 0007. J Clin Oncol. 2010;28(20):3299-306. NRP. [pmid: 20530281].
Seiwert, Connell PP, Mauer AM, Hoffman PC, George CM, Szeto L, Salgia R, Posther KE, Nguyen B, Haraf DJ, Vokes EE. A phase I study of pemetrexed, carboplatin, and concurrent radiotherapy in patients with locally advanced or metastatic non-small cell lung or esophageal cancer. Clin Cancer Res. 2007;13(2 Pt 1):515-22. NRP. [pmid: 17255273].
Sejpal, Komaki R, Tsao A, Chang JY, Liao Z, Wei X, Allen PK, Lu C, Gillin M, Cox JD. Early findings on toxicity of proton beam therapy with concurrent chemotherapy for nonsmall cell lung cancer. Cancer. 2011;117(13):3004-13. NRP. [pmid: 21264827].
Seki, Eguchi K, Katakami N, Kunikane H, Takeda K, Takayama K, Sawa T, Saito H, Harada M, Ohashi Y. Incidence of bone metastases and skeletal-related events in patients with advanced lung cancer - Results of a multicenter, prospective, cohort study (CSP-HOR13). European Journal of Cancer. 2011;47:S638. NRD.
Sekine, Nokihara H, Sumi M, Saijo N, Nishiwaki Y, Ishikura S, Mori K, Tsukiyama I, Tamura T. Docetaxel consolidation therapy following cisplatin, vinorelbine, and concurrent thoracic radiotherapy in patients with unresectable stage III non-small cell lung cancer. J Thorac Oncol. 2006;1(8):810-5. NRP. [pmid: 17409964].
Sekine, Kubota K, Niho S, Sumi M, Nihei K, Sekiguchi R, Funai J, Enatsu S, Ohe Y, Tamura T. Phase I trial of pemetrexed and cisplatin combination chemotherapy with concurrent thoracic radiotherapy in Japanese patients with locally advanced non-small-cell lung cancer. European Journal of Cancer. 2011;47:S610. NRD.
Sekine, Noda K, Oshita F, Yamada K, Tanaka M, Yamashita K, Nokihara H, Yamamoto N, Kunitoh H, Ohe Y, Tamura T, Kodama T, Sumi M, Saijo N. Phase I study of cisplatin, vinorelbine, and concurrent thoracic radiotherapy for unresectable stage III non-small cell lung cancer. Cancer Sci. 2004;95(8):691-5. NRP. [pmid: 15298734].
Sekine, Sumi M, Ito Y, Tanai C, Nokihara H, Yamamoto N, Kunitoh H, Ohe Y, Tamura T. Gender difference in treatment outcomes in patients with stage III non-small cell lung cancer receiving concurrent chemoradiotherapy. Jpn J Clin Oncol. 2009;39(11):707-12. NRP. [pmid: 19692418].
Sekine, Sumi M, Ito Y, Horinouchi H, Nokihara H, Yamamoto N, Kunitoh H, Ohe Y, Kubota K, Tamura T. Phase I Study of Concurrent High-Dose Three-Dimensional Conformal Radiotherapy with Chemotherapy Using Cisplatin and Vinorelbine for Unresectable Stage III Non-Small-Cell Lung Cancer. Int J Radiat Oncol Biol Phys. 2011. NRP.
Sekine, Sumi M, Ito Y, Kato T, Fujisaka Y, Nokihara H, Yamamoto N, Kunitoh H, Ohe Y, Tamura T. Phase I study of cisplatin analogue nedaplatin, paclitaxel, and thoracic radiotherapy for unresectable stage III non-small cell lung cancer. Jpn J Clin Oncol. 2007;37(3):175-80. NRP. [pmid: 17452427].
Sekine, Nishiwaki Y, Ogino T, Yokoyama A, Saito M, Mori K, Tsukiyama I, Tsuchiya S, Hayakawa K, Yoshimura K, Ishizuka N, Saijo N. Phase II study of twice-daily high-dose thoracic radiotherapy alternating with cisplatin and vindesine for unresectable stage III non-small-cell lung cancer: Japan Clinical Oncology Group Study 9306. J Clin Oncol. 2002;20(3):797-803. NRP. [pmid: 11821463].
Semik, Riesenbeck D, Linder A, Schmid C, Hoffknecht P, Heinecke A, Scheld H, Thomas M. Preoperative chemotherapy with and without additional radiochemotherapy: benefit and risk for surgery of stage III non-small cell lung cancer. Eur J Cardiothorac Surg. 2004;26(6):1205-1210. NRP. [pmid: 15678591].
Semrau, Bier A, Thierbach U, Virchow C, Ketterer P, Fietkau R. Concurrent radiochemotherapy with vinorelbine plus cisplatin or carboplatin in patients with locally advanced non-small-cell lung cancer (NSCLC) and an increased risk of treatment complications. Preliminary results. Strahlenther Onkol. 2003;179(12):823-31. NRP. [pmid: 14652671].
Semrau, Bier A, Thierbach U, Virchow C, Ketterer P, Klautke G, Fietkau R. 6-year experience of concurrent radiochemotherapy with vinorelbine plus a platinum compound in multimorbid or aged patients with inoperable non-small cell lung cancer. Strahlenther Onkol. 2007;183(1):30-5. NRI. [pmid: 17225943].
Sen, Saglam EK, Toker A, Dilege S, Kizir A, Oral EN, Saip P, Sakallioglu B, Topuz E, Aydiner A. Weekly docetaxel and cisplatin with concomitant radiotherapy in addition to surgery and/or consolidation chemotherapy in stage III non-small cell lung cancer. Cancer Chemother Pharmacol. 2011;68(6):1497-505. NRP. [pmid: 21499895].
Senan, Lagerwaard FJ. In regard to Rosenman et al., high-dose conformal radiotherapy for treatment of stage III A/B non-small-cell lung cancer: technical issues and results of a phase I/II trial. IJROBP 2002; 54:348–356. Int J Radiat Oncol Biol Phys. 2003;55(5):1458-9. author reply 1459–60. NRD. [pmid: 12654460].
Senan, Cardenal F, Vansteenkiste J, Stigt J, Akyol F, De Neve W, Bakker J, Dupont JM, Scagliotti GV, Ricardi U, van Meerbeeck JP. A randomized phase II study comparing induction or consolidation chemotherapy with cisplatin-docetaxel, plus radical concurrent chemoradiotherapy with cisplatin-docetaxel, in patients with unresectable locally advanced non-small-cell lung cancer. Ann Oncol. 2011;22(3):553-8. NRP. [pmid: 20696676].
Senkus-Konefka, Dziadziuszko R, Bednaruk-Mlynski E, Pliszka A, Kubrak J, Lewandowska A, Malachowski K, Wierzchowski M, Matecka-Nowak M, Jassem J. A prospective, randomised study to compare two palliative radiotherapy schedules for non-small-cell lung cancer (NSCLC). Br J Cancer. 2005;92(6):1038-45. NRP. [pmid: 15770205].
Senzer. A phase III randomized evaluation of amifostine in stage IIIA/IIIB non-small cell lung cancer patients receiving concurrent carboplatin, paclitaxel, and radiation therapy followed by gemcitabine and cisplatin intensification: preliminary findings. Semin Oncol. 2002;29(6 Suppl 19):38-41. NRP. [pmid: 12577242].
Seung, Ross HJ. Phase II trial of combined modality therapy with concurrent topotecan plus radiotherapy followed by consolidation chemotherapy for unresectable stage III and selected stage IV non-small-lung cancer. Int J Radiat Oncol Biol Phys. 2009;73(3):802-9. NRP. [pmid: 18762390].
Sharma, Rath GK, Thulkar S, Bahl A, Pandit S, Julka PK. Computerized tomography-guided percutaneous high-dose-rate interstitial brachytherapy for malignant lung lesions. Journal of Cancer Research and Therapeutics. 2011;7(2):174-179. NRI. [pmid: 21768706].
Sharma, Sharma R, Bhowmik KT. Sequential chemoradiotherapy versus radiotherapy in the management of locally advanced non-small-cell lung cancer. Adv Ther. 2003;20(1):14-9. NRP. [pmid: 12772814].
Shaw, Deming RL, Creagan ET, Nair S, Su JQ, Levitt R, Steen PD, Wiesenfeld M, Mailliard JA. Pilot study of human recombinant interferon gamma and accelerated hyperfractionated thoracic radiation therapy in patients with unresectable stage IIIA/B nonsmall cell lung cancer. Int J Radiat Oncol Biol Phys. 1995;31(4):827-31. NRP. [pmid: 7860395].
Shen, Denittis A, Werner-Wasik M, Axelrod R, Gilman P, Meyer T, Treat J, Curran WJ, Machtay M. Phase i study of 'dose-dense' pemetrexed plus carboplatin/radiotherapy for locally advanced non-small cell lung carcinoma. Radiat Oncol. 2011;6:17. NRP. [pmid: 21324160].
Shepherd, Johnston MR, Payne D, Burkes R, Deslauriers J, Cormier Y, de Bedoya LD, Ottaway J, James K, Zee B. Randomized study of chemotherapy and surgery versus radiotherapy for stage IIIA non-small-cell lung cancer: a National Cancer Institute of Canada Clinical Trials Group Study. Br J Cancer. 1998;78(5):683-5. NRP. [pmid: 9744511].
Shi, Zhu G, Yu R, Wang Y, Xia T. A randomized phase I/II trial to compare weekly usage with triple weekly usage of paclitaxel in concurrent radiochemotherapy for patients with locally advanced non-small cell lung cancer. 2011;14:227-32. FLA.
Shi, An T, Zhu G, Yu R, Xu G, Liu X, Xu B. Phase I study to determine the MTD of paclitaxel given three times per week during concurrent radiation therapy for stage III non-small cell lung cancer. Curr Med Res Opin. 2007;23(5):1161-7. NRP. [pmid: 17519083].
Shibamoto, Jeremic B, Acimovic L, Milicic B, Nikolic N. Influence of interfraction interval on the efficacy and toxicity of hyperfractionated radiotherapy in combination with concurrent daily chemotherapy in stage III non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2001;50(2):295-300. NRP. [pmid: 11380214].
Shioyama, Tokuuye K, Okumura T, Kagei K, Sugahara S, Ohara K, Akine Y, Ishikawa S, Satoh H, Sekizawa K. Clinical evaluation of proton radiotherapy for non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2003;56(1):7-13. USD. [pmid: 12694818].
Shrimali, Webster GJ, Lee LW, Bayman N, Sheikh H, Bewley M, Burt PA, Pemberton L, Harris MA, Chittalia A, Faivre-Finn C. Early report of intensity modulated radiotherapy (IMRT) for locally advanced lung cancer at the Christie. Clinical Oncology. 2011;23(3):S21-S22. NRD.
Sibley, Mundt AJ, Shapiro C, Jacobs R, Chen G, Weichselbaum R, Vijayakumar S. The treatment of stage III nonsmall cell lung cancer using high dose conformal radiotherapy. Int J Radiat Oncol Biol Phys. 1995;33(5):1001-7. NRP. [pmid: 7493826].
Sibley, Jamieson TA, Marks LB, Anscher MS, Prosnitz LR. Radiotherapy alone for medically inoperable stage I non-small-cell lung cancer: the Duke experience. Int J Radiat Oncol Biol Phys. 1998;40(1):149-54. NRI. [pmid: 9422571].
Sim, Rosenzweig KE, Schindelheim R, Ng KK, Leibel SA. Induction chemotherapy plus three-dimensional conformal radiation therapy in the definitive treatment of locally advanced non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2001;51(3):660-5. NRP. [pmid: 11597806].
Simon, Dupuy DE, DiPetrillo TA, Safran HP, Grieco CA, Ng T, Mayo-Smith WW. Pulmonary radiofrequency ablation: long-term safety and efficacy in 153 patients. Radiology. 2007;243(1):268-75. USD. [pmid: 17392258].
Singhal, Pittman K, Karapetis C, Stephens S, Borg M. Oral vinorelbine and cisplatin with concomitant radiotherapy in stage iii non small cell lung cancer (NSCLC) - Covert study. Asia-Pacific Journal of Clinical Oncology. 2011;7:153. NRD.
Sinha, McGarry RC. Stereotactic body radiotherapy for bilateral primary lung cancers: the Indiana University experience. Int J Radiat Oncol Biol Phys. 2006;66(4):1120-4. NRP. [pmid: 17145532].
Smith, Palma D, Parhar T, Alexander CS, Wai ES. Inoperable early stage non-small cell lung cancer: comorbidity, patterns of care and survival. Lung Cancer. 2011;72(1):39-44. NRP. [pmid: 20801544].
Socinski, Blackstock AW, Bogart JA, Wang X, Munley M, Rosenman J, Gu L, Masters GA, Ungaro P, Sleeper A, Green M, Miller AA, Vokes EE. Randomized phase II trial of induction chemotherapy followed by concurrent chemotherapy and dose-escalated thoracic conformal radiotherapy (74 Gy) in stage III non-small-cell lung cancer: CALGB 30105. J Clin Oncol. 2008;26(15):2457-63. NRP. [pmid: 18487565].
Socinski, Zhang C, Herndon JE 2nd, Dillman RO, Clamon G, Vokes E, Akerley W, Crawford J, Perry MC, Seagren SL, Green MR. Combined modality trials of the Cancer and Leukemia Group B in stage III non-small-cell lung cancer: analysis of factors influencing survival and toxicity. Ann Oncol. 2004;15(7):1033-41. NRP. [pmid: 15205196].
Socinski, Morris DE, Halle JS, Moore DT, Hensing TA, Limentani SA, Fraser R, Tynan M, Mears A, Rivera MP, Detterbeck FC, Rosenman JG. Induction and concurrent chemotherapy with high-dose thoracic conformal radiation therapy in unresectable stage IIIA and IIIB non-small-cell lung cancer: a dose-escalation phase I trial. J Clin Oncol. 2004;22(21):4341-50. NRP. [pmid: 15514375].
Socinski, Clark JA, Halle J, Steagall A, Kaluzny B, Rosenman JG. Induction therapy with carboplatin/paclitaxel followed by concurrent carboplatin/paclitaxel and dose-escalating conformal radiotherapy in the treatment of locally advanced, unresectable non-small cell lung cancer: preliminary report of a phase I trial. Semin Oncol. 1997;24(4 Suppl 12):S12-117-S12-122. NRP.
Socinski, Rosenman JG, Halle J, Schell MJ, Lin Y, Russo S, Rivera MP, Clark J, Limentani S, Fraser R, Mitchell W, Detterbeck FC. Dose-escalating conformal thoracic radiation therapy with induction and concurrent carboplatin/paclitaxel in unresectable stage IIIA/B nonsmall cell lung carcinoma: a modified phase I/II trial. Cancer. 2001;92(5):1213-23. NRP. [pmid: 11571735].
Socinski, Rosenman JG, Schell MJ, Halle J, Russo S, Rivera MP, Clark J, Limentani S, Fraser R, Mitchell W, Detterbeck FC. Induction carboplatin/paclitaxel followed by concurrent carboplatin/paclitaxel and dose-escalating conformal thoracic radiation therapy in unresectable stage IIIA/B nonsmall cell lung carcinoma: a modified Phase I trial. Cancer. 2000;89(3):534-42. NRP. [pmid: 10931452].
Soliman, Cheung P, Yeung L, Poon I, Balogh J, Barbera L, Spayne J, Danjoux C, Dahele M, Ung Y. Accelerated hypofractionated radiotherapy for early-stage non-small-cell lung cancer: long-term results. Int J Radiat Oncol Biol Phys. 2011;79(2):459-65. NRI. [pmid: 20385455].
Solomon, Ball DL, Richardson G, Smith JG, Millward M, MacManus M, Michael M, Wirth A, O'Kane C, Muceniekas L, Ryan G, Rischin D. Phase I/II study of concurrent twice-weekly paclitaxel and weekly cisplatin with radiation therapy for stage III non-small cell lung cancer. Lung Cancer. 2003;41(3):353-61. NRP. [pmid: 12928126].
Song, Pyo H, Moon SH, Kim TH, Kim DW, Cho KH. Treatment-related pneumonitis and acute esophagitis in non-small-cell lung cancer patients treated with chemotherapy and helical tomotherapy. Int J Radiat Oncol Biol Phys. 2010;78(3):651-8. NRP. [pmid: 20207499].
Song, Benedict SH, Cardinale RM, Chung TD, Chang MG, Schmidt-Ullrich RK. Stereotactic body radiation therapy of lung tumors: preliminary experience using normal tissue complication probability-based dose limits. Am J Clin Oncol. 2005;28(6):591-6. NRP. [pmid: 16317270].
Sotnikov, Panshin G, Ilin M, Ivashin A. Radiation therapy of non-small cell lung cancer with dose escalation on cobalt 60 gamma units. Four years results. Radiotherapy and Oncology. 2011;99:S345. NRD.
Souquet, Fournel P, Bohas CH, Fortune IC, Chatte G. Cisplatin and ifosfamide with various doses of vinorelbine (navelbine) in advanced non-small lung cancer. Semin Oncol. 1996;23(2 Suppl 5):8-10. NRP. [pmid: 8610239].
Spiro, Rudd RM, Souhami RL, Brown J, Fairlamb DJ, Gower NH, Maslove L, Milroy R, Napp V, Parmar MK, Peake MD, Stephens RJ, Thorpe H, Waller DA, West P. Chemotherapy versus supportive care in advanced non-small cell lung cancer: improved survival without detriment to quality of life. Thorax. 2004;59(10):828-36. NRP. [pmid: 15454647].
Splinter, van Schil PE, Kramer GW, van Meerbeeck J, Gregor A, Rocmans P, Kirkpatrick A. Randomized trial of surgery versus radiotherapy in patients with stage IIIA (N2) non small-cell lung cancer after a response to induction chemotherapy. EORTC 08941. Clin Lung Cancer. 2000;2(1):69-72. discussion 73. NRP. [pmid: 14731343].
Spych, Gottwald L, Klonowicz M, Biegala M, Bibik R, Fijuth J. The analysis of prognostic factors affecting post-radiation acute reaction after conformal radiotherapy for non-small cell lung cancer. Archives of Medical Science. 2010;6(5):756-763. NRO. [pmid: 22419936].
Srisam-Ang, Podhipak A, Narksawat K, Supaattagorn P, Tipayamongkholgul M. Survival of patients with advanced non-small-cell lung cancer at Ubon Ratchathani Cancer Center, Thailand. Southeast Asian J Trop Med Public Health. 2005;36(4):994-1006. NRP. [pmid: 16295558].
Stamatis, Eberhardt W, Stuben G, Bildat S, Dahler O, Hillejan L. Preoperative chemoradiotherapy and surgery for selected non-small cell lung cancer IIIB subgroups: long-term results. Ann Thorac Surg. 1999;68(4):1144-9. NRP. [pmid: 10543470].
Stathopoulos, Malamos N, Antonadou D, Throuvalas N, Thalassinos N, Zoitopoulos M. Comparison of effectiveness between chemotherapy alone versus chemo-radiotherapy in stage III non-small cell lung cancer. Oncol Rep. 1997;4(1):119-22. NRP. [pmid: 21590024].
Stathopoulos, Papakostas P, Malamos N, Samelis G, Moschopoulos N. Chemo-radiotherapy versus chemo-surgery in stage IIIA non-small cell lung cancer. Oncol Rep. 1996;3(4):673-6. NRP. [pmid: 21594433].
Stathopoulos, Dafni UG, Malamos NA, Rigatos S, Kouvatseas G, Moschopoulos N. Induction chemotherapy in non small cell lung cancer stage IIIa–b and IV and second-line treatment. Anticancer Res. 1999;19(4C):3543-8. NRP. [pmid: 10629650].
Stauder, Macdonald OK, Olivier KR, Call JA, Lafata K, Mayo CS, Miller RC, Brown PD, Bauer HJ, Garces YI. Early pulmonary toxicity following lung stereotactic body radiation therapy delivered in consecutive daily fractions. Radiother Oncol. 2011;99(2):166-71. USD. [pmid: 21571384].
Stephens, Girling DJ, Hopwood P, Thatcher N. A randomised controlled trial of pre-operative chemotherapy followed, if feasible, by resection versus radiotherapy in patients with inoperable stage T3, N1, M0 or T1-3, N2, M0 non-small cell lung cancer. Lung Cancer. 2005;49(3):395-400. NRP. [pmid: 15908042].
Stevens, Begbie SD. Hypofractionated irradiation for inoperable non-small cell lung cancer. Australas Radiol. 1995;39(3):265-70. NRP. [pmid: 7487763].
Stevens, Stevens G, Kolbe J, Cox B. Management of stages I and II non-small-cell lung cancer in a New Zealand study: divergence from international practice and recommendations. Intern Med J. 2008;38(10):758-68. NRP. [pmid: 18298555].
Stinchcombe, Lee CB, Moore DT, Rivera MP, Halle J, Limentani S, Rosenman JG, Socinski MA. Long-term follow-up of a phase I/II trial of dose escalating three-dimensional conformal thoracic radiation therapy with induction and concurrent carboplatin and paclitaxel in unresectable stage IIIA/B non-small cell lung cancer. J Thorac Oncol. 2008;3(11):1279-85. NRP. [pmid: 18978563].
Stinchcombe, Morris DE, Lee CB, Moore DT, Hayes DN, Halle JS, Rivera MP, Rosenman JG, Socinski MA. Induction chemotherapy with carboplatin, irinotecan, and paclitaxel followed by high dose three-dimension conformal thoracic radiotherapy (74 Gy) with concurrent carboplatin, paclitaxel, and gefitinib in unresectable stage IIIA and stage IIIB non-small cell lung cancer. J Thorac Oncol. 2008;3(3):250-7. NRP. [pmid: 18317067].
Stinchcombe, Hodgson L, Herndon JE, Kelley Ii MJ, Cicchetti MG, Ramnath N, Niell HB, Atkins JN, Akerley W, Green MR, Vokes EE. Treatment outcomes of different prognostic groups of patients on Cancer and Leukemia Group B trial 39801: Induction chemotherapy followed by chemoradiotherapy compared with chemoradiotherapy alone for unresectable stage III non-small cell lung cancer. Journal of Thoracic Oncology. 2009;4(9):1117-1125. NRP. [pmid: 19652624].
Strand, Brunsvig PF, Johannessen DC, Sundstrom S, Wang M, Hornslien K, Bremnes RM, Stensvold A, Garpestad O, Norstein J. Potentially curative radiotherapy for non-small-cell lung cancer in Norway: a population-based study of survival. Int J Radiat Oncol Biol Phys. 2011;80(1):133-41. NRI. [pmid: 20452137].
Stupp, Mayer M, Kann R, Weder W, Zouhair A, Betticher DC, Roth AD, Stahel RA, Majno S, Peters S, Jost L, Furrer M, Thierstein S, Schmid RA, Hsu-Schmitz SF, Mirimanoff RO, Ris HB, Pless M. Neoadjuvant chemotherapy and radiotherapy followed by surgery in selected patients with stage IIIB non-small-cell lung cancer: a multicentre phase II trial. Lancet Oncol. 2009;10(8):785-93. NRP. [pmid: 19604722].
Sugarbaker, Herndon J, Kohman LJ, Krasna MJ, Green MR. Results of cancer and leukemia group B protocol 8935. A multiinstitutional phase II trimodality trial for stage IIIA (N2) non-small-cell lung cancer. Cancer and Leukemia Group B Thoracic Surgery Group. J Thorac Cardiovasc Surg. 1995;109(3):473-83. discussion 483–5. NRP. [pmid: 7877308].
Sulman, Komaki R, Klopp AH, Cox JD, Chang JY. Exclusion of elective nodal irradiation is associated with minimal elective nodal failure in non-small cell lung cancer. Radiat Oncol. 2009;4:5. NRO. [pmid: 19183471].
Sun, Leung SW, Wang CJ, Chen HC, Fang FM, Huang EY, Hsu HC, Yeh SA, Hsiung C, Huang DT. Concomitant boost radiation therapy for inoperable non-small-cell lung cancer: preliminary report of a prospective randomized study. Int J Radiat Oncol Biol Phys. 2000;47(2):413-8. NRI. [pmid: 10802368].
Sundstrom, Bremnes R, Brunsvig P, Aasebo U, Olbjorn K, Fayers PM, Kaasa S. Immediate or delayed radiotherapy in advanced non-small cell lung cancer (NSCLC)? Data from a prospective randomised study. Radiother Oncol. 2005;75(2):141-8. NRP. [pmid: 16094739].
Sundstrom, Bremnes R, Aasebo U, Aamdal S, Hatlevoll R, Brunsvig P, Johannessen DC, Klepp O, Fayers PM, Kaasa S. Hypofractionated palliative radiotherapy (17 Gy per two fractions) in advanced non-small-cell lung carcinoma is comparable to standard fractionation for symptom control and survival: a national phase III trial. J Clin Oncol. 2004;22(5):801-10. NRP. [pmid: 14990635].
Sundstrom, Bremnes RM, Brunsvig P, Aasebo U, Kaasa S. Palliative thoracic radiotherapy in locally advanced non-small cell lung cancer: can quality-of-life assessments help in selection of patients for short- or long-course radiotherapy?. J Thorac Oncol. 2006;1(8):816-24. NRP. [pmid: 17409965].
Sunyach, Falchero L, Pommier P, Perol M, Arpin D, Vincent M, Boutry D, Rebatu P, Ginestet C, Martel-Lafay I, Perol D, Carrie C. Prospective evaluation of early lung toxicity following three-dimensional conformal radiation therapy in non-small-cell lung cancer: preliminary results. Int J Radiat Oncol Biol Phys. 2000;48(2):459-63. NRP. [pmid: 10974462].
Sur, Ahmed SN, Donde B, Morar R, Mohamed G, Sur M, Pacella JA, Van der Merwe D, Feldman C. Brachytherapy boost vs teletherapy boost in palliation of symptomatic, locally advanced non-small cell lung cancer: Preliminary analysis of a randomized, prospective study. Journal of Brachytherapy International. 2001;17(4):309-315. NRD.
Sura, Yorke E, Jackson A, Rosenzweig KE. High-dose radiotherapy for the treatment of inoperable non-small cell lung cancer. Cancer J. 2007;13(4):238-42. NRP. [pmid: 17762758].
Sura, Gupta V, Yorke E, Jackson A, Amols H, Rosenzweig KE. Intensity-modulated radiation therapy (IMRT) for inoperable non-small cell lung cancer: the Memorial Sloan-Kettering Cancer Center (MSKCC) experience. Radiother Oncol. 2008;87(1):17-23. USD. [pmid: 18343515].
Surmont, Smit EF, de Jonge M, Aerts JG, Nackaerts K, Vernhout R, Gras J, Van Wijk A, Phernambucq EC, van Meerbeeck JP, Senan S, Kraaij CJ, Chouaki N, Praag J, van Klaveren RJ. Pemetrexed and cisplatin with concurrent radiotherapy for locally advanced non-small cell and limited disease small cell lung cancer: results from 2 phase I studies. Lung Cancer. 2010;69(3):302-6. NRP. [pmid: 20096951].
Tada, Minakuchi K, Matsui K, Kin H, Nishiguchi T, Fukuda H. A single institutional subset analysis of the WJLCG study comparing concurrent and sequential chemoradiotherapy for stage III non-small-cell lung cancer. Radiat Med. 2004;22(3):163-7. NRP. [pmid: 15287531].
Tada, Chiba Y, Tsujino K, Fukuda H, Nishimura Y, Kokubo M, Negoro S, Kudoh S, Fukuoka M, Nakagawa K, Nakanishi Y. A Phase I Study of Chemoradiotherapy with Use of Involved-Field Conformal Radiotherapy and Accelerated Hyperfractionation for Stage III Non-Small-Cell Lung Cancer: WJTOG 3305. Int J Radiat Oncol Biol Phys. 2011. NRP.
Takamori, Rikimaru T, Hayashi A, Tayama K, Mitsuoka M, Fujimoto K, Horiuchi M, Hayabuchi N, Oizumi K, Shirouzu K. A preoperative alternating chemotherapy and radiotherapy program for patients with stage IIIA (N2) non-small cell lung cancer. Lung Cancer. 2000;29(1):49-56. NRP. [pmid: 10880847].
Takata, Ueoka H, Kiura K, Tabata M, Takigawa N, Katayama H, Takemoto M, Hiraki Y, Harada M, Tanimoto M. Daily low-dose cisplatin and concurrent thoracic irradiation for poor-risk patients with unresectable non-small-cell lung cancer. Acta Med Okayama. 2002;56(5):261-6. FLA. [pmid: 12530510].
Takeda, Kunieda E, Ohashi T, Aoki Y, Oku Y, Enomoto T, Nomura K, Sugiura M. Severe COPD is correlated with mild radiation pneumonitis following stereotactic body radiotherapy. Chest. 2011. NRP.
Takeda, Nemoto K, Saito H, Ogawa Y, Takai Y, Yamada S. Dosimetric correlations of acute esophagitis in lung cancer patients treated with radiotherapy. Int J Radiat Oncol Biol Phys. 2005;62(3):626-9. NRP. [pmid: 15936536].
Takeda, Negoro S, Tanaka M, Fukuda H, Nakagawa K, Kawahara M, Semba H, Kudoh S, Sawa T, Saijo N, Fukuoka M. A phase II study of cisplatin and irinotecan as induction chemotherapy followed by concomitant thoracic radiotherapy with weekly low-dose irinotecan in unresectable, stage III, non-small cell lung cancer: JCOG 9706. Jpn J Clin Oncol. 2011;41(1):25-31. NRP. [pmid: 20802006].
Takeda, Negoro S, Kudoh S, Okishio K, Masuda N, Takada M, Tanaka M, Nakajima T, Tada T, Fukuoka M. Phase I/II study of weekly irinotecan and concurrent radiation therapy for locally advanced non-small cell lung cancer. Br J Cancer. 1999;79(9–10):1462-7. NRP. [pmid: 10188891].
Takigawa, Kiura K, Hotta K, Hosokawa S, Nogami N, Aoe K, Gemba K, Fujiwara K, Harita S, Takemoto M, Himei K, Shinkai T, Fujiwara Y, Takata S, Tabata M, Kanazawa S, Tanimoto M. A phase I study of S-1 with concurrent thoracic radiotherapy in elderly patients with localized advanced non-small cell lung cancer. Lung Cancer. 2011;71(1):60-4. NRP. [pmid: 20451285].
Takigawa, Kiura K, Segawa Y, Hotta K, Tamaoki A, Tokuda Y, Nagata T, Watanabe K, Gemba K, Moritaka T, Horita N, Takeda H, Okimoto N, Takemoto M, Matsuo K, Shinkai T, Tabata M, Ueoka H, Kanazawa S, Tanimoto M. Benefits and adverse events among elderly patients receiving concurrent chemoradiotherapy for locally advanced non-small cell lung cancer: analysis of the Okayama Lung Cancer Study Group trial 0007. J Thorac Oncol. 2011;6(6):1087-91. NRP. [pmid: 21415777].
Takiguchi, Uruma R, Asaka-Amano Y, Kurosu K, Kasahara Y, Tanabe N, Tatsumi K, Uno T, Itoh H, Kuriyama T. Phase I study of cisplatin and irinotecan combined with concurrent hyperfractionated accelerated thoracic radiotherapy for locally advanced non-small cell lung carcinoma. Int J Clin Oncol. 2005;10(6):418-24. NRP. [pmid: 16369746].
Takita, Shin KH. Radiation induced chemotherapy sensitization in trimodality therapy of stage III non small cell lung cancer. A preliminary report. J Exp Clin Cancer Res. 2000;19(4):413-6. NRP. [pmid: 11277316].
Takita, Shin KH, Soh AY, Yi WS, Wilding G. Induction therapy of loco-regional non-small-cell lung cancer with reliable response and low toxicity (low dose radiotherapy sensitizes tumor to subsequent chemotherapy?). 2009;63:387-92. NRI.
Tan, Wee J, Ang PT, Fong KW, Leong SS, Khoo KS, Tan T, Lee KS, Eng P, Hsu A, Tan YK, Chua EJ, Ong YY. Induction chemotherapy followed by concurrent chemoradiotherapy in stage III unresectable non-small cell lung cancer. Acta Oncol. 1999;38(8):1005-9. NRP. [pmid: 10665753].
Tanabe, Koizumi T, Tsushima K, Ito M, Kanda S, Kobayashi T, Yasuo M, Yamazaki Y, Kubo K, Honda T, Kondo R, Yoshida K. Comparative study of three different catheters for CT imaging-bronchoscopy-guided radiofrequency ablation as a potential and novel interventional therapy for lung cancer. Chest. 2010;137(4):890-7. NRI. [pmid: 19858232].
Tanaka, Okamoto I, Yamamoto N, Hattori Y, Masuda N, Nishio M, Takeda K, Seto T, Nishimura Y, Nakagawa K. Phase 2 study of nimotuzumab in combination with concurrent chemoradiotherapy (CRT) in patients with locally advanced non-small cell lung cancer (NSCLC). European Journal of Cancer. 2011;47:S605. NRD.
Tannehill, Mehta MP, Larson M, Storer B, Pellet J, Kinsella TJ, Schiller JH. Effect of amifostine on toxicities associated with sequential chemotherapy and radiation therapy for unresectable non-small-cell lung cancer: results of a phase II trial. J Clin Oncol. 1997;15(8):2850-7. NRP. [pmid: 9256128].
Tawfik, Taha H, Attia Ael GA. Induction Docetaxel and Cisplatin Followed by Weekly Docetaxel and Cisplatin with Concurrent Radiotherapy in Locally Advanced Stage III Non Small Cell Lung Cancer (LA-NSCLC)-A Phase II Study. J Egypt Natl Canc Inst. 2007;19(1):15-20. NRP. [pmid: 18839031].
Taylor, Liao ZX, Cox JD, Stevens C, Roth J, Walsh G, Chang JY, Guerrero T, Jeter M, Putnam J Jr, Fossella FV, Allen P, Komaki R. Equivalent outcome of patients with clinical Stage IIIA non-small-cell lung cancer treated with concurrent chemoradiation compared with induction chemotherapy followed by surgical resection. Int J Radiat Oncol Biol Phys. 2004;58(1):204-12. NRP. [pmid: 14697440].
Tejedor, Valerdi JJ, Lopez R, Dominguez MA, Arias F, Illarramendi JJ, Martinez E. Mitomycin, cisplatin, and vindesine followed by radiotherapy combined with cisplatin in stage III nonsmall cell lung cancer: long-term results. Int J Radiat Oncol Biol Phys. 1995;31(4):813-8. NRP. [pmid: 7860393].
Tell, Sederholm C, Klintenberg C, Franksson L, Branden E, Hillerdal G, Lonn U, Linden CJ, Ewers SB, Lamberg K, Mrazek E, Loden B, Sjogren A, Linne T, Friesland S, Sirzen F. Multicentre phase II trial of paclitaxel and carboplatin with concurrent radiotherapy in locally advanced non-small cell lung cancer. Anticancer Res. 2008;28(5B):2851-7. NRP. [pmid: 19031924].
Testolin, Baiocchi C, Galuppo S, Favretto MS, Schiavon S, Morandi P. Stage i non small cell lung cancer (NSCLC) in patients aged >80 years - Clinical outcomes after stereotactic radiotherapy using real time tumour tracking. European Journal of Cancer. 2011;47:S273-S274. NRD.
Thammakumpee. Clinical manifestation and survival of patients with non-small cell lung cancer. J Med Assoc Thai. 2004;87(5):503-7. USD. [pmid: 15222519].
Thanos, Mylona S, Ptohis N, Tsiouris S, Sotiropoulou E, Pomoni A, Pomoni M. Percutaneous radiofrequency thermal ablation in the management of lung tumors: presentation of clinical experience on a series of 35 patients. Diagn Interv Radiol. 2009;15(4):290-6. USD. [pmid: 19813168].
Thirion, Holmberg O, Collins CD, O'Shea C, Moriarty M, Pomeroy M, O'Sullivan C, Buckney S, Armstrong J. Escalated dose for non-small-cell lung cancer with accelerated hypofractionated three-dimensional conformal radiation therapy. Radiother Oncol. 2004;71(2):163-6. NRP. [pmid: 15110449].
Thomas, Rube C, Semik M, von Eiff M, Freitag L, Macha HN, Wagner W, Klinke F, Scheld HH, Willich N, Berdel WE, Junker K. Impact of preoperative bimodality induction including twice-daily radiation on tumor regression and survival in stage III non-small-cell lung cancer. J Clin Oncol. 1999;17(4):1185. NRP. [pmid: 10561177].
Thomas, Rube C, Hoffknecht P, Macha HN, Freitag L, Linder A, Willich N, Hamm M, Sybrecht GW, Ukena D, Deppermann KM, Droge C, Riesenbeck D, Heinecke A, Sauerland C, Junker K, Berdel WE, Semik M. Effect of preoperative chemoradiation in addition to preoperative chemotherapy: a randomised trial in stage III non-small-cell lung cancer. Lancet Oncol. 2008;9(7):636-48. NRP. [pmid: 18583190].
Thomas, Kleisbauer JP, Robinet G, Clavier J, Poirier R, Vernenegre A, Bonnaud F, Taytard A, Paillotin D, Pommier P, De Santi, Barriere JR, Pignon T. Carboplatin as radiosensitizer in non-small cell lung cancer after cisplatin containing chemotherapy. A phase I study of a groupe francais de pneumo-cancerologie (G.F.P.C.). Lung Cancer. 1997;18(1):71-81. NRP. [pmid: 9268949].
Timmerman, Papiez L, McGarry R, Likes L, DesRosiers C, Frost S, Williams M. Extracranial stereotactic radioablation: results of a phase I study in medically inoperable stage I non-small cell lung cancer. Chest. 2003;124(5):1946-55. NRI, USD. [pmid: 14605072].
Timmerman, McGarry R, Yiannoutsos C, Papiez L, Tudor K, DeLuca J, Ewing M, Abdulrahman R, DesRosiers C, Williams M, Fletcher J. Excessive toxicity when treating central tumors in a phase II study of stereotactic body radiation therapy for medically inoperable early-stage lung cancer. J Clin Oncol. 2006;24(30):4833-9. NRI, USD. [pmid: 17050868].
Timmerman, Paulus R, Galvin J, Michalski J, Straube W, Bradley J, Fakiris A, Bezjak A, Videtic G, Johnstone D, Fowler J, Gore E, Choy H. Stereotactic body radiation therapy for inoperable early stage lung cancer. JAMA. 2010;303(11):1070-6. NRI, USD. [pmid: 20233825].
Tiwana, Lee HN, Gupta M, Kumar S, Verma SK, Saini S. Where do we stand in the multidisciplinary approach to non-small cell lung cancer (NSCLC) - A retrospective single institution experience from rural india. European Journal of Cancer. 2011;47:S600-S601. NRD.
Tokuda, Takigawa N, Kozuki T, Kamei H, Bessho A, Tada A, Hotta K, Katsui K, Kanazawa S, Tanimoto M, Kiura K. Long-term follow-up of phase II trial of docetaxel and cisplatin with concurrent thoracic radiation therapy for locally advanced non-small cell lung cancer. Acta Oncol. 2011. NRP.
Tombolini, Bonanni A, Donato V, Raffetto N, Santarelli M, Valeriani M, Enrici RM. Radiotherapy alone in elderly patients with medically inoperable stage IIIA and IIIB non-small cell lung cancer. Anticancer Res. 2000;20(6C):4829-33. NRP. [pmid: 11205228].
Tomirotti, Galassi B, Dambrosio M, Fossati V, Gramegna G, Colombo F, Rovej R, Scanni A. Cis/carboplatin + vinorelbine +/− radiotherapy in stage III and IV non small cell lung carcinoma. J Chemother. 1997;9(1):62-5. NRP. [pmid: 9106020].
Topczewska-Bruns, Hempel D, Pancewicz-Janczuk B, Sierko E, Filipowski T, Wojtukiewicz M. 3-year overall survival for inoperable non-small cell lung carcinoma patients treated with radiochemotherapy-single-institution retrospective analysis. Radiotherapy and Oncology. 2011;99:S340. NRD.
Treat, Gonin R, Socinski MA, Edelman MJ, Catalano RB, Marinucci DM, Ansari R, Gillenwater HH, Rowland KM, Comis RL, Obasaju CK, Belani CP. A randomized, phase III multicenter trial of gemcitabine in combination with carboplatin or paclitaxel versus paclitaxel plus carboplatin in patients with advanced or metastatic non-small-cell lung cancer. Annals of Oncology. 2010;21(3):540-547. NRP. [pmid: 19833819].
Trodella, De Marinis F, D'Angelillo RM, Ramella S, Cesario A, Valente S, Nelli F, Migliorino MR, Margaritora S, Corbo GM, Porziella V, Ciresa M, Cellini F, Bonassi S, Russo P, Cortesi E, Granone P. Induction cisplatin-gemcitabine-paclitaxel plus concurrent radiotherapy and gemcitabine in the multimodality treatment of unresectable stage IIIB non-small cell lung cancer. Lung Cancer. 2006;54(3):331-8. NRP. [pmid: 17011065].
Trodella, Cellini N, Picciocchi A, Marano P, Balducci M, Mantini G, Turriziani A, Corbo GM, Valente S, Valentini V, Pirronti T, Granone P, Dobelbower RR. Phase I–II trial of concomitant continuous carboplatin (CBDCA) infusion and radiotherapy in advanced nonsmall cell lung cancer with evaluation for surgery: final report. Int J Radiat Oncol Biol Phys. 1997;37(1):93-101. NRP. [pmid: 9054882].
Trodella, Granone P, Valente S, Turriziani A, Macis G, Corbo GM, Margaritora S, Cesario A, D'Angelillo RM, Gualano G, Ramella S, Galetta D, Cellini N. Phase I trial of weekly gemcitabine and concurrent radiotherapy in patients with inoperable non-small-cell lung cancer. J Clin Oncol. 2002;20(3):804-10. NRP. [pmid: 11821464].
Trodella, Granone P, Valente S, Margaritora S, Macis G, Cesario A, D'Angelillo RM, Valentini V, Corbo GM, Porziella V, Ramella S, Tonini G, Galetta D, Ciresa M, Vincenzi B, Cellini N. Neoadjuvant concurrent radiochemotherapy in locally advanced (IIIA–IIIB) non-small-cell lung cancer: long-term results according to downstaging. Ann Oncol. 2004;15(3):389-98. NRP. [pmid: 14998840].
Trovo, Linda A, El Naqa I, Javidan-Nejad C, Bradley J. Early and late lung radiographic injury following stereotactic body radiation therapy (SBRT). Lung Cancer. 2010;69(1):77-85. NRP. [pmid: 19910075].
Tsao, Liu D, Lee JJ, Spitz M, Hong WK. Smoking affects treatment outcome in patients with advanced nonsmall cell lung cancer. Cancer. 2006;106(11):2428-36. NRP. [pmid: 16634096].
Tselis, Ferentinos K, Kolotas C, Schirren J, Baltas D, Antonakakis A, Ackermann H, Zamboglou N. Computed tomography-guided interstitial high-dose-rate brachytherapy in the local treatment of primary and secondary intrathoracic malignancies. J Thorac Oncol. 2011;6(3):545-52. NRI. [pmid: 21258257].
Tsoutsou, Froudarakis ME, Bouros D, Koukourakis MI. Hypofractionated/accelerated radiotherapy with cytoprotection (HypoARC) combined with vinorelbine and liposomal doxorubicin for locally advanced non-small cell lung cancer (NSCLC). Anticancer Res. 2008;28(2B):1349-54. NRP. [pmid: 18505077].
Tsuchiya, Ohe Y, Sugiura T, Fuwa N, Kitamoto Y, Mori K, Kobayashi H, Nakata K, Sawa T, Hirai K, Etoh T, Saka H, Saito A, Fukuda H, Ishizuka N, Saijo N, Japan S. Clinical Oncology Group. Randomized phase I study of standard-fractionated or accelerated-hyperfractionated radiotherapy with concurrent cisplatin and vindesine for unresectable non-small cell lung cancer: a report of Japan Clinical Oncology Group Study (JCOG 9601). 2001;31:488-94. NRP.
Uematsu, Shioda A, Suda A, Fukui T, Ozeki Y, Hama Y, Wong JR, Kusano S. Computed tomography-guided frameless stereotactic radiotherapy for stage I non-small cell lung cancer: a 5-year experience. Int J Radiat Oncol Biol Phys. 2001;51(3):666-70. NRI. [pmid: 11597807].
Uitterhoeve, Belderbos JS, Koolen MG, van der Vaart PJ, Rodrigus PT, Benraadt J, Koning CC, Gonzalez D, Bartelink Gonzalez H. Toxicity of high-dose radiotherapy combined with daily cisplatin in non-small cell lung cancer: results of the EORTC 08912 phase I/II study. European Organization for Research and Treatment of Cancer. Eur J Cancer. 2000;36(5):592-600. NRP. [pmid: 10738123].
Uitterhoeve, Koolen MG, van Os RM, Koedooder K, van de Kar M, Pieters BR, Koning CC. Accelerated high-dose radiotherapy alone or combined with either concomitant or sequential chemotherapy; treatments of choice in patients with Non-Small Cell Lung Cancer. Radiat Oncol. 2007;2:27. USD. [pmid: 17659094].
Ukena, Leutz M, Schlimmer P, Huwer H, SchÃ¤fers HJ, Sybrecht G. Non-small cell lung cancer (NSCLC) stage IIIA/IIIB. A pilot study of neoadjuvant chemotherapy with paclitaxel and carboplatin. 1997;92(Suppl 5()):49-53. FLA.
Ulutin, Guden M, Oysul K, Surenkok S, Pak Y. Split-course radiotherapy with or without concurrent or sequential chemotherapy in non-small cell lung cancer. Radiat Med. 2000;18(2):93-6. NRP. [pmid: 10888041].
Unlu, Diniz G, Komurcuoglu B, Gayaf M, Gokce T, Karadogan I, Akcay C. Comparison of curative and palliative radiotherapy efficacy in unresectable advanced non-small cell lung cancer patients with or without metastasis. Saudi Med J. 2006;27(6):849-53. NRP. [pmid: 16758049].
Urbanic, Turrisi AT 3rd, Sharma AK, Silvestri GA, Williams TE, Vanek KN, Sherman CA. Conformal high dose external radiation therapy, 80.5 Gy, alone for medically inoperable non-small cell lung cancer: a retrospective analysis. J Thorac Oncol. 2006;1(2):112-9. NRP. [pmid: 17409839].
Uy, Darling G, Xu W, Yi QL, De Perrot M, Pierre AF, Waddell TK, Johnston MR, Bezjak A, Shepherd FA, Keshavjee S. Improved results of induction chemoradiation before surgical intervention for selected patients with stage IIIA-N2 non-small cell lung cancer. J Thorac Cardiovasc Surg. 2007;134(1):188-93. NRP. [pmid: 17599507].
Valerio, Russo A, Latteri MA, Modica G, Gulotta G, Armata MG, Bajardi E, Cicero G, Pantuso G, Grassi N, Agosta G, Gebbia N. Weekly docetaxel as II line therapy in non-small cell lung cancer: an interim analysis of a phase II study. Lung Cancer. 2001;34(Suppl 4()):S31-5. NRI. [pmid: 11742700].
van Baardwijk, Bosmans G, Boersma L, Wanders S, Dekker A, Dingemans AM, Bootsma G, Geraedts W, Pitz C, Simons J, Lambin P, De Ruysscher D. Individualized radical radiotherapy of non-small-cell lung cancer based on normal tissue dose constraints: a feasibility study. Int J Radiat Oncol Biol Phys. 2008;71(5):1394-401. NRP. [pmid: 18258380].
van Baardwijk, Wanders S, Boersma L, Borger J, Ollers M, Dingemans AM, Bootsma G, Geraedts W, Pitz C, Lunde R, Lambin P, De Ruysscher D. Mature results of an individualized radiation dose prescription study based on normal tissue constraints in stages I to III non-small-cell lung cancer. J Clin Oncol. 2010;28(8):1380-6. USD. [pmid: 20142596].
Van den Brande, De Ruysscher D, Vansteenkiste J, Spaas P, Specenier P, Demedts M. Sequential treatment with vindesine-ifosfamide-platinum (VIP) chemotherapy followed by platinum sensitized radiotherapy in stage IIIB non-small cell lung cancer: a phase II trial. Lung Cancer. 1998;22(1):45-53. NRP. [pmid: 9869107].
van der Voort van Zyp, van der Holt B, van Klaveren RJ, Pattynama P, Maat A, Nuyttens JJ. Stereotactic body radiotherapy using real-time tumor tracking in octogenarians with non-small cell lung cancer. Lung Cancer. 2010;69(3):296-301. OPP. [pmid: 20060195].
van der Voort van Zyp, Prevost JB, van der Holt B, Braat C, van Klaveren RJ, Pattynama PM, Levendag PC, Nuyttens JJ. Quality of life after stereotactic radiotherapy for stage I non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2010;77(1):31-7. USD. [pmid: 19864077].
van Dijck, Festen J, de Kleijn EM, Kramer GW, Tjan-Heijnen VC, Verbeek AL. Treatment and survival of patients with non-small cell lung cancer Stage IIIA diagnosed in 1989–1994 a study in the region of the Comprehensive Cancer Centre East, The Netherlands. Lung Cancer. 2001;34(1):19-27. NRP. [pmid: 11557109].
Van Kooten, Rosenberg M, Orlando M, Morero J, Vilanova M, Rojas O, Vicente H, Bagnes C, Silva C, Chacon RD. Neoadjuvant chemotherapy with gemcitabine and cisplatin in stage IIIA/B non-small cell lung cancer. Invest New Drugs. 2002;20(4):439-46. NRP. [pmid: 12448663].
van Loon, Grutters J, Wanders R, Boersma L, Oellers M, Dingemans AM, Bootsma G, Geraedts W, Pitz C, Simons J, Fatah SA, Snoep G, Hochstenbag M, Lambin P, De Ruysscher D. Follow-up with 18FDG-PET-CT after radical radiotherapy with or without chemotherapy allows the detection of potentially curable progressive disease in non-small cell lung cancer patients: a prospective study. Eur J Cancer. 2009;45(4):588-95. NRI. [pmid: 19046631].
van Meerbeeck, Kramer GW, Van Schil PE, Legrand C, Smit EF, Schramel F, Tjan-Heijnen VC, Biesma B, Debruyne C, van Zandwijk N, Splinter TA, Giaccone G. Randomized controlled trial of resection versus radiotherapy after induction chemotherapy in stage IIIA-N2 non-small-cell lung cancer. J Natl Cancer Inst. 2007;99(6):442-50. NRP. [pmid: 17374834].
van Putten, Price A, van der Leest AH, Gregor A, Little FA, Groen HJ. A Phase I study of gemcitabine with concurrent radiotherapy in stage III, locally advanced non-small cell lung cancer. Clin Cancer Res. 2003;9(7):2472-7. NRP. [pmid: 12855620].
Van Zandwijk, Smit EF, Kramer GW, Schramel F, Gans S, Festen J, Termeer A, Schlosser NJ, Debruyne C, Curran D, Giaccone G. Gemcitabine and cisplatin as induction regimen for patients with biopsy-proven stage IIIA N2 non-small-cell lung cancer: a phase II study of the European Organization for Research and Treatment of Cancer Lung Cancer Cooperative Group (EORTC 08955). J Clin Oncol. 2000;18(14):2658-64. NRP. [pmid: 10894864].
Vansteenkiste, De Leyn PR, Deneffe GJ, Lievens YN, Nackaerts KL, Van Raemdonck DE, van der Schueren E, Lerut TE, Demedts MG. Vindesine-ifosfamide-platinum (VIP) induction chemotherapy in surgically staged IIIA-N2 non-small-cell lung cancer: a prospective study. Leuven Lung Cancer Group. Ann Oncol. 1998;9(3):261-7. NRP. [pmid: 9602259].
Vansteenkiste, Stroobants SG, De Leyn PR, Dupont PJ, Verbeken EK. Potential use of FDG-PET scan after induction chemotherapy in surgically staged IIIa-N2 non-small-cell lung cancer: a prospective pilot study. The Leuven Lung Cancer Group. Ann Oncol. 1998;9(11):1193-8. NRP. [pmid: 9862049].
Varveris, Mazonakis M, Vlachaki M, Kachris S, Lyraraki E, Zoras O, Maris T, Froudarakis M, Velegrakis J, Perysinakis C, Damilakis J, Samonis G. A phase I trial of weekly docetaxel and cisplatinum combined to concurrent hyperfractionated radiotherapy for non-small cell lung cancer and squamous cell carcinoma of head and neck. Oncol Rep. 2003;10(1):185-95. NRP. [pmid: 12469168].
Vergnenegre, Daniel C, Lena H, Fournel P, Kleisbauer JP, Le Caer H, Letreut J, Paillotin D, Perol M, Bouchaert E, Preux PM, Robinet G. Docetaxel and concurrent radiotherapy after two cycles of induction chemotherapy with cisplatin and vinorelbine in patients with locally advanced non-small-cell lung cancer. A phase II trial conducted by the Groupe Francais de Pneumo-Cancerologie (GFPC). Lung Cancer. 2005;47(3):395-404. NRP. [pmid: 15713523].
Verstegen, Lagerwaard FJ, Haasbeek CJA, Slotman BJ, Senan S. Outcomes of stereotactic ablative radiotherapy following a clinical diagnosis of stage i NSCLC: Comparison with a contemporaneous cohort with pathologically proven disease. Radiotherapy and Oncology. 2011;101(2):250-254. USD. [pmid: 22056535].
Viallet, Brassard MA, Souhami L, Ayoub J, Del Vecchio P, Kreisman H, Guerra J, Gruber J, Langleben A, Hohneker J, Rousseau P. A phase I/II trial of neoadjuvant chemotherapy with cisplatin and vinorelbine followed by accelerated irradiation for patients with inoperable nonsmall cell lung carcinoma. Cancer. 1999;85(12):2562-9. NRP. [pmid: 10375103].
Vogt, Kolotas C, Martin T, Schneider LV, Neeb A, Mitrou PS, Diergarten K, Dornoff W, Zamboglou N. Simultaneous radiochemotherapy with paclitaxel in non-small cell lung cancer: a clinical phase I study. Semin Oncol. 1996;23(6 Suppl 15):26-30. NRP. [pmid: 8996594].
Vogt, Kolotas C, Martin T, Schneider LV, Goes-Schmieder R, Diergarten K, Zamboglou N. Concurrent paclitaxel/radiotherapy in locally advanced stage IIIA/B non- small cell lung cancer: Results of a clinical phase I study. Seminars in Radiation Oncology. 1997;7(2 SUPPL 1):S1-19-S1-24. NRP.
Vogt, Kolotas C, Martin T, Schneider LV, Goes-Schmieder R, Mitrou PS, Diergarten K, Kober B, Zamboglou N. Paclitaxel and simultaneous radiation in locally advanced stage IIIA/B non-small cell lung cancer: a clinical phase I study. Semin Oncol. 1996;23(6 Suppl 16):120-3. NRP. [pmid: 9007138].
Vokes, Haraf DJ, Drinkard LC, Hoffman PC, Ferguson MK, Vogelzang NJ, Watson S, Lane NJ, Golomb HM. A phase I trial of concomitant chemoradiotherapy with cisplatin dose intensification and granulocyte-colony stimulating factor support for advanced malignancies of the chest. Cancer Chemother Pharmacol. 1995;35(4):304-12. NRP. [pmid: 7530173].
Vokes, Herndon JE 2nd, Crawford J, Leopold KA, Perry MC, Miller AA, Green MR. Randomized phase II study of cisplatin with gemcitabine or paclitaxel or vinorelbine as induction chemotherapy followed by concomitant chemoradiotherapy for stage IIIB non-small-cell lung cancer: cancer and leukemia group B study 9431. J Clin Oncol. 2002;20(20):4191-8. NRP. [pmid: 12377962].
Vokes, Herndon JE 2nd, Kelley MJ, Cicchetti MG, Ramnath N, Neill H, Atkins JN, Watson DM, Akerley W, Green MR. Induction chemotherapy followed by chemoradiotherapy compared with chemoradiotherapy alone for regionally advanced unresectable stage III Non-small-cell lung cancer: Cancer and Leukemia Group B. J Clin Oncol. 2007;25(13):1698-704. NRP. [pmid: 17404369].
Voltolini, Luzzi L, Ghiribelli C, Paladini P, Di M, Gotti Bisceglie G. Results of induction chemotherapy followed by surgical resection in patients with stage IIIA (N2) non-small cell lung cancer: the importance of the nodal down-staging after chemotherapy. Eur J Cardiothorac Surg. 2001;20(6):1106-12. NRP. [pmid: 11717012].
Vora, Daly BD, Blaszkowsky L, McGrath JJ, Bankoff M, Supran S, Dipetrillo TA. High dose radiation therapy and chemotherapy as induction treatment for stage III nonsmall cell lung carcinoma. Cancer. 2000;89(9):1946-52. NRP. [pmid: 11064351].
Voroney, Hope A, Dahele MR, Purdie TG, Franks KN, Pearson S, Cho JB, Sun A, Payne DG, Bissonnette JP, Bezjak A, Brade AM. Chest wall pain and rib fracture after stereotactic radiotherapy for peripheral non-small cell lung cancer. J Thorac Oncol. 2009;4(8):1035-7. NRD. [pmid: 19633478].
Vyas, Suryanarayana U, Dixit S, Singhal S, Bhavsar DC, Neema JP, Baboo HA. Inoperable non-small cell lung cancer: palliative radiotherapy with two weekly fractions. Indian J Chest Dis Allied Sci. 1998;40(3):171-4. NRP. [pmid: 9919836].
Wagner, von Eiff M, Klinke F, Micke O, RÃ¼be C, Willich N. Neoadjuvant radiochemotherapy in locally advanced non-small cell bronchial carcinoma. Initial results of a prospective multicenter study. 1995;171:390-7. FLA.
Wanders, Steevens J, Botterweck A, Dingemans AM, Reymen B, Baardwijk A, Borger J, Bootsma G, Pitz C, Lunde R, Geraedts W, Lambin P, De Ruysscher D. Treatment with curative intent of stage III non-small cell lung cancer patients of 75years: A prospective population-based study. Eur J Cancer. 2011;47(18):2691-7. NRP. [pmid: 21733675].
Wang, Correa CR, Zhao L, Hayman J, Kalemkerian GP, Lyons S, Cease K, Brenner D, Kong FM. The effect of radiation dose and chemotherapy on overall survival in 237 patients with Stage III non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2009;73(5):1383-90. NRP. [pmid: 18929449].
Wang, Lu J, Liu T, Chen KM, Huang G, Liu FJ. CT-guided interstitial brachytherapy of inoperable non-small cell lung cancer. Lung Cancer. 2011;74(2):253-7. NRP. [pmid: 21513997].
Wang, Song M, Xu H, Fang Y. Prospective trial of combined hyperfractionated radiotherapy and bronchial arterial infusion of chemotherapy for locally advanced nonsmall cell lung cancer. Int J Radiat Oncol Biol Phys. 1996;34(2):309-13. NRP. [pmid: 8567331].
Wang, Wu N, Cham MD, Song Y. Tumor response in patients with advanced non-small cell lung cancer: perfusion CT evaluation of chemotherapy and radiation therapy. AJR Am J Roentgenol. 2009;193(4):1090-6. NRP. [pmid: 19770333].
Wang, Wang SY, Yang S, Ding Y, Shang Y. Late course three-dimensional conformal radiotherapy in patients with stage III non-small cell lung cancer. 2005;25:726-8. FLA.
Wang, Xia TY, Wang YJ, Li HQ, Li P, Wang JD, Chang DS, Liu LY, Di YP, Wang X, Wu WZ. Prospective study of epidermal growth factor receptor tyrosine kinase inhibitors concurrent with individualized radiotherapy for patients with locally advanced or metastatic non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2011;81(3):e59-65. NRP. [pmid: 21345607].
Wang, Huang XB, Ding Y, Mo KL, Yang S. Three-dimensional conformal radiotherapy combined with stereotactic radiotherapy for locally advanced non-small cell lung cancer: efficacy and complications. 2008;28:1996-8. FLA.
Waters, Dingle B, Rodrigues G, Vincent M, Ash R, Dar R, Inculet R, Kocha W, Malthaner R, Sanatani M, Stitt L, Yaremko B, Younus J, Yu E. Analysis of a novel protocol of combined induction chemotherapy and concurrent chemoradiation in unresected non-small-cell lung cancer: a ten-year experience with vinblastine, Cisplatin, and radiation therapy. Clin Lung Cancer. 2010;11(4):243-50. NRP. [pmid: 20630826].
Watkins, Wahlquist AE, Zauls AJ, Fields EC, Garrett-Mayer E, Aguero EG, Silvestri GA, Sharma AK. High-dose fractionated radiotherapy to 80 Gy for stage I-II medically inoperable non-small-cell lung cancer. J Med Imaging Radiat Oncol. 2010;54(6):554-61. NRP. [pmid: 21199434].
Weitberg, Liu L, Yashar J, Glicksman AS. Twelve-year follow-up of trimodality therapy for stage IIIA non-small cell lung cancer. J Exp Clin Cancer Res. 2001;20(3):335-40. NRP. [pmid: 11718211].
Werner-Wasik, Pequignot E, Leeper D, Hauck W, Curran W. Predictors of severe esophagitis include use of concurrent chemotherapy, but not the length of irradiated esophagus: a multivariate analysis of patients with lung cancer treated with nonoperative therapy. Int J Radiat Oncol Biol Phys. 2000;48(3):689-96. NRD. [pmid: 11020565].
Werner-Wasik, Paulus R, Curran WJ Jr, Byhardt R. Acute esophagitis and late lung toxicity in concurrent chemoradiotherapy trials in patients with locally advanced non-small-cell lung cancer: analysis of the radiation therapy oncology group (RTOG) database. Clin Lung Cancer. 2011;12(4):245-51. NRP. [pmid: 21726824].
Widder, Postmus D, Ubbels JF, Wiegman EM, Langendijk JA. Survival and quality of life after stereotactic or 3D-conformal radiotherapy for inoperable early-stage lung cancer. International Journal of Radiation Oncology Biology Physics. 2011;81(4):e291-e297. USD.
Willers, Wurschmidt F, Bunemann H, Heilmann HP. High-dose radiation therapy alone for inoperable non-small cell lung cancer--experience with prolonged overall treatment times. Acta Oncol. 1998;37(1):101-5. NRP. [pmid: 9572662].
Willner, Schmidt M, Kirschner J, Lang S, Borgmeier A, Huber RM, Flentje M. Sequential chemo- and radiochemotherapy with weekly paclitaxel (Taxol) and 3D-conformal radiotherapy of stage III inoperable non-small cell lung cancer. Results of a dose escalation study. Lung Cancer. 2001;32(2):163-71. NRP. [pmid: 11325487].
Winterhalder, Deschler-Marini S, Landmann C, Kann R, Passweg J, Herrmann R, Pless M. Vinorelbine plus low-dose cisplatinum with concomitant radiotherapy for the treatment of locally advanced or inoperable nonmetastasized non-small-cell lung cancer (stage I–IIIB): a phase II study. Radiother Oncol. 2004;73(3):321-4. NRP. [pmid: 15588877].
Wirth, Lucca J, Ostler P, Fidias P, Lynch C, Janne PA, Herbst RS, Johnson BE, Sugarbaker DJ, Mathisen DJ, Lukanich JM, Choi NC, Berman SM, Skarin AT. Induction docetaxel and carboplatin followed by weekly docetaxel and carboplatin with concurrent radiotherapy, then surgery in stage III non-small cell lung cancer: a Phase I study. Clin Cancer Res. 2003;9(5):1698-704. NRP. [pmid: 12738723].
Wisnivesky, Halm E, Bonomi M, Powell C, Bagiella E. Effectiveness of radiation therapy for elderly patients with unresected stage I and II non-small cell lung cancer. Am J Respir Crit Care Med. 2010;181(3):264-9. NRP. [pmid: 19892859].
Wisnivesky, Bonomi M, Henschke C, Iannuzzi M, McGinn T. Radiation therapy for the treatment of unresected stage I–II non-small cell lung cancer. Chest. 2005;128(3):1461-7. NRP. [pmid: 16162744].
Wolf, Faoro C, Goerg C, Pfab R, Havemann K, Kettner H. Paclitaxel and simultaneous radiation in the treatment of stage IIIA/B non-small cell lung cancer. Semin Oncol. 1996;23(6 Suppl 16):108-12. NRP. [pmid: 9007135].
Wolski, Bhatnagar A, Flickinger JC, Belani CP, Ramalingam S, Greenberger JS. Multivariate analysis of survival, local control, and time to distant metastases in patients with unresectable non-small-cell lung carcinoma treated with 3-dimensional conformal radiation therapy with or without concurrent chemotherapy. Clin Lung Cancer. 2005;7(2):100-6. NRP. [pmid: 16179096].
Wu, Jiang GL, Liao Y, Qian H, Wang LJ, Fu XL, Zhao S. Three-dimensional conformal radiation therapy for non-small-cell lung cancer: a phase I/II dose escalation clinical trial. Int J Radiat Oncol Biol Phys. 2003;57(5):1336-44. NRP. [pmid: 14630271].
Wu, Zhu H, Tang H, Li C, Xu F. Clinical Analysis of stereotactic body radiation therapy using extracranial gamma knife for patients with mainly bulky inoperable early stage non-small cell lung carcinoma. Radiation Oncology. 2011;6(1). NRI.
Wu, Bang YJ, Choi EK, Ahn YC, Kim YW, Lim TH, Suh C, Park K, Park CI. Phase I study of weekly docetaxel and cisplatin concurrent with thoracic radiotherapy in Stage III non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2002;52(1):75-80. NRP. [pmid: 11777624].
Wu, Xie Z, Wang ZN, Feng LP, Yang ZX. Efficacy of concurrent radio-chemotherapy and chemotherapy alone in the treatment of locally advanced non-small-cell lung cancer. 2005;27:502-4. FLA.
Wulf, Haedinger U, Oppitz U, Thiele W, Mueller G, Flentje M. Stereotactic radiotherapy for primary lung cancer and pulmonary metastases: a noninvasive treatment approach in medically inoperable patients. Int J Radiat Oncol Biol Phys. 2004;60(1):186-96. NRP. [pmid: 15337555].
Wurstbauer, Deutschmann H, Kopp P, Kranzinger M, Merz F, Nairz O, Studnicka M, Sedlmayer F. Nonresected non-small-cell lung cancer in Stages I through IIIB: accelerated, twice-daily, high-dose radiotherapy--a prospective Phase I/II trial with long-term follow-up. Int J Radiat Oncol Biol Phys. 2010;77(5):1345-51. NRP. [pmid: 19910140].
Wurstbauer, Weise H, Deutschmann H, Kopp P, Merz F, Studnicka M, Nairz O, Sedlmayer F. Non-small cell lung cancer in stages I–IIIB: Long-term results of definitive radiotherapy with doses >/= 80 Gy in standard fractionation. Strahlenther Onkol. 2010;186(10):551-7. NRP. [pmid: 20936459].
Xia, Li H, Sun Q, Wang Y, Fan N, Yu Y, Li P, Chang JY. Promising clinical outcome of stereotactic body radiation therapy for patients with inoperable Stage I/II non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2006;66(1):117-25. USD. [pmid: 16765528].
Xu, Wang J, Shen Y, Zhang H, Zhou Q. Phase I/II study of gemcitabine and oxaliplatin chemotherapy in combination with concurrent 3-D conformal radiotherapy for locally advanced non-small cell lung cancer. Zhongguo Fei Ai Za Zhi. 2006;9(4):362-8. NRP. [pmid: 21176457].
Yalman, Arican A, Karakoyun O, Karadogan I, Yurut V, Esassolak Denizli M, Haydaroglu A. Radical radiotherapy in advanced-stage non-small cell lung cancer: Evaluation of 332 cases. Journal of BUON. 1999;4(4):383-387. NRP.
Yamada, Kudoh S, Fukuda H, Nakagawa K, Yamamoto N, Nishimura Y, Negoro S, Takeda K, Tanaka M, Fukuoka M. Dose-escalation study of weekly irinotecan and daily carboplatin with concurrent thoracic radiotherapy for unresectable stage III non-small cell lung cancer. Br J Cancer. 2002;87(3):258-63. NRP. [pmid: 12177791].
Yamada, Soejima T, Ota Y, Sasaki R, Yoden E, Kanaoka N, Maruta T, Sugimura K. Radiotherapy for medically inoperable non-small cell lung cancer at clinical stage I and II. Tumori. 2003;89(1):75-9. NRI. [pmid: 12729366].
Yamamoto, Nakagawa K, Nishimura Y, Tsujino K, Satouchi M, Kudo S, Hida T, Kawahara M, Takeda K, Katakami N, Sawa T, Yokota S, Seto T, Imamura F, Saka H, Iwamoto Y, Semba H, Chiba Y, Uejima H, Fukuoka M. Phase III study comparing second- and third-generation regimens with concurrent thoracic radiotherapy in patients with unresectable stage III non-small-cell lung cancer: West Japan Thoracic Oncology Group WJTOG0105. J Clin Oncol. 2010;28(23):3739-45. NRP. [pmid: 20625120].
Yamamoto, Nishimura Y, Nakagawa K, Matsui K, Fukuoka M. Phase I/II study of weekly docetaxel dose escalation in combination with fixed weekly cisplatin and concurrent thoracic radiotherapy in locally advanced non-small cell lung cancer. Cancer Chemother Pharmacol. 2006;58(3):285-91. NRP. [pmid: 16416334].
Yang, Tsai CM, Wang LS, Lee YC, Chang CJ, Lui LT, Yen SH, Hsu C, Cheng AL, Liu MY, Chiang SC, Chen YM, Luh KT, Huang MH, Yang PC, Perng RP. Gemcitabine and cisplatin in a multimodality treatment for locally advanced non-small cell lung cancer. Br J Cancer. 2002;86(2):190-5. NRP. [pmid: 11870504].
Yang, Fan XW, Zhang GQ, Shan L. Efficacy and safety of chemotherapy combined with interstitial (125)I seed implantation brachytherapy in unresectable stage IIIa/IIIb non-small cell lung cancer. 2010;32:626-9. FLA.
Yano, Yokoyama H, Yoshino I, Tayama K, Asoh H, Hata K, Ichinose Y. Results of a limited resection for compromised or poor-risk patients with clinical stage I non-small cell carcinoma of the lung. J Am Coll Surg. 1995;181(1):33-7. NRI. [pmid: 7599768].
Yap, Lim WT, Foo KF, Hee SW, Leong SS, Fong KW, Eng P, Hsu AA, Wee J, Agasthian T, Koong HN, Tan EH. Induction concurrent chemoradiotherapy using Paclitaxel and Carboplatin combination followed by surgery in locoregionally advanced non-small cell lung cancer--Asian experience. Ann Acad Med Singapore. 2008;37(5):377-82. NRP. [pmid: 18536823].
Yendamuri, Komaki RR, Correa AM, Allen P, Wynn B, Blackmon S, Hofstetter WL, Rice DC, Roth JA, Swisher SG, Vaporciyan AA, Walsh GL, Mehran RJ. Comparison of limited surgery and three-dimensional conformal radiation in high-risk patients with stage I non-small cell lung cancer. J Thorac Oncol. 2007;2(11):1022-8. NRP. [pmid: 17975494].
Yeo, Cho MJ, Kim SY, Lim SP, Kim KH, Kim JS. Treatment outcomes of three-dimensional conformal radiotherapy for stage III non-small cell lung cancer. Cancer Res Treat. 2005;37(5):273-8. NRP. [pmid: 19956526].
Yokoyama, Kurita Y, Saijo N, Tamura T, Noda K, Shimokata K, Matsuda T. Dose-finding study of irinotecan and cisplatin plus concurrent radiotherapy for unresectable stage III non-small-cell lung cancer [seecomments]. Br J Cancer. 1998;78(2):257-62. NRP. [pmid: 9683303].
Yom, Liao Z, Liu HH, Tucker SL, Hu CS, Wei X, Wang X, Wang S, Mohan R, Cox JD, Komaki R. Initial evaluation of treatment-related pneumonitis in advanced-stage non-small-cell lung cancer patients treated with concurrent chemotherapy and intensity-modulated radiotherapy. Int J Radiat Oncol Biol Phys. 2007;68(1):94-102. NRP. [pmid: 17321067].
Yoo, Dupuy DE, Hillman SL, Fernando HC, Rilling WS, Shepard JA, Siegel BA. Radiofrequency ablation of medically inoperable stage IA non-small cell lung cancer: are early posttreatment PET findings predictive of treatment outcome?. AJR Am J Roentgenol. 2011;197(2):334-40. NRO. [pmid: 21785078].
Yoon, Hong YC, Park HJ, Lee JE, Kim SY, Kim JH, Lee SW, Park SY, Lee JS, Choi EK. The polymorphism and haplotypes of XRCC1 and survival of non-small-cell lung cancer after radiotherapy. Int J Radiat Oncol Biol Phys. 2005;63(3):885-91. NRP. [pmid: 16199318].
Yoshizawa, Tanaka J, Kagamu H, Maruyama Y, Miyao H, Ito K, Sato T, Iwashima A, Suzuki E, Gejyo F. Phase I/II study of daily carboplatin, 5-fluorouracil and concurrent radiation therapy for locally advanced non-small-cell lung cancer. Br J Cancer. 2003;89(5):803-7. NRP. [pmid: 12942108].
Yu, Sun XD, Li MH, Zhang JD, Yao CP, Liu S, Zhang Z. Involved-field three-dimensional conformal radiation treatment for stage III non-small-cell lung. 2006;28:526-9. FLA.
Yu, Liu YF, Yu JM, Liu J, Zhao Y, Hou M. Involved-field radiotherapy is effective for patients 70 years old or more with early stage non-small cell lung cancer. Radiother Oncol. 2008;87(1):29-34. NRP. [pmid: 18237795].
Yuan, Sun X, Li M, Yu J, Ren R, Yu Y, Li J, Liu X, Wang R, Li B, Kong L, Yin Y. A randomized study of involved-field irradiation versus elective nodal irradiation in combination with concurrent chemotherapy for inoperable stage III nonsmall cell lung cancer. Am J Clin Oncol. 2007;30(3):239-44. NRP. [pmid: 17551299].
Zaric, Perin B, Jovelic A, Lalic N, Secen N, Kopitovic I, Antonic M. Clinical risk factors for early complications after high-dose-rate endobronchial brachytherapy in the palliative treatment of lung cancer. Clin Lung Cancer. 2010;11(3):182-6. USD. [pmid: 20439194].
Zarogoulidis, Kontakiotis T, Hatziapostolou P, Fachantidou E, Delis D, Goutsikas J, Constantinidis TC, Athanasiadis A, Patakas D. A Phase II study of docetaxel and carboplatin in the treatment of non-small cell lung cancer. Lung Cancer. 2001;32(3):281-7. NRP. [pmid: 11390009].
Zatloukal, Petruzelka L, Zemanova M, Havel L, Janku F, Judas L, Kubik A, Krepela E, Fiala P, Pecen L. Concurrent versus sequential chemoradiotherapy with cisplatin and vinorelbine in locally advanced non-small cell lung cancer: a randomized study. Lung Cancer. 2004;46(1):87-98. NRP. [pmid: 15364136].
Zemlyak, Moore WH, Bilfinger TV. Comparison of survival after sublobar resections and ablative therapies for stage I non-small cell lung cancer. J Am Coll Surg. 2010;211(1):68-72. USD. [pmid: 20610251].
Zhang, Yu JM, Meng X, Yue JB, Feng R, Ma L. Prognostic value of serial [18F]fluorodeoxyglucose PET-CT uptake in stage III patients with non-small cell lung cancer treated by concurrent chemoradiotherapy. Eur J Radiol. 2011;77(1):92-6. NRP. [pmid: 19695804].
Zhang, Zheng Y, Yu P, Yu F, Zhang Q, Lv Y, Xie X, Gao Y. The combined treatment of CT-guided percutaneous 125I seed implantation and chemotherapy for non-small-cell lung cancer. J Cancer Res Clin Oncol. 2011;137(12):1813-22. NRP. [pmid: 21922327].
Zhao, West BT, Hayman JA, Lyons S, Cease K, Kong FM. High radiation dose may reduce the negative effect of large gross tumor volume in patients with medically inoperable early-stage non-small cell lung cancer. Int J Radiat Oncol Biol Phys. 2007;68(1):103-10. NRI. [pmid: 17363189].
Zhao, Wang L, Ji W, Wang X, Zhu X, Hayman JA, Kalemkerian GP, Yang W, Brenner D, Lawrence TS, Kong FM. Elevation of plasma TGF-beta1 during radiation therapy predicts radiation-induced lung toxicity in patients with non-small-cell lung cancer: a combined analysis from Beijing and Michigan. Int J Radiat Oncol Biol Phys. 2009;74(5):1385-90. NRP. [pmid: 19231104].
Zhao, Ji W, Zhang L, Ou G, Feng Q, Zhou Z, Lei M, Yang W, Wang L. Changes of circulating transforming growth factor-beta1 level during radiation therapy are correlated with the prognosis of locally advanced non-small cell lung cancer. J Thorac Oncol. 2010;5(4):521-5. NRP. [pmid: 20130485].
Zhou, Zheng JX. Hyperfractionated radiation therapy combined with concomitant chemotherapy for inoperable stage III non-small cell lung cancer: clinical analysis of 70 cases. 2004;24:841-2. 844. FLA.
Zhu, Wu R. Sequential and concurrent radiochemotherapy for stage III non-small cell lung cancer. Chinese Journal of Cancer Prevention and Treatment. 2009;16(14):1105-1107. FLA.
Zhu, Fan M, Wu KL, Zhao KL, Yang HJ, Chen GY, Jiang GL, Wang LJ, Zhao S, Fu XL. A phase II trial of accelerated hypofractionated three-dimensional conformal radiation therapy in locally advanced non-small cell lung cancer. Radiother Oncol. 2011;98(3):304-8. NRP. [pmid: 21345508].
Zhu, Yan TD, Glenn D, Morris DL. Radiofrequency Ablation of Lung Tumors: Feasibility and Safety. Annals of Thoracic Surgery. 2009;87(4):1023-1028. NRP. [pmid: 19324122].
Zierhut, Bettscheider C, Schubert K, van Kampen M, Wannenmacher M. Radiation therapy of stage I and II non-small cell lung cancer (NSCLC). Lung Cancer. 2001;34(Suppl 3()):S39-43. NRI. [pmid: 11740992].
Zimmermann, Geinitz H, Schill S, Grosu A, Schratzenstaller U, Molls M, Jeremic B. Stereotactic hypofractionated radiation therapy for stage I non-small cell lung cancer. Lung Cancer. 2005;48(1):107-14. OPP. [pmid: 15777977].
Zimmermann, Geinitz H, Schill S, Thamm R, Nieder C, Schratzenstaller U, Molls M. Stereotactic hypofractionated radiotherapy in stage I (T1-2 N0 M0) non-small-cell lung cancer (NSCLC). Acta Oncol. 2006;45(7):796-801. OPP. [pmid: 16982542].
Zinner, Komaki R, Cox JD, Glisson BS, Pisters KM, Herbst RS, Kies M, Liao Z, Hong WK, Fossella FV. Dose escalation of gemcitabine is possible with concurrent chest three-dimensional rather than two-dimensional radiotherapy: a phase I trial in patients with stage III non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2009;73(1):119-27. NRP. [pmid: 18556142].
Zwitter, Kovac V, Smrdel U, Strojan P. Gemcitabine, cisplatin, and hyperfractionated accelerated radiotherapy for locally advanced non-small cell lung cancer. J Thorac Oncol. 2006;1(7):662-6. NRP. [pmid: 17409933].