# Search Strategy

The following electronic databases were searched by a medical librarian for citations:

- MEDLINE® (January 1995 to December 12, 2011) yielded 2883 records
- EMBASE® (January 1995 to December 13, 2011) yielded 1318 records
- Cochrane Controlled Trials Register (through December 13, 2011) yielded 99 records
- Search update of all three databases during peer review: (December 14, 2011–July 25, 2012) yielded 348 records

## MEDLINE

### Stage I

“Carcinoma, Non-Small-Cell Lung”[Mesh] OR (“Lung Neoplasms”[Mesh] OR “lung cancer”) AND (“non-small-cell” OR “non-small cell” OR “non small cell”)

AND

“stage I” OR “stage one” OR “stage 1” OR T1N0M0 OR T2N0M0 OR early OR inoperable OR unoperable OR nonoperable OR decline* OR refuse*

AND

“Brachytherapy”[Mesh] OR “Protons”[Mesh] OR “Radiotherapy, Intensity-Modulated”[Mesh] OR “Radiotherapy, Conformal”[Mesh] OR “Ablation Techniques”[Mesh] OR “Radiotherapy”[Mesh] OR “radiotherapy “[Subheading] OR “radiofrequency ablation” OR (radiofrequency AND ablation) OR RFA OR radiotherapy OR radiation OR “external beam” OR “3D conformal” OR “3-D Conformal” OR “intensity modulated radiotherapy” OR IMRT OR brachytherapy OR “stereotactic radiotherapy” OR “stereotactic body radiotherapy” OR (“proton beam” AND (radiation OR therapy OR radiotherapy))

AND

English language/Humans as limits

### Advanced

“Carcinoma, Non-Small-Cell Lung”[Mesh] OR (“Lung Neoplasms”[Mesh] OR “lung cancer”) AND (“non-small-cell” OR “non-small cell” OR “non small cell”)

AND

“stage III” OR “stage 3” OR “stage three” OR “stage IIIa” OR “stage IIIb” OR “stage IV” OR “stage 4” OR “stage four” OR advanced

AND

“Brachytherapy”[Mesh] OR “Protons”[Mesh] OR “Radiotherapy, Intensity-Modulated”[Mesh] OR “Radiotherapy, Conformal”[Mesh] OR “Ablation Techniques”[Mesh] OR “Radiotherapy”[Mesh] OR “radiotherapy “[Subheading] OR “radiofrequency ablation” OR (radiofrequency AND ablation) OR RFA OR radiotherapy OR radiation OR “external beam” OR “intensity modulated radiotherapy” OR IMRT OR brachytherapy OR “stereotactic radiotherapy” OR “stereotactic body radiotherapy” OR (“proton beam” AND (radiation OR therapy OR radiotherapy)) OR “Stents”[Mesh] OR stent* OR ((“Debridement”[Mesh] OR debridement) AND (endoscopy OR endoscopic OR endobronchial))

AND

English language/Humans as limits

## EMBASE

### Stage I

‘non-small-cell lung cancer’/exp OR (‘lung neoplasms’/exp OR ‘lung cancer’/exp AND (‘non-small-cell’ OR ‘non-small cell’ OR ‘non small cell’ OR nsclc))

AND

“stage I” OR “stage one” OR “stage 1” OR T1N0M0 OR T2N0M0 OR early OR inoperable OR unoperable OR nonoperable OR decline* OR refuse*

AND

“radiofrequency ablation” OR (radiofrequency AND ablation) OR RFA OR radiotherapy OR radiation OR “external beam” OR “3D conformal” OR “3-D Conformal” OR “intensity modulated radiotherapy” OR IMRT OR brachytherapy OR “stereotactic radiotherapy” OR “stereotactic body radiotherapy” OR (“proton beam” AND (radiation OR therapy OR radiotherapy))

AND

English language/Humans as limits

AND NOT MEDLINE

### Advanced

‘non-small-cell lung cancer’/exp OR (‘lung neoplasms’/exp OR ‘lung cancer’/exp AND (‘non-small-cell’ OR ‘non-small cell’ OR ‘non small cell’ OR nsclc))

AND

‘stage iii’ OR ‘stage 3’ OR ‘stage three’ OR ‘stage iiia’ OR ‘stage iiib’ OR ‘stage iv’ OR ‘stage 4’ OR ‘stage four’ OR advanced

AND

‘radiofrequency ablation’/exp OR (‘radiofrequency’/exp AND ablation) OR rfa OR ‘radiotherapy’/exp OR ‘radiation’/exp OR ‘external beam’ OR ‘intensity modulated radiotherapy’/exp OR ‘imrt’/exp OR ‘brachytherapy’/exp OR ‘stereotactic radiotherapy’ OR ‘stereotactic body radiotherapy’/exp OR (‘proton beam’/exp AND (‘radiation’/exp OR ‘therapy’/exp OR ‘radiotherapy’/exp)) OR stent* OR (‘debridement’/exp AND (‘endoscopy’/exp OR endoscopic OR endobronchial))

AND

English language/Humans as limits

AND NOT MEDLINE

## COCHRANE

1. MeSH descriptor Carcinoma, Non-Small-Cell Lung explode all trees
2. (brachytherapy):ti,ab,kw or (radiotherapy):ti,ab,kw or (ablation):ti,ab,kw or (radiation):ti,ab,kw or (stereotactic):ti,ab,kw
3. (#1 AND #2)
4. (stent*):ti,ab,kw or (proton):ti,ab,kw or (radiofrequency):ti,ab,kw or (debridement):ti,ab,kw
5. (( #1 AND #4 )
6. (#3 OR #5)

## Search Strategy For Gray Literature

### Regulatory Information

#### FDA (Drugs@FDA)

Source: http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfpmn/pmn.cfm

Date searched: 5/30/12

Search strategy: “RF 3000,” RF 3000 Radiofrequency Ablation System (Boston Scientific); “RITA StarBurst,” RITA StarBurst Radiofrequency Ablation System (Angiodynamics (formerly RITA)); “Elektrotom 106,” Berchtold Elektrotom 106 HFTT (Berchtold Corp.); “OncoSeed,” OncoSeed(Oncura), “Best Iodine 125,” Best Iodine-125 (Best Medical International, Inc); “Best Palladium 103 Seeds” Best Palladium-103 Seeds(Best Medical International, Inc.); “VariSource HDR afterloader,” VariSource HDR afterloader (Varian Medical Systems); “GammaMedplus afterloader,” GammaMedplus (Varian Medical Systems); “Clinac Linear Accelerator,” Clinac Linear Accelerator(Varian Medical Systems); “Varian Trilogy system,” Trilogy system (Varian Medical Systems); “Varian TrueBeam,” TrueBeam (Varian Medical Systems); “Novalis,” Novalis Tx (Varian Medical Systems); “ONCOR,” ONCOR Impression & ONCOR Expression (Siemens Medical Solutions USA, Inc); “Primatom,” Primatom (Siemens Medical Solutions USA, Inc); “Optivus PBTS,” Proton Beam Therapy System (PBTS) (Optivus); “PT2 Varian Proton Therapy System,” PT2 Varian Proton Therapy System (Varian Medical Systems); “Proteus One,” Proteus One (IBA Particle Therapy); “Hood stent,” Hood stent with rings (Hood Laboratories); “Plyflex stent, Ultraflex Metallic stents,” Plyflex stent & Ultraflex Metallic stents (Boston Scientific); “Bryan Dumon,” Bryan-Dumon Series II (Bryan Corporation); “Nd-YAG Laser,” Nd-YAG Laser (Lee Laser Inc., Crystal Laser, & PowerTechnology Inc.)

Records: 0

### Clinical Trial Registries

#### ClinicalTrials.gov

Source: http://clinicaltrials.gov/

Date searched: 5/30/12

Search strategy: (“NSCLC” OR “non-small cell”) AND ((“stage I”) OR (“stage III” OR “stage IV”)) | Closed Studies | Exclude Unknown | Phase 3, 4

Records: 81

Unpublished records: 1: NCT00687986

### Conference Papers and Abstracts

- American Society of Clinical Oncology
- American Society for Radiation Oncology

Date searched: 5/30/12

Search strategy: (“NSCLC” OR “non-small cell”) AND (“stage I” OR “stage III” OR “stage IV”)

Records: 493

### Manufacturer Database

- Source: Covidien
  Date posted: 5/24/12
  Search strategy: Not applicable
  Records: 95
- Source: Accuray
  Date posted: 5/24/12
  Search strategy: Not applicable
  Records: 74
- Source: Elekta
  Date posted: 5/24/12
  Search strategy: Not applicable
  Records: 11
- Source: Loma Linda
  Date posted: 5/24/12
  Search strategy: Not applicable
  Records: 5