# Abbreviations

3DRT: Three-dimensional radiation therapy
ACE-27: Adult Co-Morbidity Evaluation-27 scoring system
BED: Biologically Effective Dose
CGE: Cobalt Gray equivalent
CI: Confidence interval
CSS: Cancer-specific survival
CT: Computed Tomography
CTC: Common Toxicity Criteria
CTCAE: Common Terminology Criteria for Adverse Events
DSS: Disease-specific survival
ECOG: Eastern Cooperative Oncology Group
EORTC: European Organization for Research and Treatment of Cancer
FACT-G: Functional Assessment of Cancer Therapy- General
FACT-L: Functional Assessment of Cancer Therapy- Lung
FDG: Fluorodeoxyglucose
FEV: Forced expiratory volume
FRS: Fractions
GY: Gray
IMRT: Intensity-modulated radiotherapy
KPS: Karnofsky performance status
LCS: Lung Cancer Subscale
LCT: Local control
LENT-SOMA: Late Effects Normal Tissue Task Force -Subjective, Objective, Management, Analytic scales
MeV: Million electron volts
mos: Months
N: Number
NA: Not applicable
NOS: Not otherwise specified Non–small-cell Lung Cancer
NR: Not reported
NSCLC: Non–small-cell lung cancer
OS: Overall Survival
PCS: Physical Component Summary
PDT: Photodynamic therapy
PS: Performance status
Pts: Patients
QLQ: Quality of life Questionnaire
QOL: Quality of life
RFA: Radiofrequency ablation
RT: Radiation Therapy
RTOG: Radiation Therapy Oncology Group
Rx: Treatment
SAS: Single arm study
SBRT: Stereotactic body radiotherapy
UICC: Union Internationale Contre le Cancer
WHO: World Health Organization
YAGL: Yttrium aluminum garnet laser