# Peer Reviewers

- Peter Creticos, M.D.
  Johns Hopkins University
  Baltimore, MD
- Ronald Rabin, M.D.
  U.S. Food and Drug Administration, Center for Biologics Evaluation and Research
  Rockville, MD
- Jay Slater, M.D.
  Children’s Hospital
  Washington, DC
- Sarah K. Wise, M.D.
  Emory University
  Atlanta, GA