# Technical Expert Panel

- Michael Blaiss, M.D.
  Representing the American College of Allergy, Asthma & Immunology
  University of Tennessee
  Germantown, TN
- David A. Brown, M.D.
  Allergy Partners
  Asheville, NC
- Linda S. Cox, M.D.
  Nova Southeastern University College of Osteopathic Medicine
  Ft. Lauderdale-Davie, FL
- Berrylin J. Ferguson, M.D.
  University of Pittsburgh School of Medicine
  Pittsburgh, PA
- Ira Finegold, M.D.
  Representing the American College of Allergy, Asthma & Immunology
  New York, NY
- Bryan Leatherman, M.D.
  Representing the American Academy of Otolaryngology
  Coastal Ear, Nose, and Throat
  Gulfport, MS
- Harold Nelson, M.D.
  Department of Medicine
  National Jewish Health
  Denver, CO