# Key Informants

- David A. Brown, M.D.
  Allergy Partners
  Asheville, NC
- Bradley E. Chipps, M.D.
  Capital Allergy and Respiratory Disease Center
  Sacramento, CA
- Linda S. Cox, M.D.
  Nova Southeastern University College of Osteopathic Medicine
  Ft Lauderdale-Davie, FL
- Berrylin J. Ferguson, M.D.
  University of Pittsburgh School of Medicine
  Pittsburgh, PA
- Harold Nelson, M.D.
  National Jewish Health
  Denver, CO
- Marcus Shaker M.D.
  Dartmouth-Hitchcock Medical Center.
  Lebanon, NH