# Acknowledgments

The Evidence-based Practice Center acknowledges Peter Creticos, Franklin Adkinson, and Daniela Vollenweider for their significant role during the initial phases (refinement and development of the protocol) of this project and for their invaluable assistance reviewing articles during this period.