# Conclusion

In summary, we found sufficient evidence to support the effectiveness and safety of subcutaneous and sublingual immunotherapy for treatment of allergic rhinitis and asthma, particularly using single allergen immunotherapy regimens in adults and children. Strengthening the evidence for the effectiveness and safety of multiple allergen regimens should be high priority for future studies. There are far fewer pediatric studies than adult studies; hence the evidence is less strong for the pediatric population. Additional pediatric studies may strengthen the evidence the effectiveness and safety of allergen immunotherapy in the pediatric population. When comparing subcutaneous to sublingual immunotherapy, the existing evidence is insufficient and inconclusive. Additional trials are needed to establish the efficacy and safety of these two interventions compared directly, in the usual care settings, given the expectation of differences in adherence.