# Evidence Tables for Sublingual Immunotherapy Versus Subcutaneous Immunotherapy

TABLE F1 STUDY CHARACTERISTICS SCIT vs SLIT

TABLE F2 PATIENT CHARACTERISTICS- SCIT vs SLIT

TABLE F3 INTERVENTION CHARACTERISTICS- SCIT vs SLIT

TABLE F4 QUALITY ASSESSMENT- SCIT vs SLIT

TABLE F5 ASTHMA AND ASTHMA COMBINED SCORES- SCIT vs SLIT

TABLE F6 RHINITIS AND RHINOCONJUNCTIVITIS SYMPTOM SCORES SCIT vs SLIT

TABLE F7 OTHER CLINICAL SCORES, SCIT vs SLIT

TABLE F8 MEDICATION SCORES SCIT vs SLIT

TABLE F9 COMBINED SYMPTOM MEDICATION SCORES, SCIT vs SLIT

TABLE F10 ALLERGY CHALLENGES AND FUNCTIONAL OUTCOMES: PFT SCIT vs SLIT

TABLE F11 BIOMARKERS – IgE- SCIT vs SLIT

TABLE F12 SAFETY SCIT vs SLIT

## REFERENCES SCIT VS. SLIT APPENDIX

1 Mauro M, Russello M, Incorvaia C, Gazzola GB, Di Cara G, Frati F. Comparison of efficacy, safety and immunologic effects of subcutaneous and sublingual immunotherapy in birch pollinosis: a randomized study. Eur Ann Allergy Clin Immunol. 2007;39(4):119-22. [pmid: 17523385].
2 Piazza I, Bizzaro N. Humoral response to subcutaneous, oral, and nasal immunotherapy for allergic rhinitis due to Dermatophagoides pteronyssinus. Ann Allergy. 1993;71(5):461-9. [pmid: 7755664].
3 Tahamiler R, Saritzali G, Canakcioglu S, Ozcora E, Dirican A. Comparison of the long-term efficacy of subcutaneous and sublingual immunotherapies in perennial rhinitis. ORL J Otorhinolaryngol Relat Spec. 2008;70(3):144-50. [pmid: 18391573].
4 Khinchi MS, Poulsen LK, Carat F, Andre C, Hansen AB, Malling HJ. Clinical efficacy of sublingual and subcutaneous birch pollen allergen-specific immunotherapy: a randomized, placebo-controlled, double-blind, double-dummy study. Allergy. 2004;59(1):45-53. [pmid: 14674933].
5 Eifan A, Akkoc T, Yildiz A, et al. Clinical efficacy and immunological mechanisms of sublingual and subcutaneous specific immunotherapy in asthmatic/rhinitis children sensitised to house-dust-mite: an open randomised controlled study. Allergy. 2010.
6 Mungan D, Misirligil Z, Gurbuz L. Comparison of the efficacy of subcutaneous and sublingual immunotherapy in mite-sensitive patients with rhinitis and asthma--a placebo controlled study. Ann Allergy Asthma Immunol. 1999;82(5):485-90. [pmid: 10353581].
7 Yukselen A, Kendirli SG, Yilmaz M, Altintas DU, Karakoc GB. Effect of One-Year Subcutaneous and Sublingual Immunotherapy on Clinical and Laboratory Parameters in Children with Rhinitis and Asthma: A Randomized, Placebo-Controlled, Double-Blind, Double-Dummy Study. International Archives of Allergy and Immunology. 2011;157(3):288-298. [pmid: 22041501].
8 Keles S, Karakoc-Aydiner E, Ozen A, et al. A novel approach in allergen-specific immunotherapy: combination of sublingual and subcutaneous routes. J Allergy Clin Immunol. 2011;128(4):808-815. e7. [pmid: 21641635].