# Screening and Data Abstraction Forms

Abstract Review Form

Appendix B shows the forms utilized by the team to revise the studies and abstract the data required for each study. All the forms were filled and submitted by two independent reviewers during the different stages of the process.

Article Review Form

Appendix B shows the forms utilized by the team to revise the studies and abstract the data required for each study. All the forms were filled and submitted by two independent reviewers during the different stages of the process.

Study Design Triage Form

Appendix B shows the forms utilized by the team to revise the studies and abstract the data required for each study. All the forms were filled and submitted by two independent reviewers during the different stages of the process.

Inclusion and Exclusion Criteria Form

Appendix B shows the forms utilized by the team to revise the studies and abstract the data required for each study. All the forms were filled and submitted by two independent reviewers during the different stages of the process.

Study Characteristics Form

Appendix B shows the forms utilized by the team to revise the studies and abstract the data required for each study. All the forms were filled and submitted by two independent reviewers during the different stages of the process.

Intervention Characteristics Form

Appendix B shows the forms utilized by the team to revise the studies and abstract the data required for each study. All the forms were filled and submitted by two independent reviewers during the different stages of the process.

Primary Outcomes Form

Appendix B shows the forms utilized by the team to revise the studies and abstract the data required for each study. All the forms were filled and submitted by two independent reviewers during the different stages of the process.

SECONDARY OUTCOMES

Appendix B shows the forms utilized by the team to revise the studies and abstract the data required for each study. All the forms were filled and submitted by two independent reviewers during the different stages of the process.

Safety Form

Appendix B shows the forms utilized by the team to revise the studies and abstract the data required for each study. All the forms were filled and submitted by two independent reviewers during the different stages of the process.

Quality Form for Trials

Appendix B shows the forms utilized by the team to revise the studies and abstract the data required for each study. All the forms were filled and submitted by two independent reviewers during the different stages of the process.