# Search Strategy

## PubMed (6498)

(allergen-specific immunotherapy[tiab] OR allergen immunotherapy[tiab] OR immunotherapy[tiab] OR immunotherapy[mesh] OR immunotherap*[tiab]) AND ((rhinitis[mh] OR rhinitis[tiab] OR hay fever[mh] OR hay fever[tiab] OR rhinoconjunctivitis[tiab] OR conjunctivitis[mh] OR “allergic conjunctivitis”[tiab] OR pollinosis[mh] OR pollinosis[tiab] OR pollenosis[tiab] OR asthma[mh] OR asthma[tiab]) NOT (“occupational diseases”[mh] OR “trachoma”[mh])) NOT (animals[mh] NOT humans[mh])

1 | allergen-specific immunotherapy[tiab] OR allergen immunotherapy[tiab] OR immunotherapy[tiab] OR immunotherapy[mesh] OR immunotherap*[tiab]
2 | rhinitis[mh] OR rhinitis[tiab] OR hay fever[mh] OR hay fever[tiab] OR rhinoconjunctivitis[tiab] OR conjunctivitis[mh] OR “allergic conjunctivitis”[tiab] OR pollinosis[mh] OR pollinosis[tiab] OR pollenosis[tiab] OR asthma[mh] OR asthma [tiab]
3 | “occupational diseases”[mh] OR “trachoma”[mh]
4 | 2 NOT 3
5 | (animals[mh] NOT humans[mh])
6 | 1 AND 4
7 | 6 NOT 5

## EMBASE (9327)

(‘immunotherapy’/exp OR desensiti*ation) AND (‘rhinitis’/exp OR ‘allergic rhinitis’/exp OR ‘hay’/exp AND ‘fever’/exp OR ‘rhinoconjunctivitis’/exp OR ‘conjunctivitis’/exp OR ‘allergic conjunctivitis’/exp OR ‘asthma’/exp) AND [humans]/lim AND [embase]/lim

1 | ‘immunotherapy’/exp OR desensiti*ation
2 | ‘rhinitis’/exp OR ‘allergic rhinitis’/exp OR ‘hay’/exp AND ‘fever’/exp OR ‘rhinoconjunctivitis’/exp OR ‘conjunctivitis’/exp OR ‘allergic conjunctivitis’/exp OR ‘asthma’/exp
3 | [humans]/lim
4 | embase]/lim
5 | 3 AND 4
6 | 1 AND 2 AND 5

## COCHRANE (840)

Immunotherapy AND (rhinitis OR allergic rhinitis OR rhinoconjunctivitis OR conjunctivitis OR allergic conjunctivitis OR asthma)

## LILACS (99)

Immunotherapy AND (rhinitis OR allergic rhinitis OR rhinoconjunctivitis OR conjunctivitis OR allergic conjunctivitis OR asthma