# Results

## Search Results

Figure 4 summarizes the results of our literature search. Our search retrieved 2,028 unique records. After reviewing the titles and abstracts, we considered 142 articles as potentially relevant and we reviewed the full text of each article for eligibility (see Appendix C for a list of the excluded articles). We included a total of 12 studies (in 18 publications) in this review.12,17,32,34,41-48 One manuscript45 conducted additional analyses among the subjects included in another manuscript by Kuo et al.16 Two manuscripts49,50 conducted additional analyses among the subjects included in the manuscript by Rao et al.17 Two abstracts46,51 reported on the same patient population. One manuscript34 previously appeared in two abstracts.52,53

Figure 4 Summary of literature search, with numbers of articles involved in each search step

* Total may exceed number in corresponding box, as articles could be excluded for more than one reason at this level.

Summary of literature: The figure is a summary of the literature, showing the search flow of the literature search. The overall structure is a vertical flow chart. The first box is the electronic databases, showing 1751 titles from PubMed and 1033 from EMBASE. The next box is total retrieved, which is 2788. A side box shows more added to the search via Handsearching, which is 4. Then, a side box showing removal of 760 duplicates is followed by the Title Review box, which has 2028 titles. A side box with Excluded shows 1267 excluded titles from the title review. Then, the abstract review of 761 excluded 619 which is shown in the next box and side box. The next box is article review of 142, and a side box of 124 excluded. The last box is the included studies, which is 12 studies in 18 publications. Two boxes are off of the excluded from abstract review and from article review and each show the reasons for exclusion. The reasons for exclusion at abstract review show as 274 for no original data, 265 for no subjects with suspected gastroparesis or constipation, 261 for does not evaluate wireless motility capsule that measures pH, pressure, motility, or transit time, 54 for no human subjects, 20 for does not include an adult population, and 31 for other reason. The reasons for exclusion at the article review level box shows 16 for no original data, 27 for no subjects with suspected gastroparesis of slow-transit constipation, 55 for does not evaluate the wireless motility capsule, 51 for does not have an appropriate comparison group, 8 for no outcome of interest, 2 for not adult population, 9 for does not apply to a key question, and 13 for other reason.

Seven studies (10 publications) evaluated the wireless motility capsule test among patients with gastroparesis,12,16,34,41-45,52,53 and nine studies (14 publications) evaluated the wireless motility capsule test among patients with slow-transit constipation.12,17,32,34,42,44,46-53

We identified four protocols from our search of ClinicalTrials.gov. We were able to match one protocol to a published manuscript using the NCT number32,54 and matched two others based on the study descriptions.16,17,55,56 We were unable to match the fourth protocol to any published study and the ClinicalTrials.gov website did not post results.57 This study compares the gastric emptying time as measured by the wireless motility capsule with that measured by gastric scintigraphy in patients over age 64 years.

## Study Design Characteristics

We included a total of 12 studies from 18 publications (see Appendix D, Evidence Table 1).12,16,17,32,34,41-53 Seven studies were prospective,16,17,32,41,43,47,48 Four studies were retrospective,12,34,42,44 and one did not specify a study design.46 Five of the prospective studies occurred at multiple study centers,16,17,32,43,47 one occurred at a single center,48 and the other prospective studies did not report the number of study locations. All prospective studies applied the tests concurrently. One of the retrospective studies involved chart review from multiple centers12 with the remainder using information from single centers.34,42,44 Six studies were in meeting abstracts,41-44,46,47 the remainder were in peer-reviewed publications.

All studies that reported the study location occurred in the United States (U.S.).12,16,17,32,34,41,43,44 One study took place in multiple countries including the U.S.32 All studies that reported the location of recruitment occurred in tertiary centers.12,17,34,41-44,48

Three studies reported the start year of recruitment.12,16,34 One began recruitment in 2005^16^ with the other two starting recruitment in 2007.^12,34^ Length of followup for the prospective studies and those with unspecified designs included the day of the testing only,41,43,44,46,51 3 days,16 5 days,47,48 14 days,32 and 21 days.17

Prospective studies included patients with known gastroparesis16,41,43 or constipation.17,32,48 Four retrospective studies included patients with suspected gastroparesis or constipation12,34,42,44 and one included patients with known constipation exclusively.46 Six of the prospective studies also included patients without gastroparesis or constipation,16,17,41,43,47,48 whereas one study included only patients with known constipation.32 Three studies that included patients with constipation used the Rome III criteria as inclusion criteria.17,32,48 Two studies reported age restrictions. One allowed patients 18 to 80 years of age32 and two others included patients older than 65 years of age.47,48

## Study Population Characteristics

No gender restrictions were made in the inclusion criteria, although the majority of participants with gastroparesis or constipation were female (Appendix D, Evidence Table 2). The mean age was 40 or greater in all studies that reported an average.12,17,32,34,46-48 Three studies reported on race or ethnicity.16,32,34 Greater than 80 percent of the participants were white in these studies. No study reported a measure of weight, blood sugar, or smoking status at baseline. Two studies reported on the percent of patients with diabetes.12,45 Fifteen and 37 percent had diabetes. Two studies reported on defecatory dysfunction.12,46 Twenty of 32 subjects had defecatory dysfunction in one study46 and in another study 64 percent of patients with had defecatory dysfunction.12 Studies rarely reported use of medications such as prokinetics, opiates, antidepressants, proton pump inhibitors, and laxatives, prior to and during the studies. Diagnostic testing prior to the study included scintigraphy12,16,34,43 and ROM.12,34

## Characteristics of Diagnostic Tests

In Tables 2, 3, and 4, we summarized the characteristics of the tests the studies used, taking into consideration how the evaluation of gastrointestinal motility is dependent on multiple factors, including not only the type of test but also the specific protocol employed (Appendix D, Evidence Table 3). The specific protocols these studies employed were often not standardized. We detailed the characteristics of the gastric scintigraphy tests in Table 2. We detailed the characteristics of wireless motility capsule testing for gastroparesis in Table 3. We detailed the characteristics of ROM testing in Table 4. Only two abstracts reported on antroduodenal manometry testing, and both provided limited information regarding study characteristics. No included studies reported on colonic manometry.

Table 2 Characteristics of gastric scintigraphy testing in studies of patients with symptoms of possible gastroparesis

Author, Year | Duration of Test | Tougas Protocol^*^ | Patients Off Tobacco at Time of Test | Patients Off Prokinetics at Time of Test | Patients Off Opiates at Time of Test | Patients Off Antidepressants at Time of Test
Rao, 2011^34^ | NR | NR | NR | NR | NR | NR
Kuo, 2008^16^ | 4 hours | Yes | Yes | Yes | Yes | No
Brun, 2011^41^ [abstract] | 4 hours | Yes | NR | NR | NR | NR
Mysore, 2010^53^ [earlier version of study34] | NR | NR | NR | NR | NR | NR
Lee, 2010^42^ [abstract] | 4 hours | Yes | NR | NR | NR | NR
Reddymasu, 2010^43^ [abstract] | 4 hours | Yes | NR | NR | NR | NR
Lee, 2012^45^ | 4 hours | Yes | NR | Yes | Yes | NR

NR = not reported

* The Tougas protocol refers to a 4-hour solid state gastric scintigraphy protocol agreed upon by consensus of the American Neurogastroenterology and Motility Society and the Nuclear Medicine Society.21

Table 3 Characteristics of WMC testing in studies of patients with symptoms of possible gastroparesis or slow-transit constipation

Author, Year | Criteria for Abnormal | Standardized Meal | Type of Meal | Ensure ^®^ Challenge | Off Tobacco at Time of Test | Off Prokinetics at Time of Test | Off Opiates at Time of Test | Off Anti-Depressants at Time of Test | Off PPIs at Time of Test | Was Another Study Referenced in Lieu of Providing Details Within Current Study?
Kuo, 2011^12^ | 5 hours | NR | NR | NR | NR | NR | Yes | No | Yes | Yes16,17
Rao, 2011^34^ | 5 hours | Yes | Bar | NR | NR | NR | Yes | No | Yes | Yes16,17,32
Camilleri, 2010^32^ | 5 hours | Yes | Egg Beaters ^®^ | Yes | NR | Yes | Yes | Yes | Yes | Yes17
Saad, 2010^50^ [Sub-analysis of data17] | NR | Yes | Bar | Yes | NR | Yes | NR | No | Yes | Yes17
Hasler, 2009^49^ [Sub-analysis of data17] | NR | Yes | Bar | Yes | NR | Yes | Yes | No | Yes | No
Rao, 2009^17^ | NR | Yes | Bar | Yes | NR | Yes | NR | No | Yes | No
Kuo, 2008^16^ | NR^*^ | Yes | Egg Beaters ^®^ | Yes | Yes | Yes | Yes | No | Yes | No
Brun, 2011^41^ [abstract] | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Mysore, 2010^53^ [earlier version of study34] | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Lee, 2010^42^ [abstract] | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Reddymasu, 2010^43^ [abstract] | Gastric cph < 73 | NR | NR | NR | NR | NR | NR | NR | NR | NR
Paulson, 2009^51^ | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Lee, 2009^44^ [abstract] | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Rao, 2009^46^ [abstract] | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
Rao, 2009^47^ [abstract] | NR | Yes | Bar | Yes | NR | NR | NR | NR | NR | NR
Lee, 2012^45^ | 5 hours | Yes | Egg Beaters ^®^ | Yes | NR | Yes | Yes | NR | Yes | Yes16
Rao, 2012^48^ | 5 hours | Yes | Bar | NR | NR | Yes | NR | NR | Yes | No

cph = contractions per hour; NR = not reported; PPI = proton pump inhibitor

* Reference article that came up with 5 hour criteria.

Table 4 Characteristics of ROM testing in studies of patients with symptoms of slow-transit constipation

Author, Year | Markers Swallowed | Type of Markers Were Used | Timing of Ingestion | Days Imaging Studies Were Taken | Method of Analysis | Considered Prolonged Colon Transit | Was Another Study Referenced in Lieu of Providing Details?
Kuo, 2011^12^ | Historically by chart review | ROM | NR | NR | NR | NR | Not referenced
Rao, 2011^34^ | NR | ROM | NR | NR | NR | Retention of ≥6 ROM at 120 hrs was defined as abnormal colonic transit | Yes17,58
Camilleri, 2010^32^ | Yes | ROM | Ingestion of 24 ROM on 3 consecutive days | Abdominal x rays taken on day 4 and day 7 (144 hours after ingestion of first markers) | Metcalf method= Count number and distribution of markers. Sum the number of markers visualized on day 4 and day 7 x rays and equating 1 marker to 1 hr of colonic transit time | Colonic transit time greater than 67 hrs is considered delayed | Yes59
Saad, 2010^50^ Sub-analysis of data17 | Yes | ROM | Ingestion of 24 ROM | Abdominal x-rays taken on day 2 and day 5 after ingestion of first markers | See reference | Retention of > 20% of ROM after 5 days | Yes60
Hasler, 2009^49^ Subset of study17 | Yes | ROM^*^ | Ingestion of 24 ROM (one capsule) | NR | NR | NR | Yes17
Rao, 2009^17^ | Yes | ROM^*^ | Ingestion of 24 ROM (one capsule) | Abdominal x ray 48 hrs and 5 days (120 hrs) after ingestion | Radiographs were reviewed at each location. All radiographs were reviewed by 2 independent blinded investigators. | Retention of > 5 markers at day 5 was considered abnormal | Yes58,60
Mysore, 2010^53^ [abstract] | Yes | NR | NR | NR | NR | NR | Not referenced
Rao, 2009^46^ [abstract] | Yes | NR | NR | NR | NR | NR | Not referenced
Rao, 2012^48^ | Yes | ROM^*^ | Ingestion of 24 ROM (one capsule) | Day 5 | Radiographs on day 5 were reviewed | Retention of > 5 markers at day 5 was considered abnormal | Yes58

NR = not reported; ROM = radiopaque markers

* Sitzmarks ^®^, Konsyl Pharmaceuticals; Fort Worth, TX.

## KQ 1 Evaluation of Gastric Dysmotility: WMC Alone Versus Other Diagnostic Tests

### Key Points

- The diagnostic accuracy of WMC is similar to scintigraphy. The sensitivity of WMC compared with the reference standard of a clinical diagnosis of gastroparesis ranged from 65 to 68 percent and the specificity ranged from 82 to 87 percent. The sensitivity of gastric scintigraphy compared with a clinical diagnosis of gastroparesis ranged from 34 to 44 percent and the specificity ranged from 93 to 94 percent. Sensitivity of the wireless motility capsule compared with gastric scintigraphy ranged from 59 to 86 percent and specificity ranged from 64 to 81 percent. (Strength of evidence [SOE]: Low)
- Transit data obtained via WMC correlate well with scintigraphic gastric emptying data. (SOE: Low)
- Pressure profiles obtained via WMC add to the diagnostic accuracy. Scintigraphy does not measure pressure patterns. (SOE: Low)
- Information derived from WMC testing alters management in patients with suspected gastroparesis (50 to 69 percent change in management for medicine, diet, or surgery). (SOE: Low)
- WMC testing may reduce the need for other testing, but this conclusion was based on one study with a high risk of bias. WMC testing may not reduce the need for anorectal manometry. (SOE: Low)
- Harms associated with WMC were minimal. While studies did not report any major safety issues, conclusions about harms will likely change with new evidence. (SOE: Low)
- The SOE was insufficient regarding the effect of WMC testing on patient-centered outcomes, as no studies addressed this type of outcome.
- The SOE was insufficient for the comparison of WMC with antroduodenal manometry in patients with suspected gastroparesis, as we did not find any studies evaluating this comparison.
- The SOE was insufficient for the comparison of WMC with endoscopy in patients with suspected gastroparesis, as we did not find any studies evaluating this comparison.

### WMC Versus Gastric Scintigraphy

#### Diagnostic Accuracy

We found seven studies with 560 total patients that examined this outcome for this comparison (Tables 5 and 6 and Figure 5).12,16,34,41,43-45 Three of these studies appeared as abstracts only.41,43,44 These studies defined diagnostic accuracy in various ways. Two studies, one of which appeared as an abstract only,43 included subjects with and without gastroparesis and evaluated the sensitivity and specificity of the wireless motility capsule and gastric scintigraphy compared with clinical gastroparesis. The sensitivity of wireless motility capsule ranged from 65 to 68 percent and the specificity ranged from 82 to 87 percent. The sensitivity of gastric scintigraphy compared with clinical gastroparesis ranged from 34 to 46 percent and the specificity ranged from 93 to 94 percent.

Table 5 Diagnostic accuracy of WMC compared with gastric scintigraphy in the evaluation of gastroparesis comparing patients with known gastroparesis with known non-diseased controls

Author, Year | Definition for GP – WMC | Definition for GP - GES | Total N | Sensitivity of WMC Compared With Clinical GP | Specificity of WMC Compared With Clinical GP | Sensitivity of GES Compared With Clinical GP | Specificity of GES Compared With Clinical GP | Correlation Between WMC and GES, (95% CI) | AUC, (95% CI)
Kuo, 2008^16^ | Threshold NR; abrupt pH rise (usually >3 pH units) from gastric baseline to a pH >4 as determined by software and 2 reviewers | >10% of meal retained after 4 hr | 61 patients with GP 87 subjects without GI dysmotility | 65%^*^ | 87%^*^ | 34% (2-hr), 44% (4-hr)^*^ | 93%^*^ | 0.63 (0.50-0.75) (2-hr) 0.73 (0.61-0.82) (4-hr) | 0.83 (0.74–0.90) (WMC) 0.79 (0.71–0.88) (GES, 2-hr) 0.82 (0.77–0.91) (GES, 4-hr)
Reddymasu, 2010^43^ [abstract] | Motility criteria: gastric cph < 73 or frequency of gastric contractions > 100 mm Hg being less than 2/hr | >10% of meal retained after 4 hr | 41 patients with GP 66 subjects without GI dysmotility | 68% (motility criteria: 88%)^*^ | 82% (motility criteria: 30%)^*^ | 46%^*^ | 94%^*^ | NR | NR

AUC = area under the curve; CI = confidence interval; cph = contractions per hour; GES = gastric scintigraphy; GI = gastrointestinal; GP = gastroparesis; hr = hours; mm Hg = millimeters mercury; NR = not reported; WMC = wireless motility capsule

* Numerator and denominator not available.

Table 6 Diagnostic accuracy of WMC compared with gastric scintigraphy in the evaluation of gastroparesis including only patients with known or suspected gastroparesis

Author, Year | Definition for GP – WMC | Definition for GP- GES | N Analyzed With GP | Sensitivity of WMC Compared With Symptoms | Specificity of WMC Compared With Symptoms | Sensitivity of GES Compared With Symptoms | Sensitivity of WMC Compared With GES | Specificity of WMC Compared With GES | Concordance of WMC and GES
Kuo, 2011^12^ | Emptying time > 5 hr | Based on result of prior testing | 83 with suspected GI dysmotility | 24/52 (46%) | 19/28 (68%) | 17/44 (39%) | 10/17 (59%) | 18/28 (64%) | 17/45 (35%)
Rao, 2011^34^ | NR | >10% of meal retained after 4 hr | 36 suspected | 24/36 (66%) | NR | 15/36 (42%) | 12/15 (80%) | 17/21 (81%) | 29/36 (81%)
Lee, 2009^44^ [abstract] | NR | NR | 32 suspected GI dysmotility | NR | NR | NR | 9/14 (64%) | 8/10 (80%) | NR
Lee, 2012^45^ | WMC emptying time > 5 hr | >10% of meal retained after 4 hr | 43 suspected | 26/43 (60%) | NR | 22/43 (51%) | 86%^*^ | 66%^*^ | 77%^*^

GES = gastric scintigraphy; GI = gastrointestinal; GP = gastroparesis; hr = hours; NR = not reported; WMC = wireless motility capsule

* Numerator and denominator not available.

Figure 5 Summary of the sensitivity and specificity of WMC compared with gastric scintigraphy in patients with known or suspected gastroparesis

This figure plots the sensitivity and specificity of the wireless motility capsule compared with gastric scintigraphy in patients with known or suspected gastroparesis. Four studies are displayed. Lee 2012 has a sensitivity of 86 percent and a specificity of 66 percent. Rao 2011 has a sensitivity of 80 percent and a specificity of 81 percent. Lee 2009, which was an abstract, has a sensitivity of 64 percent and a specificity of 80 percent. Kuo 2011 has a sensitivity of 59 percent and a specificity of 64 percent.

All studies, including one abstract,44 looked at diagnostic agreement between the modalities. Diagnostic agreement between wireless motility capsule and gastric scintigraphy ranged from 59 to 86 percent positive test agreement and from 64 to 81 percent for negative test agreement. We estimated the concordance between the two tests to range between 35 and 81 percent. The range reflects the heterogeneity of the studies, which used different definitions of gastroparesis as determined by wireless motility capsule, as well as different study inclusion criteria. The results from the abstract do not change these conclusions.

One study16 examined the specific outcome of diagnostic reclassification for this comparison. The authors recalculated diagnostic accuracy of the wireless motility capsule after reclassifying subjects as gastroparetic or normal based on their 4-hour scintigraphic study results. The receiver operating characteristic area under the curve for gastric emptying time was 0.94, the sensitivity was 87 percent, and the specificity was 92 percent.

One study45 estimated the diagnostic accuracy, which they termed “diagnostic gain,” of wireless motility capsule compared with gastric emptying scintigraphy (Table 7), using various combinations of gastric emptying time, wireless motility parameters, and gastric scintigraphy. The study defined diagnostic gain as abnormal motility detected by wireless motility capsule, deducting the number of subjects with abnormal gastric scintigraphy but normal wireless motility studies, over the total number of subjects, expressed as a percentage. In patients with confirmed gastroparesis (based on symptoms and prior scintigraphy within 2 years), gastric scintigraphy alone was abnormal in 51 percent of patients whereas 70 percent of patients had an abnormal wireless motility capsule study using a combination of gastric emptying time and motility parameters. The overall diagnostic gain of wireless motility capsule compared with gastric scintigraphy was 19 percent (P = 0.04).

Table 7 Diagnostic gain of WMC compared with gastric scintigraphy in the evaluation of gastroparesis

Author, Year | Definition for Gastroparesis | Total N | GES | GES + GET | GES + G/SB PM | GES + GET + G PM | GET + G/SB PM | GES + GET + SB PM | GES + GET + G/SB PM
Lee, 2012^45^ | 5 hours | 43 | 51% | 67% | 65% | 67% | 70% | 75% | 74%

GES = gastric emptying scintigraphy; GET = gastric emptying time; G/SB PM = gastric/small bowel pressure measurements; G PM = gastric pressure measurements; SB PM = small bowel pressure measurements

One study41 compared the coefficient of variation (COV) for various measures obtained by gastric scintigraphy and gastric emptying time via wireless motility capsule. This abstract evaluated the relationship between gastric emptying time of the wireless motility capsule and different parameters obtained via 4-hour gastric scintigraphy: namely retention at 2 hours, retention at 4 hours, time of 50 percent emptying, or time of 90 percent emptying. Both tests were obtained simultaneously and they reported that the time of 90 percent emptying by scintigraphy had the COV most similar to that of gastric emptying time by wireless motility capsule (Table 8).

Table 8 Coefficient of variation^*^ of gastric emptying among patients with gastroparesis using gastric scintigraphy and WMC

Author, Year | Definition for Gastroparesis | 2h % Retention - GES | 4h % Retention - GES | 2h % Emptying - GES | 4h % Emptying – GES | T50 - GES | T90 - GES | GET - WMC
Brun, 2011^41^ [abstract] | Not reported | 41% | 129% | 44% | 24% | 49% | 30% | 34%

GES = gastric emptying scintigraphy; GET = gastric emptying time; T50 = time of 50% emptying; T90 = time of 90% emptying; WMC = wireless motility capsule

* The coefficient of variation is a measure of dispersion of a probability distribution, defined as the ratio of the standard deviation of values to the mean of the values in a distribution. The coefficient of variation by itself doesn't tell us which test is better. It only provides a measure of how precisely the test can measure the value of interest, in this case, percent retention or percent emptying.

#### Motility Assessment

##### Transit Times

Five studies, including two abstracts,41,43 evaluated wireless motility capsule-derived transit times in comparison with gastric scintigraphy alone for patients with gastroparesis.

Kuo et al.16 evaluated 87 healthy subjects and 61 patients with gastroparesis via simultaneous gastric scintigraphy and wireless motility capsule. They compared gastric emptying via scintigraphy at 2 hours (GES-2h) and 4 hours (GES-4h) using wireless motility capsule to obtain gastric emptying time. Normative data for gastric scintigraphy at 2- and 4-hour time points came from the Tougas protocol. The study reported that the correlation coefficient between gastric emptying time via wireless motility capsule and GES-4h was 0.73 and the correlation coefficient between gastric emptying time via wireless motility capsule and GES-2h was 0.63. The study calculated receiver operating characteristic curves to evaluate the clinical utility of the diagnostic tests for gastric emptying time via the wireless motility capsule and GES-2h and GES-4h cut-offs compared with clinical diagnosis. They reported the area under the receiver operating characteristic curve and the sensitivity and specificity of the three diagnostic tests. The study did not observe any statistically significant difference between the areas under the curve for gastric emptying time via the wireless motility capsule and GES-4h. The authors then compared gastric emptying time via the wireless motility capsule with GES-4h. Using these data, the authors concluded that the area under the curve for gastric emptying time via the wireless motility capsule was 0.94, sensitivity was 87 percent, and specificity was 92 percent.

In a subsequent abstract,41 the investigators reported on variability using additional scintigraphically-derived parameters (T50 or the time of 50 percent emptying of the meal, and T90 or the time of 90 percent emptying of the meal) and reported that gastric emptying time via the wireless motility capsule correlated more closely with T90 than with GES-2h or GES-4h; however, data provided in this abstract were limited.

Lee et al.45 enrolled 48 subjects with symptoms of gastroparesis and a prior abnormal gastric emptying study. These patients then underwent simultaneous gastric scintigraphy and wireless motility capsule testing. Data from 43 subjects were available for analysis. Looking at transit alone, the study calculated overall device agreement at 77 percent (positive agreement 86 percent, negative agreement 66 percent). Seven subjects had a delayed wireless motility capsule with normal scintigraphy, whereas three subjects had a delayed scintigraphy but normal transit time on wireless motility capsule.

Rao et al.34 evaluated 86 patients referred for motility evaluation in a retrospective fashion, comparing the wireless motility capsule with conventional motility testing. Of these patients, 36 had upper gastrointestinal symptoms and also underwent 4-hour gastric scintigraphy. The investigators reported that when they compared wireless motility capsule and gastric scintigraphy results in these patients using transit data alone, both studies were abnormal in 12 of 15 (80 percent) subjects and both tests were normal in 17 of 21 (81 percent) subjects. The study reported an overall device agreement of 81 percent using transit alone. There was diagnostic discrepancy in five of the 36 subjects (14 percent).

Reddymasu et al.43 evaluated 66 healthy subjects and 41 patients with gastroparesis using simultaneous wireless motility capsule testing and scintigraphy. It defined gastroparetic patients as having symptoms consistent with gastroparesis and a prior abnormal gastric scintigraphy. When the study looked at wireless motility capsule-derived transit data isolated from pressure parameters and compared it with clinical symptoms and a prior abnormal gastric scintigraphy test, the study reported the sensitivity of the wireless motility capsule at 68 percent and specificity at 82 percent. The study reported a current gastric scintigraphy to have a sensitivity of 46 percent and specificity of 94 percent.

##### Pressure Patterns

Two studies, including one that was published as an abstract only,43 evaluated wireless motility capsule-derived pressure patterns in comparison with gastric scintigraphy alone for patients with gastroparesis. Lee et al.45 evaluated 43 subjects with symptoms of gastroparesis and a previously-abnormal gastric scintigraphy within 2 years of enrollment. The authors reported that 47 percent of subjects had abnormal gastric or small bowel pressure measurements using the wireless motility capsule. However, the study did not perform a direct comparison between pressure parameters derived by wireless motility capsule (in the absence of transit data) and scintigraphic data alone. The authors did, however, evaluate the additional diagnostic gain achieved by using a combination of transit and pressure parameters. Specifically, 10 of 21 subjects with a normal gastric emptying scintigraphy had pressure abnormalities identified by wireless motility capsule. When compared with gastric scintigraphy alone, this study found a statistically significant improvement in diagnostic gain using a combination of gastric scintigraphy and wireless motility study (P = 0.002).

Reddymasu and colleagues43 evaluated 66 healthy and 41 gastroparetic patients with simultaneous wireless motility capsule testing and scintigraphy. The study defined gastroparetic patients as having symptoms consistent with gastroparesis and a prior abnormal gastric scintigraphy. When the study looked at gastric pressure patterns in isolation from transit data and compared them with a clinical diagnosis of gastroparesis based on symptoms and a prior scintigraphy, the sensitivity of the wireless motility capsule was 88 percent and specificity was 30 percent. This was in comparison with gastric scintigraphy, which had a sensitivity of 46 percent and specificity of 94 percent. This abstract did not report data evaluating the combination of wireless motility capsule-derived transit and pressure data in comparison with scintigraphy.

#### Treatment Decisions

Three studies, including one abstract,44 addressed this outcome for this comparison (Table 9). Kuo et al. found that examination with wireless motility capsule changed management in 52 of 83 (63 percent) patients.12 Rao et al.34 found that physicians made changes in management owing to wireless motility capsule testing in 18 of 36 (50 percent) of patients. However, the numbers of patients for whom physicians made particular categories of management changes were not available in the report. Lee et al. found that, physicians made management changes in multiple areas in patients who underwent examination by wireless motility capsule, compared with “another modality,” for a total of 22 of 32 (69 percent) patients.44

Table 9 Change in treatment decisions due to examination by WMC compared with gastric scintigraphy in the evaluation of gastroparesis

Author, Year | Study Design | Total N | Total Change in Management | Changes in Medication | Changes in Diet | Changes in Procedure (G-tube Placement, J-tube Placement, or Surgery)
Kuo, 2011^12^ | Retrospective chart review | 83 | 52/83 (63%) | 39/83 (47%) | 9/83 (11%) | 4/83 (5%)
Rao, 2011^34^ | Retrospective chart review | 36 | 18/36 (50%) | NR | NR | NR
Lee, 2009^44^ [abstract] | Retrospective cohort | 32 | 22/32 (69%) | 18/22 (82%) | 6/22 (27%) | 4/22 (18%)

G-tube = gastronomy tube; J-tube = jejunostomy tube; NR = not reported

#### Resource Utilization

One study addressed resource utilization as an outcome.12 Kuo et al. reviewed outpatient records of patients who had undergone wireless motility capsule testing to determine if capsule testing eliminated the need for additional tests. They assumed that patients who were undergoing evaluation for presumptive gastroparesis would undergo scintigraphy, that patients who were undergoing evaluation for presumptive small intestinal dysmotility would undergo barium studies, that patients with presumed slow-transit constipation would undergo ROM studies, and that WMC eliminated the need for these tests if these tests were not performed for patients with the aforementioned symptoms. They found there was no need for additional testing via gastric scintigraphy in nine of 52 patients (17.3 percent) patients, no need for additional testing via small bowel barium transit in seven of 13 (53.8 percent) patients, and no need for additional testing via radiopaque colon marker tests in 41 of 60 (68 percent) patients.

#### Patient-Centered Outcomes

No studies addressed patient-centered outcomes for this comparison.

#### Harms

The studies had limited data on potential harms of wireless capsule testing. Kuo et al.16 evaluated 148 patients and reported that 46 percent required an abdominal x-ray to verify passage of the capsule because they did not return the capsule. Five subjects required a second x-ray to ensure passage; however, the capsule did pass in all subjects. The study reported 10 adverse events; six were unrelated to the wireless motility capsule and three were probably not related. The one event that the study felt to be associated with capsule use was capsule retention in the stomach due to entrapment with a fiber supplement; however, the capsule did pass in this case after administration of intravenous erythromycin. The study did not report any serious adverse events.

Rao et al.34 reported on 86 patients who underwent wireless motility capsule testing in addition to conventional motility testing. The study did not report any serious adverse events and all subjects successfully expelled the capsule.

No other studies reported on this outcome.

### WMC Versus Antroduodenal Manometry

No included studies addressed this comparison.

### WMC Versus Endoscopy

No included studies addressed this comparison.

### SOE

For most of the outcomes included in this Key Question, the SOE was low or insufficient. We included seven studies for diagnostic accuracy; however, four of the seven were felt to have a high risk of bias and only two of the seven were felt to be precise studies—both of which were felt to have high risk of bias. With regards to motility assessment, we also felt the strength of evidence was low, primarily due to risk of bias. Similar issues were present with the subquestions for treatment decisions, resource utilization, and harms. Please see Table 10 for more details.

Table 10 Numbers of studies and subjects, SOE domains, and SOE among studies comparing WMC testing with gastric scintigraphy

Outcome | Number of Studies/Abstracts | Domains Pertaining to SOE | | | | SOE
Outcome | Number of Studies/Abstracts | Risk of Bias | Consistency | Directness | Precision | SOE
Diagnostic accuracy | 7^12, 16, 34, 41, 43-45^ / 3 | Medium | Consistent | Direct | Imprecise | Low
Motility assessment | 5^16,34,41,43,45^ / 2 | Medium | Consistent | Direct | Imprecise | Low
Treatment decisions | 3^12,34,44^ / 1 | High | Consistent | Direct | Imprecise | Low
Harms | 2^16,34^ / 0 | Medium | Consistent | Direct | Imprecise | Low
Patient-centered outcomes | 0 | N/A | N/A | N/A | N/A | Insufficient
Resource utilization | 1^12^ / 0 | High | Unknown | Direct | Imprecise | Low

N/A = not applicable; SOE = strength of evidence; WMC = wireless motility capsule

The strength of the evidence was defined as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Moderate = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable or does not permit a conclusion.

## KQ 2 Evaluation of Gastric Dysmotility: WMC in Combination With Other Diagnostic Tests Versus Other Diagnostic Tests Alone

### Key Points

- Adding wireless motility capsule testing to conventional motility testing improves diagnostic accuracy in patients with suspected gastroparesis (sensitivity of scintigraphy compared with symptoms ranged from 42 to 51 percent; sensitivity of wireless motility capsule ranged from 60 to 66 percent). (SOE: Low)
- Adding wireless motility capsule testing to conventional motility testing improves assessment of motility parameters in patient with suspected gastroparesis. Scintigraphy does not measure pressure patterns. (SOE: Low)
- The strength of evidence was insufficient for treatment decisions, harms, patient-centered outcomes, and resource utilization. We did not find any studies addressing these outcomes.
- The strength of evidence was insufficient that the addition of wireless motility capsule testing to antroduodenal manometry or endoscopy affects diagnostic accuracy, motility assessment, treatment decisions, harms, patient-centered outcomes, or resource utilization. We did not find any studies addressing these comparisons.

### WMC Plus Gastric Scintigraphy Versus Gastric Scintigraphy Alone

#### Diagnostic Accuracy

Two studies addressed this question with a total of 79 applicable patients.34,45 Rao et al. evaluated 86 patients with symptoms of dysmotility and normal baseline endoscopic and radiographic evaluations.34 Of those 86 patients, 36 had predominant upper gastrointestinal symptoms and underwent evaluation with 4-hour gastric scintigraphy and wireless motility capsule testing. On testing, gastric scintigraphy confirmed clinical suspicion for gastroparesis in 42 percent of patients whereas the wireless motility capsule confirmed suspicion for gastroparesis in 66 percent of patients. The two studies were abnormal in 12 of 15 patients (80 percent) and both were normal in 17 of 21 patients (81 percent) with an overall device agreement of 81 percent. There was diagnostic discrepancy in 5 of 36 (14 percent) subjects, representing at least some degree of diagnostic gain from the two modalities in combination. The studies did not calculate the statistical significance of this increased diagnostic yield.

Lee et al. evaluated 43 patients with symptoms of gastroparesis and previous abnormal gastric scintigraphy.45 All patients underwent simultaneous gastric scintigraphy and wireless motility capsule study. Twenty-two of 43 patients (51 percent) had abnormal gastric scintigraphy, whereas 26 of 43 patients (60 percent) had abnormal gastric transit on wireless motility capsule. The study calculated overall device agreement for transit time at 77 percent (positive agreement 86 percent, negative agreement 66 percent). Seven of 43 patients had delayed gastric transit on wireless motility capsule and normal gastric scintigraphy. Three of 43 patients had delayed gastric scintigraphy with normal gastric transit on wireless motility capsule. In addition, this study evaluated gastric pressure parameters and found additional gain using those parameters. Ten of 21 subjects with a normal GES had pressure abnormalities identified by wireless motility capsule. When compared with gastric scintigraphy alone, this study found a statistically significant improvement in diagnostic gain using a combination of gastric scintigraphy and wireless motility study (P = 0.002).

#### Motility Assessment

##### Transit Times

The article by Rao et al. looked only at transit times and did not include pressure patterns in their analysis.34 Thus, the findings above represent only transit time assessment. The study by Lee et al. looked at both transit times and pressure patterns. However, even when looking at transit times alone and disregarding pressure patterns entirely, there was a statistically significant improvement in diagnostic gain discovered by scintigraphy plus wireless motility capsule transit time as compared with scintigraphy alone (P = 0.02).

##### Pressure Patterns

The only article to evaluate the role of gastric scintigraphy in combination with wireless motility capsule pressure patterns as compared with scintigraphy alone was that of Lee et al.45 As stated above, they found that the addition of pressure profile analysis to scintigraphy data significantly increased diagnostic yield. They looked at multiple pressure pattern parameters, including contractile frequency and a calculated motility index. When taken together, the data obtained with scintigraphy plus wireless motility capsule-derived pressure patterns increased diagnostic yield over scintigraphy alone.

#### Treatment Decisions

We did not find any studies meeting our eligibility criteria that reported on the effect of testing on treatment decisions.

#### Resource Utilization

No included studies addressed this outcome for this comparison.

#### Patient-Centered Outcomes

No included studies addressed this outcome for this comparison.

#### Harms

The article by Rao34 found no harms from either modality of testing. The article by Lee45 did not report on harms; however, these numbers are small and insufficient to address this issue.

### WMC Plus Antroduodenal Manometry Versus Antroduodenal Manometry Alone

No studies addressed this comparison.

### WMC Plus Endoscopy Versus Endoscopy Alone

No studies addressed this comparison.

### SOE

We graded the SOE for this KQ as low. While few studies addressed this question specifically, the ones that did were among the better studies in terms of quality, and demonstrated independent review of the wireless motility capsule and scintigraphy. Both were peer-reviewed full manuscripts. We did not include any abstracts in this analysis. We assessed risk of bias as medium and rated these studies as consistent and direct. We rated precision as low but this is difficult to gauge for this question. Table 11 summarizes our grading of the SOE.

Table 11 Numbers of studies and subjects, SOE domains, and SOE among studies comparing WMC testing plus gastric scintigraphy compared with gastric scintigraphy alone

Outcome | Number of Studies / Abstracts | Domains Pertaining to SOE | | | | SOE
Outcome | Number of Studies / Abstracts | Risk of Bias | Consistency | Directness | Precision | SOE
Diagnostic accuracy | 2^34,45^ / 0 | Medium | Consistent | Direct | Imprecise | Low
Motility assessment | 2^34,45^ / 0 | Medium | Consistent | Direct | Imprecise | Low
Treatment decisions | 0 | N/A | N/A | N/A | N/A | Insufficient
Harms | 0 | N/A | N/A | N/A | N/A | Insufficient
Patient-centered outcomes | 0 | N/A | N/A | N/A | N/A | Insufficient
Resource utilization | 0 | N/A | N/A | N/A | N/A | Insufficient

N/A = not applicable; SOE = strength of evidence; WMC = wireless motility capsule

SOE was defined as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Moderate = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable or does not permit a conclusion.

## KQ 3 Evaluation of Colonic Dysmotility: WMC Alone Versus Other Diagnostic Tests

### Key Points

- The SOE comparing WMC with colonic or whole-gut scintigraphy was insufficient because no articles or abstracts formally evaluated this comparison.
- The diagnostic accuracy of WMC is similar to ROM. Concordance between ROM and WMC was approximately 80 percent in three larger studies. The sensitivity for wireless motility capsule compared with clinical suspicion ranged from 32 to 46 percent and the specificity ranged from 95 to 100 percent. The sensitivity of day-5 ROM ranged from 28 to 37 percent and the specificity ranged from 95 to 100 percent. (SOE: Low)
- WMC was comparable with ROM in their ability to detect colonic transit time and identify slow-transit constipation. (SOE: Low)
- WMC testing affects treatment decisions based on ROM testing. Very small numbers made comparison difficult for treatment decisions. Studies reported a 7 percent change in nutrition, a 21 percent referral to surgery, and a 4 percent change in nutritional and behavioral therapies with WMC. (SOE: Low)
- WMC testing can affect resource utilization. (SOE: Low)
- Studies infrequently reported harms and adverse events for WMC or ROM. (SOE: Low)
- The SOE was insufficient regarding patient-centered outcomes. We did not identify any studies that met our inclusion criteria and evaluated this outcome.

### WMC Versus Colonic Scintigraphy

We did not include any studies that addressed this comparison.

### WMC Versus ROM

Nine studies reported in 14 publications compared the WMC with ROM in colon dysmotility patients.17,32,48-50,53 One study had three publications,17,49,50 but we only describe one publication below.17 The additional studies compared an unclear subset of patients' results to the Bristol stool test50 and studied how irritable bowel syndrome may alter pressure results measured by the wireless motility capsule among moderate and severe constipation without reporting the corresponding ROM results.49 Another full-text publication34 updated an abstract,53 so we only reported on the full-text publication.

One study included patients with suspected slow-transit constipation, gastroparesis, or intestinal dysmotility.12 Only the diagnostic accuracy results contribute because the study did not distinguish between the clinical management changes for patients with suspected slow-transit constipation or changes from other patients, or because it reported results based on the final diagnosis, not the suspected diagnosis. Two abstracts42,44 included patients with suspected gastrointestinal dysmotility disorders, but did not report results separately for slow-transit constipation. We presented the results from this study under KQ 1. All other studies enrolled patients who received a previous diagnosis of chronic or slow-transit constipation according to Rome criteria.

#### Diagnostic Accuracy

Tables 12 and 13 and Figure 6 summarize data reported on diagnostic accuracy, sensitivity, and specificity within the included studies.12,17,32,34,48

Table 12 Diagnostic accuracy and test concordance of WMC and ROM in the evaluation of constipation comparing patients with known constipation with known non-diseased controls

Author, Year | Definition for Slow-Transit Constipation CTT WMC | Definition for Slow-Transit Constipation ROM | Total N | Sensitivity of CTT WMC Compared With Clinical Constipation | Specificity of CTT WMC Compared With Clinical Constipation | Sensitivity of ROM Compared With Clinical Constipation | Specificity of ROM Compared With Clinical Constipation | Concordance of CTT WMC and ROM
Rao, 2009^17^ | 44 hours for men and 59 hours for women | Day 2: NR Day 5 ROM sensitivity was based on cut off of 5 or more markers retained | 67 with known constipation 81 without gastrointestinal disease | 46%^*^ | 95%^*^ | Day 5: 22/67 (37%) | Day 5: 95%^*^ | Day 2: 0.78^†^ (0.70-0.84) Day 5: 0.59 (0.46-0.69)
Rao, 2012^48^ | 59 hours | > 5 markers retained on Day 5 | 25 with known constipation 11 without gastrointestinal disease | 8/25 (32%) | 11/11 (100%) | 7/25 (28%) | 11/11 (100%) | Among constipated subjects: 0.71 Among controls: 0.28

CTT = colonic transit time; NR = not reported; ROM = radiopaque markers; WMC = wireless motility capsule

* Numerator and denominator not reported.

† Spearman correlation coefficient.

Table 13 Diagnostic accuracy and test concordance of WMC compared with ROM markers in the evaluation of constipation including only patients with known or suspected constipation

Author, Year | Definition for Slow-Transit Constipation WMC | Definition for Slow-Transit Constipation | N Analyzed With Constipation | Positive Percent Agreement of CTT WMC Compared With ROM | Negative Percent Disagreement of CTT WMC Compared With ROM | AUC, CTT WMC Compared With ROM | Concordance of CTT WMC and ROM
Rao, 2009^17,50^ | CTT 44 hours for men and 59 hours for women | Day 5 ROM sensitivity was based on cut off of 5 or more markers retained | 67 known | Day 5: 19/23=83%^*^ | NR | NR | Day 2: 0.74^†^ Day 5: 0.69
Camilleri, 2010^32^ | 59 hours | Delayed on days 4 and 7 | 157 known | 47/59 (80%; CI, 67 to 98%) | 89/98 (91%; CI, 83 to 92%) | NR | 136/157 (87%)
Kuo, 2011^12^ | 59 hours | NR | 7 with information on colonic transit time from both ROM and WMC | 3/7 (43%) | 6/7 (86%) | NR | 9/14 (64%)
Rao, 2011^34^ | NR | 6 or more ROM at 120 hours | 50 suspected | 20/23 (87%) | 18/27 (67%) | NR | 38/50 (76%)
Rao, 2012^48^ | 59 hours | > 5 markers retained on Day 5 | 25 known | 6/7 (86%) | 16/18 (89%) | NR | 22/25 (88%)

AUC = receiver operating characteristic area under curve; CI = 95 percent confidence interval; CTT = colonic transit time; NR = not reported; ROM = radiopaque markers; WMC = wireless motility capsule

* This study also reported that 31 subjects had a colonic transit time greater than 59 hours measured by wireless motility capsule testing, and 21 of these subjects were also delayed based on day-5 ROM count.

† Spearman correlation coefficient.

Figure 6 Summary of the positive and negative percent agreement of WMC compared with ROM in patients with known or suspected constipation

This figure plots the positive and negative percent agreement of the wireless motility capsule compared with radiopaque markers in patients with known or suspected slow-transit constipation. Four studies are displayed. Rao 2011 has a positive percent agreement of 87 percent and a negative percent agreement of 67 percent. Rao 2012 has a positive percent agreement of 86 percent and a negative percent agreement of 89 percent. Camilleri 2010 has a positive percent agreement of 80 percent and a negative percent agreement of 91 percent. Kuo 2011 has a positive percent agreement of 43 percent and a negative percent agreement of 86 percent.

Two studies17,48 evaluated the sensitivity and specificity of colon transit time measured by WMC compared with clinical suspicion. The sensitivity for WMC ranged from 32 to 46 percent and the specificity ranged from 95 to 100 percent. The sensitivity of day-5 ROMs ranged from 28 to 37 percent and the specificity ranged from 95 to 100 percent.

Five studies compared the diagnostic accuracy of WMC testing with ROM among patients with known or suspected constipation.12,17,32,34,48 The positive percent agreement ranged from 43 to 87 percent and the negative percent agreement ranged from 67 to 91 percent. As three larger studies determined the concordance between ROM and WMC to be approximately 80 percent,32,34,48 we found the tests to be considered similar based on criteria set out in the methods. One study,12 which found a lower concordance rate, had a different population focus and much smaller sample size. Another study17 reported the Spearmen correlation coefficient between colonic transit times recorded by the wireless motility capsule and day-2 and day-5 ROM counts. The correlation among constipated subjects was 0.74 on day 2 and 0.69 on day 5.

#### Motility Assessment

##### Transit Time

Three studies reported data on transit times measured by WMC and ROM (Table 14). One study reported significantly different colonic transit times as measured by WMC (median 43.5 hours) compared with ROM (median 55 hours; P < 0.001). Transit times do differ between testing modalities as ROM testing includes gastric and small bowel transit time, whereas WMC does not.32 However, the correlation coefficient between these numbers was 0.71. Two other studies17,48 reported correlation coefficients between colonic transit time by WMC and day-5 ROM count ranging from 0.69 to 0.71.

Table 14 Transit times recorded by WMC and ROM in the evaluation of constipation

Author, Year | Study Design | Total N Constipated | WMC Transit Time | ROM Transit Time^*^ | Spearman Correlation Coefficient
Camilleri, 2010^32^ | Prospective cohort | 157 | CTT median (25-75 percentiles) 43.5 h (21.7-70.3) | Median (25-75 percentiles) 55.0 h (31.0-85.0) | 0.71 (P < 0.001)
Rao, 2009^17^ | Prospective cohort | 67 | Median (25-75 percentiles), hours GET 3.5 (3.0-4.2) CTT 46.7 (24.0-91.9) | Median (25-75 percentiles), Day 5 ROM count 1 (0-17) | 0.69
Rao, 2012^48^ | Prospective cohort | 25 | CTT median (25-75 percentiles) 45 h (37-60)^†^ | Median (25-75 percentiles), Day 5 ROM count, 6 (1-6) | 0.71 (P = 0.0001)

CTT = colonic transit time; GET = gastric emptying time; NR = not reported; ROM = radiopaque markers; SBTT = small bowel transit time; SD = standard deviation; WGTT = whole gut transit time; WMC = wireless motility capsule

* In an ROM test, transit delay is measured by counting the number of markers remaining at a certain time interval after the capsule is ingested. There are 24 markers at the start.

† Data abstracted from figures.

##### Pressure Patterns

No study compared WMC with ROM and reported on pressure patterns. A sub-study reported on pressure patterns49 but we excluded it because the publication did not report ROM results. Similarly, an abstract reporting on pressure patterns mentioned that testing with ROM occurred, but did not report on ROM results.

#### Treatment Decisions

##### Change in Medications

Only two studies offered information regarding how WMC informed changes in medications, compared with ROM.12,34 Both these studies reported data gleaned from retrospective chart reviews and no studies prospectively assessed whether change in medication was appropriate based on diagnostic testing (Table 15). Of these two included studies, one study reported an overall change in medications of 71 percent12 and another reported a 40 percent change.34

Table 15 Change in medications following a WMC for the evaluation of slow-transit constipation

Author, Year | Study Design | % Changed Medications After WMC | % Changed Medications After ROM
Rao, 2011^34^ | Prospective cohort | 40% overall change, but not specified for LGI or UGI symptoms Treatment Prokinetic agents 6% Prescription laxatives 20% Antidepressants 12% Withdrawal of opioids 6% Antiemetics 6% | Not reported (all patients had previously had ROM)
Kuo, 2011^12^ | Retrospective cohort | 71% changed medications | Not reported

LGI = lower gastrointestinal; ROM = radiopaque makers; UGI = upper gastrointestinal; WMC = wireless motility capsule

##### Change in Management: Referral, Referral to Surgery, or Change in Nutrition

Only two studies offered information about change in care management for WMC compared with use of ROM.12,34 Both studies reported data gleaned from retrospective chart reviews and no studies prospectively assessed whether change in medication was appropriate based on diagnostic testing (Table 16). One study reported a person changing their nutritional intake and three people being referred to surgery.12 The other study reported that 28 percent of the patients were referred for anorectal manometry and 16 percent for breath testing based on the WMC capsule results. Four percent received new nutritional or behavioral therapies.34

Table 16 Change in other management following WMC and ROM for evaluation of slow-transit constipation

Author, Year | Study Design | WMC Change in Nutrition | WMC Referral to Surgery | ROM
Rao, 2011^34^ | Prospective cohort | Nutritional and behavioral therapies 4% | Not specifically reported | NR
Kuo, 2011^12^ | Retrospective cohort | Change in nutritional program, 7% | Referred to surgery, 21% | NR

NR = not reported; ROM = radiopaque markers; WMC = wireless motility capsule

#### Resource Utilization and Patient-Centered Outcomes

Table 17 summarizes the changes in resource utilization based on WMC or ROM testing in the evaluation of slow-transit constipation. Three studies reported on unreadable results from the WMC test and problems with followup for the radiopaque marker testing.17,32,48 Unreadable results from the WMC ranged from 4 to 8 percent, and problems with ROM followup ranged from zero percent to 7 percent. Another study reported patients being referred for anorectal manometry (28 percent) and breath testing (16 percent).34 This study also reported that 26 out of 50 patients (53 percent) received new information on their diagnosis based on the WMC test.

Table 17 Change in resource utilization following WMC and ROM testing for evaluation of slow-transit constipation

Author, Year | Study Design | WMC Subsequent Tests | ROM Subsequent Tests | WMC New Diagnoses | ROM New Diagnoses | Unreadable Results From WMC (For Resource Utilization Section) | Failure to Attend Followup ROM Radiographs or Read on Wrong Day (For Resource Utilization)
Camilleri, 2010^32^ | Prospective | NR | NR | NR | NR | 8/180 (4%) | 5/180 (3%)
Rao, 2011^34^ | Prospective | Anorectal manometry, 28%^*^ Breath testing for bacterial overgrowth or carbohydrate intolerance, 16%^*^ | NR | Prolonged gastric emptying, 14/50 (28%) Rapid gastric emptying, 2/50 (4%) Prolonged small bowel transit, 7/50 (14%) Prolonged colon transit, 3/50 (6%) | NR | N/A (based on chart review of completed tests; had to have readable result to be included) | N/A (based on chart review of completed tests)
Rao, 2009^17^ | Prospective | NR | NR | NR | NR | 14/165 (8%) | 12/165 (7%)
Rao, 2012^48^ | Prospective | NR | NR | Delayed small bowel transit time, 1/25 (4%) Delayed gastric emptying time, 3/25 (12%) | NR | 3/39 (8%) | 0/39 (0%)

N/A = not applicable; NR = not reported; ROM = radiopaque markers; WMC = wireless motility capsule

* Numerators and denominators not reported.

#### Harms

The articles reporting on the comparison of WMC testing and use of ROM reported very few harms (Table 18).

Table 18 Summary of the adverse events from WMC testing in the evaluation of slow-transit constipation

Author, Year | Serious Adverse Events | Other Adverse Events | Retained Capsule | Retained Capsule Requiring Intervention | Radiation Exposure | Mortality
Rao, 2009^17^ | None | NR | 0 non-constipation 14/67 constipated | 11/67 | NR | NR, presumably 0
Camilleri, 2010^32^ | None | 31 adverse events (could have more than 1 per person) | NR | 0/180 | At least 1 person | NR, presumably 0
Rao, 2011^34^ | None | NR | 0 | 0 | NR | NR, presumably 0
Rao, 2009^46,*^ [abstract] | None | None | 0 | 0 | NR | NR
Rao, 2012^48^ | None | NR | 1/39 | NR | NR | NR

NR = not reported; WMC = wireless motility capsule

* Results were not reported for radiopaque marker testing.

The types of harms the articles most frequently mentioned were inability to swallow the capsule, technical failure or data loss, and failure to pass the capsule within the time frame of initial testing.17,32,48 Patients required x-rays at day 21 to exclude capsule retention in some cases, but this was based on simultaneous ROM testing during the study (and a day-5 x-ray showing retention of the capsule). No studies reported deaths from exposure to the WMCs or ROMs. The Rao et al. article17 reported a technical failure rate of 3.4 percent in the literature, and a technical failure rate of 10 percent in the study. No studies that reported on harms reported serious adverse events.17,32,46,48 The only reported adverse events were from Camilleri et al.32 with two patients suffering dysphagia with ingestion attempts for the WMC, and one patient suffering abdominal pain after ingestion of the capsule. The authors determined these were “definitely related” to the capsule itself.

In comparison of harms, although the articles discussed the radiation exposure risk between WMC and ROM, they did not report the difference in actual exposure in any unit of measure for comparison on a person-by-person basis. The research protocols in the studies we included used between one and three sequential x-rays to assess ROM transit. Study protocols mandated that if the patient does not observe passage of the WMCs, then x-rays at days 7 or 21 were necessary to detect retention. This x-ray exposure was necessary in four patients at day 7^32^ and in 14 patients at day 21.^17^ In clinical practice beyond the study setting, x-rays would be required only if the patient was symptomatic. The studies rarely reported any symptoms from WMC ingestion.

### SOE

Although relatively few articles compared the diagnostic accuracy of the WMC with the use of ROM for evaluating slow-transit constipation, Table 19 shows that the strength of evidence was low in support of the diagnostic accuracy of WMC in evaluating slow-transit constipation. The risk of bias in these studies was low, but the total amount of evidence was sparse. The strength of evidence also was low regarding the accuracy of the WMC in assessing motility times in patients with possible slow transit constipation, and regarding the low risk of harm associated with use of the device. The strength of evidence was low or insufficient regarding other outcomes associated with use of the device.

Table 19 Numbers of studies and subjects, SOE domains, and SOE among studies comparing WMC with ROM

Outcome | Number of Studies (Participants) / Number of Abstracts | Domains Pertaining to SOE | | | | SOE
Outcome | Number of Studies (Participants) / Number of Abstracts | Risk of Bias: Design/Quality | Consistency | Directness | Precision | SOE
Diagnostic accuracy of slow-transit constipation | 5 (306)12,17,32,34,48 / 0 | Medium | Consistent | Direct | Precise | Low
Motility time assessment | 3 (249)17,32,48 / 0 | Medium | Consistent | Direct | Precise | Low
Treatment decisions | 2 on medications & referrals (169)12,34 / 0 | Medium | Consistent | Direct | Imprecise | Low
Harms | 5 (388)17,32,34,46,48 / 1 | Medium | Consistent | Direct | Imprecise | Low
Patient-centered outcomes | 0 | N/A | N/A | N/A | N/A | Insufficient
Resource utilization | 4 (299)17,32,34,48 / 0 | Medium | Consistent | Direct | Imprecise | Low

N/A = not applicable; SOE = strength of evidence

SOE was defined as follows: High = High confidence that the evidence reflects the true effect. Further research is unlikely to change our confidence in the estimate of the effect. Moderate = Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate. Low = Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Insufficient = Evidence is unavailable or does not permit a conclusion.

## KQ 4 Evaluation of Colonic Dysmotility: WMC in Combination With Other Diagnostic Tests Versus Other Diagnostic Tests Alone

### Key Points

- Strength of evidence was insufficient because no studies directly addressed the outcomes for this comparison.

### Summary

We reviewed nine studies (14 publications) that looked at the comparison of WMC with scintigraphy or ROM in the evaluation of colonic dysmotility.12,17,32,34,42,44,46-53 However, no studies specifically looked at the incremental value of WMC testing in addition to ROM or scintigraphy in terms of diagnostic accuracy of slow-transit constipation. Additionally, no studies looked at the incremental value of also using the WMC in addition to ROM or scintigraphy in terms of motility, treatment decisions, patient-centered outcomes, harms, and resource utilization. One study34 attempted to answer this question by comparing the WMC with conventional motility tests, including both scintigraphy and ROM. However, the data were incomplete and did not directly answer the KQ regarding incremental value specifically. Thus, the evidence was insufficient to determine the incremental value of using WMC in combination with other conventional tests of colonic motility.

## Study Quality (For All KQs)

We reported study quality separately for full-length publications and abstracts because the abstracts had limited information about study methods (Appendix D, Evidence Table 4). The overall study quality was fair.

Of the 11 full-length publications,12,16,17,32,34,45,48-50,52,53 six stated that a goal was to compare the diagnostic accuracy of WMC with a reference/nonreference standard.12,17,32,34,45,49 Five publications excluded healthy controls from the diagnostic accuracy analyses,12,34,45,52,53 with the remainder including both healthy controls in the comparison of diagnostic tests. Two publications excluded severely ill patients,16,34 one publication49 included these patients and the remainder had unclear reporting. Five publications used the same reference standard for all patients,16,17,32,49,50 one publication allowed different reference standards,45 and four publications did not report on the reference standard with enough detail to determine if the studies used the same reference standard for all participants. No publication analyzed all patients. Seven of the studies performed the WMC and reference standard within three months of each other,16,17,32,34,45,50,52 often with concurrent testing. Six publications reported a threshold for disease positivity or cited that they used a threshold from a previous publication.17,32,34,45,49,50 Only three publications interpreted the WMC results independently from the reference standard.17,32,34 One of these publications was a retrospective chart review.34 Four publications explicitly stated that they did not interpret the test results independently.12,16,45,49,50 For the two publications with unclear reporting52,53 and those publications that did not interpret results without knowledge of the other test results, we contacted the authors to obtain information on independent assessment of the tests. We were able to confirm from the authors that they interpreted the results independently in three publications that did not report blinding.16,45,50

Nine full-length studies reported on conflicts of interest.12,16,17,32,34,45,48-50 A commercial source related to motility testing funded six of the studies and one study was independent of commercial funding.34 Of two studies with unclear commercial funding,12,45 a related publication16 reported that one study45 had commercial funding. All of the studies that reported on conflict of interest included an author employed by industry or an author who received funding or fees from at least one commercial source related to motility testing.

The seven abstracts did not provide sufficient details to evaluate all domains of study quality. One abstract excluded healthy controls from the analyses,44 five abstracts included healthy controls,41,43,46,47,51 and one had unclear inclusion.42 Two abstracts reported that all patients received the same reference standard,41,43 with the remainder having unclear consistency of a reference standard. No abstract stated that they interpreted results of WMC independently of the reference standard. Two studies reported that the WMC assessment and reference standard occurred within three months.41,43 One study stated in the abstract a threshold for disease based on the WMC.43 Three studies stated the aim was to compare the diagnostic accuracy of the WMC with a reference standard.42-44

No abstract reported on conflict of interest. However, many of the abstract authors were authors of the full-length publications we reviewed, and some of those publications reported potential conflicts as noted above.