# References

1 FDA. Gastrointestinal Motility System, Capsule 510(k), K053547. US Food and Drug Administration. 2006. Jul. 7. 2006. Available at: www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfpmn/pmn.cfm?ID=20313.
2 Hasler WL. Gastroparesis: pathogenesis, diagnosis and management. Nat Rev Gastroenterol Hepatol. 2011;8(8):438-53. [pmid: 21769117].
3 Camilleri M, Bharucha AE, Farrugia G. Epidemiology, mechanisms, and management of diabetic gastroparesis. Clin Gastroenterol Hepatol. 2011;9(1):5-12. quiz e7. [pmid: 20951838].
4 Parkman HP, Camilleri M, Farrugia G, et al. Gastroparesis and functional dyspepsia: excerpts from the AGA/ANMS meeting. Neurogastroenterol Motil. Feb. 2010;22(2):113-33. [pmid: 20003077].
5 Parkman HP, Yates K, Hasler WL, et al. Clinical features of idiopathic gastroparesis vary with sex, body mass, symptom onset, delay in gastric emptying, and gastroparesis severity. Gastroenterology. 2011;140(1):101-15. [pmid: 20965184].
6 Parkman HP, Yates KP, Hasler WL, et al. Dietary intake and nutritional deficiencies in patients with diabetic or idiopathic gastroparesis. Gastroenterology. 2011;141(2):486-98.e7. [pmid: 21684286].
7 Jung HK. The incidence, prevalence, and survival of gastroparesis in olmsted county, Minnesota, 1996-2006 (gastroenterology 2009;136:1225-1233). J Neurogastroenterol Motil. Jan. 2010;16(1):99-100. [pmid: 20535336].
8 Rey E, Choung RS, Schleck CD, et al. Prevalence of hidden gastroparesis in the community: the gastroparesis “iceberg”. J Neurogastroenterol Motil. Jan. 2012;18(1):34-42. [pmid: 22323986].
9 Wang YR, Fisher RS, Parkman HP. Gastroparesis-related hospitalizations in the United States: trends, characteristics, and outcomes, 1995-2004. Am J Gastroenterol. 2008;103(2):313-22. [pmid: 18047541].
10 Quigley EM, Hasler WL, Parkman HP. AGA technical review on nausea and vomiting. Gastroenterology. 2001;120(1):263-86. [pmid: 11208736].
11 Sarosiek I, Selover KH, Katz LA, et al. The assessment of regional gut transit times in healthy controls and patients with gastroparesis using wireless motility technology. Aliment Pharmacol Ther. 2010;31(2):313-22. [pmid: 19814743].
12 Kuo B, Maneerattanaporn M, Lee AA, et al. Generalized transit delay on wireless motility capsule testing in patients with clinical suspicion of gastroparesis, small intestinal dysmotility, or slow transit constipation. Dig Dis Sci. 2011;56(10):2928-38. [pmid: 21625964].
13 Guo JP, Maurer AH, Fisher RS, et al. Extending gastric emptying scintigraphy from two to four hours detects more patients with gastroparesis. Dig Dis Sci. 2001;46(1):24-9. [pmid: 11270790].
14 Wang TC, Fleischer DE, Kaufman PN, et al. The best of times and the worst of times: sustaining the future of academic gastroenterology in the United States--Report of a Consensus Conference Conducted by the AGA Institute Future Trends Committee. Gastroenterology. Feb. 2008;134(2):597-616. [pmid: 18242223].
15 Rao SS, Camilleri M, Hasler WL, et al. Evaluation of gastrointestinal transit in clinical practice: position paper of the American and European Neurogastroenterology and Motility Societies. Neurogastroenterol Motil. 2011;23(1):8-23. [pmid: 21138500].
16 Kuo B, McCallum RW, Koch KL, et al. Comparison of gastric emptying of a nondigestible capsule to a radio-labelled meal in healthy and gastroparetic subjects. Aliment Pharmacol Ther. 2008;27(2):186-96. [pmid: 17973643].
17 Rao SS, Kuo B, McCallum RW, et al. Investigation of colonic and whole-gut transit with wireless motility capsule and radiopaque markers in constipation. Clin Gastroenterol Hepatol. 2009;7(5):537-44. [pmid: 19418602].
18 Williams RE 3rd, Bauman WA, Spungen AM, et al. SmartPill technology provides safe and effective assessment of gastrointestinal function in persons with spinal cord injury. Spinal Cord. 2012;50(1):81-4. [pmid: 21876549].
19 Cassilly D, Kantor S, Knight LC, et al. Gastric emptying of a non-digestible solid: assessment with simultaneous SmartPill pH and pressure capsule, antroduodenal manometry, gastric emptying scintigraphy. Neurogastroenterol Motil. 2008;20(4):311-9. [pmid: 18194154].
20 Pasricha PJ, Colvin R, Yates K, et al. Characteristics of patients with chronic unexplained nausea and vomiting and normal gastric emptying. Clin Gastroenterol Hepatol. Jul. 2011;9(7):567-76. e1. 4. [pmid: 21397732].
21 Abell TL, Camilleri M, Donohoe K, et al. Consensus recommendations for gastric emptying scintigraphy: a joint report of the American Neurogastroenterology and Motility Society and the Society of Nuclear Medicine. Am J Gastroenterol. 2008;103(3):753-63. [pmid: 18028513].
22 Stewart WF, Liberman JN, Sandler RS, et al. Epidemiology of constipation (EPOC) study in the United States: relation of clinical subtypes to sociodemographic features. Am J Gastroenterol. Dec. 1999;94(12):3530-40. [pmid: 10606315].
23 Suares NC, Ford AC. Prevalence of, and risk factors for, chronic idiopathic constipation in the community: systematic review and meta-analysis. Am J Gastroenterol. Sep. 2011;106(9):1582-91. quiz 1, 92. [pmid: 21606976].
24 Qureshi W, Adler DG, Davila RE, et al. ASGE guideline: guideline on the use of endoscopy in the management of constipation. Gastrointest Endosc. 2005;62(2):199-201. [pmid: 16046978].
25 Longstreth GF, Thompson WG, Chey WD, et al. Functional bowel disorders. Gastroenterology. Apr. 2006;130(5):1480-91. [pmid: 16678561].
26 Wald A. Pathophysiology, diagnosis and current management of chronic constipation. Nat Clin Pract Gastroenterol Hepatol. 2006;3(2):90-100. [pmid: 16456575].
27 Rao SS, Ozturk R, Laine L. Clinical utility of diagnostic tests for constipation in adults: a systematic review. Am J Gastroenterol. 2005;100(7):1605-15. [pmid: 15984989].
28 Brandt LJ, Prather CM, Quigley EM, et al. Systematic review on the management of chronic constipation in North America. Am J Gastroenterol. Suppl 1. 2005;100:S5-S21. [pmid: 16008641].
29 van der Sijp JR, Kamm MA, Nightingale JM, et al. Radioisotope determination of regional colonic transit in severe constipation: comparison with radio opaque markers. Gut. 1993;34(3):402-8. [pmid: 8472991].
30 Pomerri F, Frigo AC, Grigoletto F, et al. Error count of radiopaque markers in colonic segmental transit time study. AJR Am J Roentgenol. 2007;189(2):W56-9. [pmid: 17646438].
31 Mojaverian P, Ferguson RK, Vlasses PH, et al. Estimation of gastric residence time of the Heidelberg capsule in humans: effect of varying food composition. Gastroenterology. 1985;89(2):392-7. [pmid: 3891497].
32 Camilleri M, Thorne NK, Ringel Y, et al. Wireless pH-motility capsule for colonic transit: prospective comparison with radiopaque markers in chronic constipation. Neurogastroenterol Motil. 2010;22(8):874-82. e233. [pmid: 20465593].
33 Tack J, Muller-Lissner S, Stanghellini V, et al. Diagnosis and treatment of chronic constipation--a European perspective. Neurogastroenterol Motil. 2011;23(8):697-710. [pmid: 21605282].
34 Rao SS, Mysore K, Attaluri A, et al. Diagnostic utility of wireless motility capsule in gastrointestinal dysmotility. J Clin Gastroenterol. 2011;45(8):684-90. [pmid: 21135705].
35 Whiting PF, Rutjes AW, Westwood ME, et al. QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. 2011;155(8):529-36. [pmid: 22007046].
36 Agency for Healthcare Research and Quality. Methods Guide for Medical Test Reviews. Rockville, MD. 2010 (published draft). Final: AHRQ Publication No 12-EHC017. Rockville, MD. June. 2012. www.effectivehealthcare.ahrq.gov.
37 Food and Drug Administration. Guidance for Industry and FDA Staff: Statistical Guidance on Reporting Results from Studies Evaluating Diagnostic Tests. 2007. Available at: www.fda.gov/MedicalDevices/DeviceRegulationandGuidance/GuidanceDocuments/ucm071148.htm.
38 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. 2010;63(5):513-23. [pmid: 19595577].
39 Singh S, Chang SM, Matchar DB, et al. Chapter 7: Grading a Body of Evidence on Diagnostic Tests. J Gen Intern Med. Jun. 2012;(27):47-55.
40 Guyatt GH, Oxman AD, Vist GE, et al. GRADE: an emerging consensus on rating quality of evidence and strength of recommendations. BMJ. 2008;336(7650):924-6. [pmid: 18436948].
41 Brun M, Wilding GE, Surjanhata B, et al. Performance characteristics of gastric emptying test: Variability of gastric emptying results by two different technologies-gastric emptying scintigraphy (GES) and Wireless Motility Capsule (WMC) in healthy and gastroparetics. Gastroenterology. 2011;140(5):S804-S5.
42 Lee A, Michalek W, Wiener SM, et al. Clinical impact of a wireless motility capsule - A retrospective review. Gastroenterology. 2010;138(5):S481.
43 Reddymasu S, Semler JR, McCallum R. Postprandial gastric motility parameters assessed by the wireless motility capsule method are complimentary to gastric transit time measurement of a standardized meal for the diagnosis of gastroparesis. Gastroenterology. 2010;138(5):S714.
44 Lee A, Michalek W, Wong C, et al. Clinical impact of an ambulatory motility capsule-retrospective review. Neurogastroenterol. Motil. 2009;21:73.
45 Lee A, Wilding G, Kuo B. Variable abnormal physiological motility in the proximal upper gastrointestinal tract in gastroparesis. Neurogastroenterol Motil. 2012. Mar. 14. [pmid: 22417117].
46 Rao SS, Paulson JA, Donahoe R, et al. Can assessment of colonic motility with wireless ph/pressure capsule (SmartPill(registered trademark)) distinguish subtypes of chronic constipation?. Gastroenterology. 2009;136(5):A223.
47 Rao SS, Paulson JA, Saad RJ, et al. Assessment of colonic, whole gut and regional transit in elderly constipated and healthy subjects with a novel wireless pH/pressure capsule (SmartPill(registered trademark)). Gastroenterology. 2009;136(5):A144.
48 Rao SS, Coss-Adame E, Valestin J, et al. Evaluation of constipation in older adults: Radioopaque markers (ROMs) versus wireless motility capsule (WMC). Arch Gerontol Geriatr. 2012. May. 7. [pmid: 22572600].
49 Hasler WL, Saad RJ, Rao SS, et al. Heightened colon motor activity measured by a wireless capsule in patients with constipation: relation to colon transit and IBS. Am J Physiol Gastrointest Liver Physiol. 2009;297(6):G1107-14. [pmid: 19808653].
50 Saad RJ, Rao SS, Koch KL, et al. Do stool form and frequency correlate with whole-gut and colonic transit? Results from a multicenter study in constipated individuals and healthy controls. Am J Gastroenterol. 2010;105(2):403-11. [pmid: 19888202].
51 Paulson J, Rao S, Donahoe R, et al. Can wireless pH/pressure capsule (StnartPill(registered trademark) (SP)) distinguish subtypes of chronic constipation?. Neurogastroenterol. Motil. 2009;21:39.
52 Mysore KR, Attaluri A, Valestin J, et al. How useful is wireless motility capsule in diagnosis of gastrointestinal dysmotility?. Neurogastroenterol. Motil. 2010;22:37-8.
53 Mysore KR, Attaluri A, Valestin J, et al. Evaluation of diagnostic utility of a wireless motility capsule in gastrointestinal dysmotility. Gastroenterology. 2010;138(5):S233.
54 ClinicalTrials.gov. Colonic Transit Time Validation Study (CTT). ClinicalTrials.gov [Internet]. Bethesda (MD). National Library of Medicine. (US). 2000. [cited 2012 Oct 3]. Available from: www.clinicaltrials.gov/ct2/show/NCT00857363?term=NCT00857363&rank=1.
55 ClinicalTrials.gov. Assessment of Whole Gut Transit Time Using the SmartPill Capsule (WholeGut). ClinicalTrials.gov [Internet]. Bethesda (MD). National Library of Medicine. (US). 2000. [cited 2012 Oct 3]. Available from: www.clinicaltrials.gov/ct2/show/NCT00603707?term=NCT00603707&rank=1.
56 ClinicalTrials.gov. A Comparison of SmartPill Capsule With Scintigraphy for Determining Gastric Residence Time. ClinicalTrials.gov [Internet]. Bethesda (MD). National Library of Medicine. (US). 2000. [cited 2012 Oct 3]. Available from: www.clinicaltrials.gov/ct2/show/NCT00128284?term=NCT00128284&rank=1.
57 ClinicalTrials.gov. A Comparison of SmartPill Capsule With Scintigraphy for Determining Gastric Residence Time - Over 65 Years Old (GETOver65). ClinicalTrials.gov [Internet]. Bethesda (MD). National Library of Medicine. (US). 2000. [cited 2012 Oct 3]. Available from: www.clinicaltrials.gov/ct2/show/NCT00682877?term=NCT00682877&rank=1.
58 Hinton JM, Lennard-Jones JE, Young AC. A new method for studying gut transit times using radioopaque markers. Gut. Oct. 1969;10(10):842-7. [pmid: 5350110].
59 Metcalf AM, Phillips SF, Zinsmeister AR, et al. Simplified assessment of segmental colonic transit. Gastroenterology. Jan. 1987;92(1):40-7. [pmid: 3023168].
60 Evans RC, Kamm MA, Hinton JM, et al. The normal range and a simple diagram for recording whole gut transit time. Int J Colorectal Dis. Feb. 1992;7(1):15-7. [pmid: 1588218].
61 Saad RJ, Hasler WL. A technical review and clinical assessment of the wireless motility capsule. Gastroenterol Hepatol (N Y). Dec. 2011;7(12):795-804. [pmid: 22347818].
62 Brun M, Michalek W, Surjanhata B, et al. Small bowel transit time (Sbtt) by Wireless Motility Capsule (WMC): Normal values and analysis of pressure profiles in different subgroups of patients with slow sbtt. Gastroenterology. 2011;140(5):S865.
63 Brun R, Michalek W, Surjanhata BC, et al. Comparative analysis of phase III migrating motor complexes in stomach and small bowel using wireless motility capsule and antroduodenal manometry. Neurogastroenterol Motil. Apr. 2012;24(4):332-e165. [pmid: 22292793].
64 Maqbool S, Parkman HP, Friedenberg FK. Wireless capsule motility: comparison of the SmartPill GI monitoring system with scintigraphy for measuring whole gut transit. Dig Dis Sci. 2009;54(10):2167-74. [pmid: 19655250].
65 Michalek W, Kuo B. Analysis of upper GI migrating motor complexes using invasive and non-invasive techniques. Neurogastroenterol. Motil. 2010;22:64-5.
66 Michalek W, Neuman S, Kloetzer L, et al. Impact of acid suppression on upper gastrointestinal function as measured by a non-invasive wireless pH and motility capsule. Gastroenterology. 2009;136(5):A186-A7.
67 Michalek W, Semler JR, Kuo B. Impact of acid suppression on upper gastrointestinal pH and motility. Dig Dis Sci. 2011;56(6):1735-42. [pmid: 21086166].
68 Mikolajczyk A, Surma B, Rubin D. Assessment of tandem measurements of PH and total gut transit time in healthy volunteers. Am. J. Gastroenterol. 2011;106:S502-S3.
69 Mreyoud A, Rozov I, Moore J, et al. Assessment of drug effects on gastric emptying and contractility using wireless capsule manometry. Gastroenterology. 2009;136(5):A536.
70 Saad RJ, Semler JR, Wilding GE, et al. The effect of age on regional and whole gut transit times in healthy adults. Gastroenterology. 2010;138(5):S127.
71 Sarosiek I, Alvarez A, Romero R, et al. Prolonged cecal residence time identified by wireless technology: A new symptoms explantation for some patients with chronic constipation. Neurogastroenterol. Motil. 2011;23:22-3.
72 Timm DA, Willis H, Thomas W, et al. The use of a new wireless motility device (SmartPill(registered trademark)) for measurement of gastrointestinal transit time after dietary fiber intervention. Gastroenterology. 2010;138(5):S462.
73 Timm D, Willis H, Thomas W, et al. The use of a wireless motility device (SmartPill(R)) for the measurement of gastrointestinal transit time after a dietary fibre intervention. Br J Nutr. 2011;105(9):1337-42. [pmid: 21138605].
74 Willis HJ, Thomas W, Willis DJ, et al. Feasibility of measuring gastric emptying time, with a wireless motility device, after subjects consume fiber-matched liquid and solid breakfasts. Appetite. 2011;57(1):38-44. [pmid: 21435365].
75 Zarate N, Mohammed SD, O'Shaughnessy E, et al. Accurate localization of a fall in pH within the ileocecal region: validation using a dual-scintigraphic technique. Am J Physiol Gastrointest Liver Physiol. 2010;299(6):G1276-86. [pmid: 20847301].
76 Trikalinos TA, Balion CM. Chapter 9: options for summarizing medical test performance in the absence of a “gold standard”. J Gen Intern Med. Jun. Suppl 1. 2012;27:S67-75. [pmid: 22648677].
77 ClinicalTrials.gov. Phase 2 Study to Evaluate Safety & Efficacy of RM-131 Administered to Patients With Diabetic Gastroparesis, Rhythm Pharmaceuticals, Inc. Bethesda (MD). National Library of Medicine (US). 2012. 2012. May. 4.