# Methods

This topic was nominated via the Agency for Healthcare Research and Quality's (AHRQ) Web site. Our Evidence-based Practice Center (EPC) established a team and a work plan to develop the evidence report. The project involved formulating and refining the questions, developing a protocol with input from selected technical experts, performing a comprehensive literature search, summarizing the state of the literature, constructing evidence tables, synthesizing the evidence, and submitting the report for peer review.

## Topic Refinement

We recruited a panel of Key Informants to provide input on the selection and refinement of the questions to be examined. The Key Informants included three gastroenterologists who specialize in motility disorders, a representative from a patient advocacy group, and a representative from a payer organization. We posted our draft Key Questions (KQs) on AHRQ's website in December 2011 for public comment.

We developed the KQs that we presented in the scope and KQ sections of the introduction with input from the Key Informants, representatives of AHRQ, and public comments. The KQs focus on the diagnostic accuracy of the wireless motility capsule alone or in combination with other diagnostic tests in the evaluation of gastroparesis and slow-transit constipation.

## Technical Expert Panel

We recruited a Technical Expert Panel (TEP) to review a draft of the protocol for preparing this evidence report. The TEP included five gastroenterologists with expertise in motility disorders, a patient representative, and an expert in diagnostic accuracy. The TEP reviewed our protocol and provided feedback on the proposed methods for addressing the KQs. With the feedback from the TEP and AHRQ representatives, we finalized the protocol and posted it on AHRQ's website.

## Search Strategy

We searched the following databases for original studies for the periods in parentheses: MEDLINE^®^ (1966 to July 1, 2012) and Embase^®^ (1974 to July 1, 2012). We developed a search strategy for MEDLINE, accessed via PubMed, based on an analysis of the medical subject headings terms and text words of key articles we identified a priori (Appendix A). Additionally, we reviewed the reference lists of included articles and any relevant review articles. We also reviewed the conference proceedings for Digestive Disease Week for 2012.

We downloaded the results of the searches and imported them into ProCite^®^ version 5 (ISI ResearchSoft, Carlsbad, Calif.). We scanned for exact article duplicates, author/title duplicates, and title duplicates using the duplication check feature in ProCite^®^. We uploaded the articles from ProCite to DistillerSR (Evidence Partners, Ottawa, Ontario, Canada), a Web-based software package developed for systematic review data management. We used this database to track the search results at the levels of title review, abstract review, and article inclusion/exclusion.

To identify additional studies, the EPC's Scientific Resource Center submitted a request to the manufacturer of the motility capsule, the SmartPill^®^ Corporation, for any published or unpublished randomized controlled trials or observational studies that evaluated the wireless motility capsule. The SmartPill^®^ Corporation submitted comments on the draft report, but did not submit any new materials. We searched ClinicalTrials.gov to identify any relevant trials.

## Study Selection

Two independent reviewers scanned each title from the literature search. In order to eliminate it at this level, both reviewers had to indicate that the title was obviously ineligible. If they disagreed, they promoted the article to the next level of review (Appendix B, Title Review Form). We designed the title review to capture as many studies as possible that reported on the diagnostic accuracy of the wireless motility capsule.

Two investigators reviewed abstracts independently, and excluded an article if both investigators agreed it met one or more of the exclusion criteria (see inclusion and exclusion criteria listed in Table 1 and the Abstract Review Form in Appendix B). The team resolved differences between investigators regarding abstract eligibility through consensus adjudication.

Table 1 Inclusion and exclusion criteria

Population and Condition of Interest | - We included studies that evaluated patients with suspected gastroparesis and/or slow-transit constipation.; - We included only adult human subjects.
Diagnostic Test of Interest | - We included all studies that evaluated WMC alone or in combination with other tests.
Comparisons of Interest | - For KQs 1 and 2, we included studies that compared WMC with other conventional diagnostic tests for suspected gastroparesis, including scintigraphy, antroduodenal manometry, and endoscopy.; - For KQs 3 and 4, we included studies that compared WMC with other conventional diagnostic tests for suspected slow-transit constipation, including scintigraphy and ROM.
Outcomes | - We included studies that reported on at least one of the following outcomes:; ○ Diagnostic accuracy; ■ Gastroparesis: The reference standard is a 4-hour gastric emptying study.; ■ Slow-transit constipation: There is no consensus on a standard, so we examined this outcome relative to each existing standard (ROM and colonic scintigraphy).; ○ Motility assessment; ■ Transit time; ■ Pressure patterns; ○ Treatment decisions; ■ Change in medications; ■ Change in nutrition; ■ Need for surgery; ■ Need for a referral; ○ Patient-centered outcomes; ■ Symptom improvement; ■ Quality of life; ■ Patient satisfaction; ○ Resource utilization; ■ Test failure (unable to read test results); ■ Need for additional tests because of continued uncertainty about diagnosis; ■ Utilization of other health care services such as hospitalizations and physician visits; ○ Harms, such as capsule retention, radiation exposure, and mortality
Type of Study | - We excluded articles with no original data (e.g., editorials, commentaries, reviews).; - We included all types of studies with a comparison group that evaluated WMC.
Timing and Setting | - We included all clinical settings in developed countries.; - We included all durations of followup, but our desired length of followup for symptom improvement, quality of life, and need for additional tests was at least 3 months.

KQ = Key Question; ROM = radiopaque markers

Two reviewers performed another independent parallel full-text review of articles promoted on the basis of abstract review to determine if we should include these articles for data abstraction (Appendix B, Article Review Form). We resolved differences regarding article inclusion through consensus adjudication.

## Data Abstraction

We used a systematic approach to extract all data to minimize the risk of bias in this process. We created and pilot tested standardized spreadsheets for data extraction. By creating standardized spreadsheets for data extraction, we sought to maximize consistency in identifying all pertinent data available for synthesis.

The study investigators performed double data abstraction on each article. The second reviewer confirmed the first reviewer's abstracted data for completeness and accuracy. We formed reviewer pairs that included personnel with both clinical and methodological expertise. We did not hide from the reviewers the identity of the authors of the articles, their respective institutions, or the names of the journals that published the articles.

For all articles, the reviewers extracted information on general study characteristics (e.g., study design, country, location of recruitment, start year of recruitment, multi-center versus single center, length of followup, and length of time in between diagnostic tests), study participants (e.g., condition, age, gender, race, weight, prior diagnostic tests, blood sugar, smoking status, diabetes status, defacatory dysfunction status, and the use of prokinetics, narcotics, antidepressants, proton pump inhibitors, and laxatives), eligibility criteria, characteristics of the wireless motility capsule testing (e.g., was the pill swallowed or placed, did patients eat a standardized meal, did they drink Ensure^®^ shakes^b^), comparisons, outcome measures, definitions, and the results of each outcome (including measures of variability). For endoscopy, we would capture the number of hours that participants did not receive anything by mouth before the procedure and the method of sedation. For gastric scintigraphy, we would collect data on duration of testing (e.g., 4 hours) and if the study used liquid or solid components. For antroduodenal manometry, we would collect data on the choice and placement of the catheter. For ROM, we would collect data on the type of ROMs, the timing of dosing of markers and the surveillance x rays, and if the study recorded counts in each segment of the colon, or if it used a total count, or both. For colon scintigraphy, we would collect data on the type of protocol, and the duration of testing. For each of the diagnostic tests, we would collect information on the criteria the study used to make a diagnosis of gastroparesis and slow-transit constipation, and whether it instructed patients on the use of tobacco, prokinetics, narcotics, antidepressants, proton pump inhibitors, or laxatives at the time of the test.

b Ensure^®^ is a commercial nutritional drink that is given to subjects in some centers as part of the wireless motility capsule protocol.

The individual completing the review entered all information from the article review process into a Microsoft Excel (Microsoft, Redmond, WA) spreadsheet. Reviewers entered comments into the system whenever applicable.

## Quality Assessment

Two reviewers independently assessed article quality. We selected and modified the questions from the QUADAS-2 quality assessment tool.35 We supplemented this tool with additional quality-assessment questions (e.g., to assess spectrum bias) based on recommendations in the Methods Guide for Medical Test Review.36 Our quality assessment included items on: (1) whether the study excluded healthy subjects from the diagnostic accuracy comparison, (2) whether the study excluded severely affected patients, (3) whether the study enrolled a random sample of patients, (4) whether all patients received the same reference standard, (5) whether the study included all patients in the analysis, (6) whether the study interpreted results of the test independently, (7) whether the time period between tests was reasonably short (within 3 months) to ensure the condition did not change, (8) whether the study established cut-off values for test positivity before the study started, (9) whether a stated aim of the study was to compare diagnostic accuracy between wireless motility capsule testing and other diagnostic tests, (10) whether the study reported on conflicts of interest, (11) whether a commercial source related to motility testing funded the study, and (12) whether a commercial source related to motility testing employed or gave funding or fees to any of the authors.

When multiple publications reported on the same study and the assessments of study quality differed, we did not change the unclear responses to a yes or no based on reporting in a different publication. We assessed study quality for each individual publication because the analyses often differed even though it was conducted among the same patient population.

The two reviewers resolved differences in quality assessment.

## Applicability

We assessed the applicability of studies in terms of the degree to which the study population (e.g., age, etiology, comorbidities, prior surgery or gastric pacer), diagnostic tests (e.g., use of opiates during testing, use of bowel motility-altering agents, such as laxatives or prokinetic agents), outcomes, and settings (e.g., referral center) are typical for the treatment of individuals with suspected gastroparesis or slow-transit constipation.

## Data Analysis and Synthesis

We had planned to conduct meta-analyses when there was sufficient data (e.g., at least five studies for hierarchical summary receiver operator characteristic curves for diagnostic accuracy and at least three studies for other outcomes) and studies were sufficiently homogenous with respect to key variables (e.g., population characteristics, study duration, and diagnostic tests). We qualitatively summarized studies not amenable to pooling.

We considered gastric scintigraphy and clinical symptoms to be reference standards and ROM to be a nonreference standard. For measures of diagnostic accuracy when there was a reference standard, we summarized the results in terms of sensitivity, specificity, and test concordance. For measures of diagnostic accuracy when there was a nonreference standard, we summarized the results in terms of positive percent agreement, negative test agreement, and test concordance.37 We can describe the results of any given study in terms of the number of positive and negative tests detected by the index test and the reference standard or nonreference standard (see Figures 2 and 3). We report the diagnostic test accuracy results separately for studies that included known patients and nondiseased controls and for studies that included patients suspected of having the condition.

Figure 2 Calculation for sensitivity, specificity, and test concordance when there is a reference standard

This figure shows the calculations for sensitivity, specificity, and test concordance. A 2×2 table is shown, where the reference standard can provide either a positive or negative result and the index test can provide either a positive or negative test result. Cell “a” represents cases where both the reference standard and index test are positive. Cell “b” represents cases where the reference standard was negative, but the index test was positive. Cell “c” represents cases where the reference standard was positive, but the index test was negative. Cell “d” represents cases where both the reference standard and index test were negative. Sensitivity is equal to “a” divided by the sum of “a” and “c.” Specificity is equal to “d” divided by the sum of “b” and “d.” Test concordance is the sum of “a” and “d” divided by the sum of “a,” “b,” “c,” and “d.”

Figure 3 Calculation for positive and negative percent agreement and test concordance when there is a nonreference standard

This figure shows the calculations for percent positive agreement, percent negative agreement, and test concordance. A 2×2 table is shown, where the nonreference standard can provide either a positive or a negative result and the index test can provide either a positive or negative test result. Cell “a” represents cases where both the nonreference standard and index test are positive. Cell “b” represents cases where the nonreference standard was negative, but the index test was positive. Cell “c” represents cases where the nonreference standard was positive, but the index test was negative. Cell “d” represents cases where both the nonreference standard and index test were negative. Percent positive agreement is equal to “a” divided by the sum of “a” and “c.” Percent negative agreement is equal to “d” divided by the sum of “b” and “d.” Test concordance is the sum of “a” and “d” divided by the sum of “a,” “b,” “c,” and “d.”

We conducted a sensitivity analysis where we included data that were only reported in a conference abstract.

When the reference standard was a clinical diagnosis, we chose a 10 percent difference between tests in sensitivity or specificity as a potentially important difference because researchers powered key studies to detect a 10 percent difference.32 When the reference/nonreference standard was another diagnostic test, we considered it similar if the wireless motility capsule had test concordance of at least 80 percent.

## Data Entry and Quality Control

A second reviewer checked the data that we entered into the Excel spreadsheets. Second reviewers were generally more experienced members of the research team. We discussed any problems with a reviewer's data abstraction at a meeting with the reviewers. In addition, a third team member audited 10 percent of the included studies. We found a few discrepancies. For that reason, the lead investigators re-checked the outcome data as they prepared the text of the results on each KQ.

## Rating the Body of Evidence

At the completion of our review, we graded the strength of the best available evidence addressing KQs 1 through 4 by adapting an evidence grading scheme listed in both the Methods Guide for Medical Test Review36 and the Methods Guide for Effectiveness and Comparative Effectiveness Reviews.38,39 Both of these evidence grading schemes use the recommendations of GRADE Working Group.40 We applied evidence grades to the bodies of evidence about each diagnostic test comparison for each outcome. We assessed the strength of the best available evidence by assessing the risk of bias, consistency, directness, and precision.

To evaluate the risk of bias, we considered: (1) if researchers published the study as an abstract only or as a peer-reviewed manuscript, (2) whether researchers interpreted the results of the wireless motility capsule independently from the results of other diagnostic tests, and (3) if there were other major quality issues. We contacted the authors regarding blinding of diagnostic test results if it was unclear in the manuscript. We did not evaluate abstracts on blinding. We considered spectrum bias (i.e., the extent to which disease severity affects the test results) as part of the assessment of risk of bias. We rated the body of evidence as “low risk of bias” if the study interpreted the diagnostic test results independently and there were no other major quality issues (see above list of items included in the quality assessment). We rated the body of evidence as “medium risk of bias” if the study interpreted the diagnostic test results independently and there was one major quality issue, or the study did not interpret the results of the diagnostic test results independently and there were no other major quality issues. We rated the body of evidence as “high risk of bias” if the study interpreted the diagnostic test results independently and there was more than one major quality issues, or the study did not interpret the results of the diagnostic test results independently and there were at least one major quality issue.

We rated the body of evidence as “consistent” if most of the studies showed the same direction of effect. We rated the consistency of a single study as “not applicable.” We rated the body of the evidence as “direct” if most of the studies directly addressed the KQs. We based our rating of precision on the width of the confidence intervals for sensitivity, specificity, and positive and negative predictive values. If the width of the confidence interval was less than or equal to 10 percent, then we considered the body of evidence to be “precise.”

We classified evidence pertaining to the KQs into four basic categories: (1) “high” SOE (indicating high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of the effect), (2) “moderate” SOE (indicating moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of the effect and may change the estimate), (3) “low” grade (indicating low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate), and (4) “insufficient” SOE (evidence is unavailable or does not permit a conclusion).40

## Peer Review and Public Commentary

Experts in gastroenterology and gastrointestinal motility disorders and individuals representing stakeholder and user communities were invited to provide external peer review of this comparative effectiveness review; AHRQ and an associate editor also provided comments. The draft report was posted on the AHRQ website for 4 weeks to elicit public comment. We addressed all reviewer comments, revising the text as appropriate, and documented everything in a “disposition of comments report” that will be made available 3 months after AHRQ posts the final comparative effectiveness review on the AHRQ Web site.