# Introduction

Delayed gastric emptying and slow-transit constipation are disorders of gastrointestinal (GI) physiology that may cause persistent troubling symptoms. When patients present with their symptoms, clinicians frequently try empiric therapy first because it is often difficult to measure these disorders. When empiric therapy is unsuccessful or symptoms are severe enough to prompt immediate investigation, clinicians usually will recommend diagnostic evaluation of GI physiology with one or more of the available tests. Unfortunately, all of the traditional tests of GI physiology have limitations. Many of the traditional testing modalities have inconsistency in their performances that make interpretation difficult and complex for providers. To give patients and their clinicians another option, a new test is available and approved for use in the United States—the wireless motility capsule (WMC).1

## Gastroparesis

### Definition and Prevalence

Gastroparesis is a condition in which patients experience symptoms of delayed gastric emptying in the absence of an actual physical blockage.2 The most common symptoms are nausea, vomiting, early satiety, bloating, abdominal pain, and postprandial fullness.3 Diagnosing gastroparesis depends on the accurate detection and assessment of gastric emptying delay. Since the common symptoms for gastroparesis overlap with symptoms of functional GI disorders, such as dyspepsia, cyclical vomiting, and irritable bowel syndrome, researchers have established a more stringent definition of gastroparesis. They define it as delayed gastric emptying as detected by clinical testing and the presence of symptoms of nausea and/or vomiting, postprandial fullness, early satiety, bloating, or epigastric pain for more than 3 months.4 Using this definition, the cumulative incidence of gastroparesis is 4.8 percent in people with type 1 diabetes, 1.0 percent in people with type 2 diabetes, and 0.1 percent in people without diabetes but who may have idiopathic gastroparesis or other rare etiologies.3 A multicenter study revealed that 88 percent of patients with idiopathic gastroparesis were female, and the average age at the time of diagnosis was 41 years.5,6 A 2007 community-based study estimated the prevalence of gastroparesis to be 9.6 per 100,000 for men and 37.8 per 100,000 for women.3 Newer estimates of prevalence report a higher rate of 24.2 per 100,000 inhabitants. Some experts estimate that more than 1.5 to 3 million Americans may have gastroparesis.7,8

### Etiology and Clinical Course

The etiologies of gastroparesis are most often idiopathic, diabetic, or postsurgical, but can be autoimmune, paraneoplastic, or neurologic. Idiopathic gastroparesis is the most common etiology, estimated by some small studies to range between 36 and 64 percent of patients with the condition. Diabetes mellitus is the primary cause of gastroparesis in 29 to 31 percent of patients. Clinicians usually assess gastroparesis in the outpatient setting, but some patients become severely ill with intractable vomiting and dehydration and must be hospitalized. Hospitalizations for gastroparesis increased by 158 percent between 1995 and 2004.^9^ In individuals with diabetes and gastroparesis, food digestion is unpredictable, and wild swings in blood glucose can require medical care and increase morbidity. This unpredictability highlights the need for accurate diagnosis of gastroparesis so patients can receive appropriate care.

### Evaluation of Possible Gastroparesis

Physicians generally assess gastroparesis in patients with typical symptoms (nausea, vomiting, bloating, abdominal pain, early satiety) in an outpatient setting, where they record a patient's medical history and perform a physical examination.10 In the examination, physicians must first rule out medication-induced symptoms and mechanical causes. Medications, such as opiates or glucagon-like peptide agonists, are the usual cause of delay of gastric emptying. If there is any possible offending medication use, clinicians can stop medication and observe the patient for improvement of symptoms. If there is any clinical suggestion of mechanical obstruction, then imaging with x-rays or computed tomography can confirm obstruction and exclude gastric emptying delay as a primary etiology. Motility disorders are difficult entities to diagnose. Multiple contributing factors make pathophysiology more complex, thus physicians can have difficulty gathering a unifying diagnosis from a single test. Methods of testing include gastric emptying scintigraphy, antroduodenal manometry, and now wireless motility capsule technology. Electrogastrography is an older form of testing that clinics rarely use, even in academic centers.2 Some patients with diagnosed gastroparesis may also have evidence of a diffuse GI motility disorder, as indicated by delayed small intestinal and/or colonic transit, in addition to the delayed gastric emptying. Management of these patients is different, as the prolongation of colonic transit in gastroparetic patients indicates dysmotility beyond the stomach, and this could be contributing to some of the patient's symptoms.11,12

#### Gastric Scintigraphy

The American College of Gastroenterology and the American Gastroenterological Association, recognize gastric emptying scintigraphy of a radiolabeled solid meal as the reference standard for determining delayed gastric emptying.10 Gastric scintigraphy is the ingestion of a meal commonly standardized to toast, jam, water, and radiolabeled egg whites, which timed imaging can follow as the egg whites pass through the GI tract. Most radiology centers require that all possible interfering medications, such as opiates, motility agents, and glucagon-like peptide agonists, be withheld for 5 to 7 days before scintigraphic testing. In order to best detect more abnormalities among symptomatic patients, and for the test to be reproducible, a consensus statement issued by the American Neurogastroenterology and Motility Society (ANMS) and Society of Nuclear Medicine in 2011^13^ recommends clinicians perform gastric scintigraphy over a period of 4 hours after a patient consumes a standardized meal. Motility specialists find that community-based radiology practices often provide shorter versions of the scintigraphic examination with durations between 60 and 120 minutes, whereas regional referral centers or tertiary care centers with established practices of motility specialists are more likely to offer full 4-hour testing.13 The medical community has established clear standards of abnormal emptying for 1, 2, 3, and 4 hours. Generally, physicians diagnose delayed gastric emptying when less than 90 percent of the gastric content has not emptied at 4 hours, meaning that the patient has retained more than 10 percent of the content. There is little evidence to suggest that scintigraphy is a useful diagnostic tool for judging a patient's response to treatment. Scintigraphy has other disadvantages such as low-dose radiation exposure, lack of sensitivity in detecting delayed emptying, lack of a standardized protocol in widespread use, duration of up to 4 hours, a half-day lost from work for the patient, and a high cost of interpretation.

#### Antroduodenal Manometry

Antroduodenal manometry is a cumbersome technology that can provide information about gastric physiology, however, only a few specialized centers offer it. With the patient usually sedated, a physician inserts a manometry catheter through the pyloric channel, most commonly with endoscopic guidance. This test permits physicians to capture pressure measurements, which provide information about the small bowel and gastric pressure patterns during resting, mealtime, and after administering medication. Antroduodenal manometry may help differentiate myopathic and neuropathic etiologies of symptoms. Myopathy is present when there are amplitude muscle pressures of less than 30 mmHg, and neuropathy is present when there are uncoordinated bursts of muscle activity. These are patterns of small bowel disease. Many gastric neuropathies show a flat line pattern similar to myopathic disease.

#### WMC

The U.S. Food and Drug Administration (FDA) recently approved and made available a new modality for identifying motility disorders, the wireless motility capsule.1 This new modality is a one-time use, portable, ingestible capsule that, when swallowed, records and transmits data to a receiver as the capsule travels through the gut. The capsule can measure pH, pressure, and temperature to track location, gastric contents, and expulsion time from the different regions of the bowel. Small trials to assess gastric emptying have tested wireless motility capsules. The ANMS recommend its use and the American College of Gastroenterology considers it a technology that has great promise and should be watched.14 The patient takes the pill after eating a standardized meal and wears a small monitor that makes telemetry recordings. The device assesses gastric emptying time from ingestion of the capsule (a point at which there is a low pH reading) to after it moves into the small bowel (when there's an abrupt rise in pH).15 A tandem scintigraphic study of the capsule alone, in comparison with a radiolabeled meal, established a cutoff point for gastric emptying time of 300 minutes.16 Disadvantages of the capsule include failure to capture data (requiring repeat testing) and delay or total failure to pass. When the capsule fails to pass and patients have symptoms, then a patient may need x-rays to detect retention. In rare cases, endoscopic or surgical removal may be necessary. The capsule is not viable for patients with a possible stricture, altered anatomy, or severe pyloric stenosis.17 Most patients do not mind wearing the data receiver during testing, but this may limit some patients in their daily life. Also, patients ideally should be able to tolerate not using any proton pump inhibitors and histamine 2 blockers before testing.17 Advantages of testing with the capsule include that it is wireless and painless, can be used in an office setting without sedation or radiation, and provides information for the whole gut in addition to the area of interest for gastric emptying.18,19 The capsule can assess gastric emptying, small bowel transit, and colonic transit in a single test. The only other single test that assesses transit in all areas of the gut is whole gut transit scintigraphy, which is available at only select centers. Alternatively, multiple tests, such as gastric emptying scintigraphy and radioopaque markers, can be combined to attempt to assess the transit in multiple locations of the gut.11,12

Most physicians would assess patients for evidence or history of stricture before using the capsule; this assessment might include additional imaging studies that physicians might not perform otherwise.

### Use of Gastric Emptying Testing To Guide Treatment

Gastric emptying delay testing helps physicians choose appropriate nutrition, medication, and surgical therapies. Testing can provide useful information for adjusting diets to accommodate better gastric emptying, such as: a low-fat diet, a low-residue diet (i.e., low fiber, easy to empty from the stomach), a liquid diet, or increasing consumption to multiple small meals taken 4 to 6 times per day. Testing can also help physicians gauge whether or not to prescribe prokinetic treatments, like metoclopramide or erythromycin, which are common treatments for gastroparesis. This is especially important for oral, intravenous, and sublingual preparations of metoclopramide, since there is a FDA black box warning about side effects in patients who use metoclopramide for more than 3 months. Studies have linked both metoclopramide and erythromycin to profound tachyphylaxis, limiting any intended benefit. Similarly, domperidone is not FDA-approved, but is available in many countries outside the U.S. Clinical care and research studies in the U.S. use domperidone through an Investigational New Drug Application encouraged by the FDA. As such, most physicians would be reluctant to prescribe domperidone without documentation of gastroparesis. Testing can help guide physicians when treating patients with severe symptoms and severe emptying delay (despite dietary changes) who need feeding tubes such as jejunostomy or gastrojejunostomy tubes that bypass the stomach entirely. Testing is also helpful in patients with total failure of gastric emptying who can't tolerate feeding tubes and require intravenous nutrition. Documentation of gastric emptying delay is a key eligibility criterion for both of these treatments. Thus, accurate diagnosis of gastroparesis is integral to decisions about care management.

### Outcomes

The main outcomes of interest are assessment of motility and diagnosis of gastric emptying delay. Other outcomes include the ability of testing to influence treatment decisions (e.g., medication, nutrition) or affect patient-centered outcomes (e.g., symptom improvement, need for surgery, quality of life, patient satisfaction). Clinicians and policymakers should consider the potential harms of testing, such as capsule retention, radiation exposure, and mortality. They should also consider the effects on resource utilization such as the need for additional tests, physician services, or hospitalizations.

### Controversy

The 2011 ANMS conference addressed controversy surrounding the accuracy of the cutoff point for scintigraphy in differentiating patients with true gastroparesis from those with more functional symptoms. Experts debated the need for stricter criteria for diagnosing gastroparesis and whether greater retention of gastric content was likely to relate to greater severity of disease, which recent literature has questioned.20 Nevertheless, this may still have implications for how physicians use capsule testing to treat patients with abnormal gastric emptying. Previous consensus recommendations from 2008 established baseline standards for scintigraphy and suggested that grading the severity of gastric emptying delay was relevant to clinical research, but did not establish how that grading would affect decisions about patients.21 We will address this issue by looking for data on how treatment decisions differ between testing methods. Another controversy was the lack of information regarding whether or not scintigraphy or wireless motility capsule testing could offer any guidance in assessing response to treatment or whether they would remain purely diagnostic tools. We will address this issue by looking for data on treatment response in terms of patient-reported outcomes. It is also unclear at this time which populations would benefit most from the wireless motility capsule or which order of testing is best to diagnose patients. Currently, clinicians recommend wireless motility capsule testing as an alternative test instead of scintigraphy. However, in cases that are still suspected but indeterminate, it is controversial whether it can replace or should supersede other testing methods.

## Constipation

### Definition and Prevalence

Constipation is a common symptom, reportedly occurring in 10 to 20 percent of the U.S. population.22,23 Multiple professional societies (with few variations) define constipation as fewer than two bowel movements per week or a decrease in a person's normal frequency of stools that is accompanied by straining, difficulty passing stool, or passage of hard solid stools.17 Patients who have fewer than two bowel movements per week should have a physician assess their medical history and perform a physical examination to exclude malignant or organic causes of constipation. A careful history should be able to elicit warning signs such as new onset of symptoms, obstructive symptoms, rectal bleeding, unintentional weight loss, or family history of early colon cancer. A rectal examination can further delineate rectal function and tone, and it can help to exclude a low rectal cancer. A colonoscopy is warranted if fecal occult blood, iron deficiency anemia, or any other warning signs are present, or if the patient with constipation is 50 years of age and has never received a screening colonoscopy.24 However, the yield of colonoscopy is low in patients with constipation and warning signs. Once an examination excludes organic causes of constipation, a physician can diagnose functional constipation. For individuals who are less than 50 years of age without “red flag” symptoms, no testing is necessary for a diagnosis of constipation, assuming the patient meets the Rome III criteria.

The Rome III criteria define functional constipation as follows:

1. Two or more of the following symptoms
  a. Straining during at least 25 percent of defecations
  b. Lumpy or hard stools in at least 25 percent of defecations
  c. Sensation of incomplete evacuation for at least 25 percent of defecations
  d. Sensation of anorectal obstruction/blockage for at least 25 percent of defecations
  e. Manual maneuvers to facilitate at least 25 percent of defecations (e.g., digital evacuation, support of the pelvic floor)
  f. Fewer than three defecations per week
2. Loose stools rarely present without the use of laxatives
3. Insufficient criteria for irritable bowel syndrome

Two or more of the above criteria must be present for the last 3 months, and symptoms must have first appeared at least 6 months prior to diagnosis.25

### Basic Management

Physicians should recommend lifestyle changes and medical management for all patients with symptoms of constipation. Lifestyle changes include drinking appropriate quantities of liquid; removing all possible offending medications; and eating a sufficient amount of vegetables, fruit, and fiber as recommended by the U.S. Department of Agriculture. Medical management includes avoiding constipating medications, and initiating bulking agents (e.g., fiber supplements), stool softeners (e.g., docusate, mineral oil), osmotic and stimulant laxatives (e.g., lactulose, milk of magnesia, magnesium citrate, polyethylene glycol [Miralax^®^], PEG-3350, senna), prokinetics (e.g., bisacodyl), or secretagogues/channel enhancers (e.g., linaclotide [FDA approved], lubiprostone [FDA approved and available in U.S.], prucalopride [not yet FDA-approved, but available in Europe and elsewhere]), as indicated. An initial constipation evaluation does not often involve colonic transit testing.

### Evaluation of Possible Slow-Transit Constipation

For certain individuals with suspected slow-transit constipation (defined as persistent symptoms of constipation despite medical management and lifestyle changes) colon transit testing can provide insight into the reason for the constipation. Testing can help physicians identify why a patient failed first-line therapy and help identify patients who require surgery.17 Transit disorders include slow colonic transit or colonic inertia, a hypomotile disorder of the colon where transit in the proximal colon is slow without evidence of retropulsion of the markers from the left colon and without evidence of anorectal dysfunction. Defecatory dysfunction (or functional outlet dysfunction) is the presence of uncoordinated motion of the anorectum muscles causing ineffective or weak expulsion of stool. Idiopathic megacolon (primary or secondary), a pathological enlargement of the colon, can also be present and may occur in conjunction with longstanding neurological diseases or Hirschsprung's disease (a failure of the development of the nerve cells within the colon wall).26 The main diagnostic methods used to test for colonic motility are radiopaque marker examination, colonic scintigraphy, colonic and anorectal manometry, and wireless motility capsule testing.27,28 The nonreference standard is radiopaque markers (ROM); however, scintigraphy is a comparable measure of colonic transit. Other investigatory tools that can provide complementary information are imaging tests such as defacography with barium or magnetic resonance imaging, barium enema, endorectal ultrasound, and magnetic resonance imaging of the pelvis.

#### ROM

Experts use the nonreference standard of ROM testing (commonly known as Sitz Markers) to define slow-transit constipation.27,28 Different institutions employ varied protocols for ROM testing and major GI societies do not presently endorse one standard protocol. In its simplest form, such testing consists of a patient ingesting the ROMs on day zero and then taking x-rays at day 5; these x-rays use overpenetrated films (110 kiloelectron volts) in order to reduce radiation exposure. Gastroenterologists no longer focus on the areas of colon that have the greatest delays, since studies have shown that this does not predict pathophysiology or treatment. The only exception to this statement is the patient who accumulates markers in the rectum and does not pass them; this would strongly suggest a defecation disorder. Marker retention helps physicians identify patients with slow transit. Some centers also use other testing methods, such as the Metcalf method.15,17 One disadvantage to ROM is x-ray exposure. Another disadvantage of ROMs is that they primarily assess oro-cecal transit and are not necessarily specific to the colon, since the test requires that patients swallow the markers and pass them out the anus. Any transit delay in the stomach or small bowel, or an anorectal outlet obstruction would also show up as a positive ROM test with retained markers, but there is no simple way to differentiate between these disorders without further testing. However, the test is valid and in practice since the late 1960s.15

#### Colonic Scintigraphy

Some physicians also perform colon scintigraphy but it is rarely available outside of highly-specialized motility research centers. This procedure requires that patients ingest a radiolabeled meal or radiolabeled tracer so physicians can follow the sequence of transit from the upper to lower GI tract. Research has validated this treatment, and several drug trials have used it to study treatment response. Two protocols exist. One from Temple University uses a seven-region analysis in which a numeric value represents overall colon transit and emptying of the ascending colon; the protocol summarizes the analysis in terms of the half-life of the radiolabeled substance. A second protocol, from the Mayo Clinic, combines the results of a five-region analysis. A disadvantage of colonic scintigraphy is that testing requires several days and requires radiation exposure. Studies have assessed the validity of colon scintigraphy relative to ROM.29,30 The ANMS guidelines endorse colon scintigraphy as a potential test for evaluating colon transit.

#### Total Colonic Manometry

Colonic manometry, a relatively new diagnostic test, is not widely available and only specialized centers offer it. For this test, a physician places a manometry catheter with endoscopic and fluoroscopic guidance after a full bowel preparation. The physician leaves the catheter in place for up to 24 hours, and obtains recordings after sedation (needed to place the catheter) has worn off. One disadvantage of this method is its limited availability, which is due to the specialized technical expertise required to perform and interpret this labor-intensive procedure. It is uncertain how physicians can use this information to guide the management of adults with slow-transit constipation.

#### WMC

WMC testing involves ingesting a capsule and wearing a receiver to collect data. It can detect specific transit times in the stomach, small bowel, and colon and thus detect both upper and lower GI disorders simultaneously with a single device. The pill itself is a large object, which remains large as it passes out of the stomach and into the small intestine. This differs slightly from the regular digestion process, in that the body usually moves food to the small intestine when the stomach has reduced the particles to a size no larger than 3 mm. Physicians can determine the capsule has exited from the stomach when gastric baseline pH rises rapidly (by 3 or more pH units) to a pH greater than 4. Cecal entry occurs when there is a sustained drop in pH of greater than 1 unit, more than 30 minutes after gastric emptying.31 We measure colonic transit time by calculating the time between cecal entry and rectal exit; rectal exit produces a large temperature reduction.17 One disadvantage is that in 5 percent of patients undergoing capsule testing, physicians don't collect cecal entry-time data, this reduces the diagnostic potential of the capsule.15 Camilleri has reported a way to use a combination of small bowel and colon transit times to better interpret these tests which do not report cecal entry.32 Other disadvantages are: physicians must use radiographic imaging to confirm elimination of the capsule when it fails to pass spontaneously, studies have indicated a 3 percent failure rate for the device, and physicians need to perform another motility testing to confirm whether prolonged colon transit time might be related to defecatory dysfunction. One advantage of capsule testing is the collection of data for the whole gut with one test. For patients with both colonic and gastric emptying delay, a wireless motility capsule can detect both disorders. Without the capsule, physicians would need two tests to make these assessments--gastric emptying scintigraphy and radioopaque markers. Other advantages include the lack of radiation exposure when the capsule is passed spontaneously and safely, and the fact that physicians can perform capsule testing in the outpatient setting, thereby providing accurate information about real-life conditions. Physicians cannot perform capsule testing in any patient who might have stricture or stenosis. Patients might need additional testing to ensure that narrowing is not present. Another advantage of capsule testing is that it provides a more complete picture of colonic transit (like whole-bowel scintigraphy might if it were more widely available); whereas, ROM testing only offers static imaging. One disadvantage is that there is only a single point of detection during the wireless motility capsule study (data gathering can only occur where the capsule in located) and there is no way to find out the specific location of the capsule, beyond knowing if it has exited an area (stomach, small intestine, or colon). Furthermore, it is uncertain whether all the extra data provided by this modality will be useful to change outcomes in any way.

### Use of Colon Transit Testing To Guide Treatment

Most patients with chronic constipation see symptom improvement with medical therapy and/or lifestyle changes. For some patients, all measures fail and physicians must use colon transit testing to better understand the motility disorders. However, a single test may not reflect the full complexity of a patient's motility disturbances since colon transit disorders can be complex to sort out. For example, anorectal dysfunction can impact colonic transit, but physicians detect it using anorectal manometry, separate from other transit testing. When anorectal manometry or balloon expulsion testing identifies anorectal or outlet dysfunction, physicians can treat using biofeedback therapy. Physicians can treat Hirschsprung's disease using surgical segmental resection. Megacolon may require medical therapy tailored to reducing gas formation, and reduction of fiber intake may paradoxically relieve symptoms. If these conservative measures fail, then megacolon may warrant segmental or total colectomy. If testing confirms the presence of slow-transit constipation (colonic inertia) without laxatives, then the next step in evaluation (at some centers) is transit testing with laxatives. A motility expert consensus states that physicians should consider surgery only after confirming colonic inertia.33 Clinicians can recommend colectomy when there is severe total or segmental slow-transit constipation; however, most clinicians reserve colectomy for patients with the most untreatable conditions. Sometimes an individual may have features of both outlet dysfunction and inertia; in these cases, guidelines suggest that physicians treat the outlet dysfunction before making decisions about slow transit. If outlet dysfunction does not improve with biofeedback therapy, then surgical options may be limited to ileostomy rather than primary anastomosis. Some patients with delayed colonic transit may have evidence of a more diffuse GI disorder, such as gastric or small bowel transit delay.12,34 It is important to detect the accompanying disorder, since patients with colonic inertia and gastric emptying delay have poorer outcomes from total colectomy. Therefore, an accurate diagnosis is essential to properly manage slow-transit motility disorders.

### Outcomes

An important outcome of interest to clinicians is the ability to diagnose slow-transit constipation. Other important clinical outcomes include the ability of testing to influence treatment decisions (e.g., medications, nutrition) or to affect patient-centered outcomes (e.g., symptom improvement, need for surgery, quality of life, patient satisfaction). It is also important to consider potential harms such as capsule retention, radiation exposure, and mortality. Clinicians and policymakers may also be interested in the effects on resource utilization such as the need for additional tests, physician services, and hospitalizations.

### Controversy

The 2011 ANMS conference addressed controversy regarding the role of capsule testing in the diagnostic evaluation of constipation. Experts debated the timing of wireless motility capsule in the evaluation of patients with suspected motility disorders, especially concerning the pending FDA approval for some of the newer prokinetic/secretagogue medications.

## Scope and Key Questions

Our objective is to summarize the evidence on how useful current testing modalities for colonic and gastric motility are for diagnosing disease. Additionally, we seek to determine whether wireless motility capsule testing is useful in conjunction with or instead of other testing modalities for diagnosing and managing delayed gastric emptying or slow-transit constipation. Our goal is to define the populations that would benefit most from motility testing, including wireless motility capsule testing.

### Key Questions

We finalized our Key Questions (KQs) below, and graphically depicted them in Figure 1:

KQ 1. In the evaluation of gastric dysmotility, how does the wireless motility capsule alone compare with gastric scintigraphy, antroduodenal manometry, and endoscopy in terms of diagnostic accuracy of gastric emptying delay, motility assessment, treatment decisions, patient-centered outcomes, harms, and resource utilization?

KQ 2. When gastric scintigraphy, antroduodenal manometry, or endoscopy is used in the evaluation of gastric dysmotility, what is the incremental value of also using the wireless motility capsule in terms of diagnostic accuracy of gastric emptying delay, motility assessment, treatment decisions, patient-centered outcomes, harms, and resource utilization?

KQ 3. In the evaluation of colonic dysmotility, how does the wireless motility capsule alone compare with ROM and scintigraphy in terms of diagnostic accuracy of slow-transit constipation, motility assessment, treatment decisions, patient-centered outcomes, harms, and resource utilization?

KQ 4. When an ROM or scintigraphy is used in the evaluation of colonic dysmotility, what is the incremental value of also using the wireless motility capsule in terms of diagnostic accuracy of slow-transit constipation, motility assessment, treatment decisions, patient-centered outcomes, harms, and resource utilization?

Figure 1 Analytic framework for research on the comparative effectiveness of diagnostic technologies for evaluating gastroparesis and constipation

KQ = Key Question

Analytic Framework: The figure is the analytic framework of the comparative effectiveness of diagnostic technologies for evaluation of gastroparesis and constipation. The figure has many boxes, bubbles, and arrows connecting them and it reads left to right. On the far left, the populations are described as adults with suspected gastroparesis and adults with suspected slow-transit constipation. There are arrows pointing from each population to separate boxes showing the types of tests, which denote key question one through key question four. In the tests for suspected gastroparesis, there are: wireless capsule testing alone which is key question one or in combination versus scintigraphy, antroduodenal manometry, endoscopy, which is key question two. The Tests for suspected slow-transit constipation are wireless capsule testing alone, which is key question three or in combination versus scintigraphy or radiopaque markers, which is key question four. The rest of the boxes and bubbles pertain to both key questions. From those tests are four arrows pointing to a box with motility assessment, a bubble with harms, a bubble with resource utilization, and a box with patient-centered outcomes. The motility assessment box includes transit time and pressure patterns, then points to a box with diagnostic accuracy including gastroparesis and slow-transit constipation. This box then points to Treatment decisions such as change in medications, change in nutrition, surgery, and referral. The harms bubble includes capsule retention, radiation exposure, and mortality. The resource utilization bubble includes test failure (unable to read test results), need for additional tests, and use of other healthcare services such as hospitalizations and physician visits. The patient-centered box, which has arrows from the tests boxes and from the treatment decisions box pointing to it, has symptom improvement, quality of life, and patient satisfaction. Overall, there is also an arrow going directly from the key questions boxes with tests to diagnostic accuracy and to treatment decisions.