# Associate Editor

- Thomas Trikalinos, M.D., Ph.D.
  Brown University
  Providence, RI