# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential non-financial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Gianrico Farrugia, M.D.
  Mayo Clinic
  Rochester, MN
- Robert S. Fisher, M.D.
  Temple University School of Medicine
  Philadelphia, PA
- Lauren Gerson, M.D., M.Sc.
  Stanford University School of Medicine
  Redwood City, CA
- C. Prakash Gyawali, M.D.
  Washington University in St. Louis
  St. Louis, MO
- William Hasler, M.D.
  University of Michigan
  Ann Arbor, MI
- Braden Kuo
  Massachusetts General Hospital
  Boston, MA
- Richard McCallum, M.D.
  Texas Tech University Health Sciences Center
  El Paso, TX
- Henry Parkman, M.D.
  Temple University
  Philadelphia, PA
- Satish Rao, M.B.B.S/
  Georgia Health Sciences University
  Augusta, GA
- William J. Snape, Jr., M.D.
  California Pacific Medical Center
  San Franscisco, CA
- Arnold Wald, M.D.
  University of Wisconsin School of Medicine and Public Health
  Madison, WI