# Acknowledgments

The Evidence-based Practice Center wish to thank the Key Informants, Technical Expert Panel, Peer Reviewers, Associate Editor, and Task Order Officer.