# Evidence Tables

Table 1 Study design characteristics of studies evaluating the wireless motility capsule

Table 2 Study population characteristics of studies evaluating the wireless motility capsule

Table 3 Diagnostic tests in studies evaluating wireless motility capsule

Table 4 Study quality of studies evaluating wireless motility capsule