# List of Excluded Articles

Adler DG, Chand B, Conway JD, Diehl DL, Kantsevoy SV, Kwon RS, Mamula P, Rodriguez SA, Shah RJ, Song LM, Tierney WM. Capsule endoscopy of the colon. Gastrointest Endosc. 2008;68(4):621-3. No original data. [pmid: 18926174].
Ahmad NA, Iqbal N, Joyce A. Clinical impact of capsule endoscopy on management of gastrointestinal disorders. Clin Gastroenterol Hepatol. 2008;6(4):433-7. Not wireless motility capsule; does not apply to key question. [pmid: 18325843].
Amano Y, Yuki T, Kusunoki R, Kinoshita Y. Gastric screening examination using PillCam ESO 2: a pilot study. Dig Liver Dis. 2011;43(7):580-1. Not wireless motility capsule. [pmid: 21324759].
Aparicio JR, Martinez J, Casellas JA. Right lateral position does not affect gastric transit times of video capsule endoscopy: a prospective study. Gastrointest Endosc. 2009;69(1):34-7. No subjects with gastroparesis or constipation. [pmid: 18620344].
Apostolopoulos P, Kalantzis C, Gralnek IM, Liatsos C, Tsironis C, Kalantzis N. Clinical trial: effectiveness of chewing-gum in accelerating capsule endoscopy transit time--a prospective randomized, controlled pilot study. Aliment Pharmacol Ther. 2008;28(4):405-11. No subjects with gastroparesis or constipation; not wireless motility capsule. [pmid: 18549462].
Atia A, Rammohan M, Ahn C, Hebuterne X, Girard-Pipau F, Buchman AL. Pectin supplementation increases colonic short chain fatty acid production(SCFA) in patients with short bowel syndrome(SBS). Gastroenterology. 2009;136(5):A140. No subjects with gastroparesis or constipation; no appropriate comparison.
Attaluri A, Valestin J, Rao SSC. Is small bowel and colonic motility altered in constipated patients with methanogenic flora?. Neurogastroenterol. Motil. 2010;22:79. No appropriate comparison. [pmid: 19614867].
Bai Y, Gao J, Song B, Zhou YQ, Zou DW, Li ZS. Surgical intervention for capsule endoscope retained at ileal stricture. Endoscopy. Suppl 1. 2007;39:E268-9. Not wireless motility capsule. [pmid: 17957648].
Baichi MM, Arifuddin RM, Mantry PS. What we have learned from 5 cases of permanent capsule retention. Gastrointest Endosc. 2006;64(2):283-7. Not wireless motility capsule. [pmid: 16860090].
Baker J, Hasler WL, Camilleri M, Rao S, Thorne NK, Ringel Y, Kuo B, Esfandyari T, Gupta AD, Scott SM, McCallum R, Parkman HP, Soffer EE, Di Baise JK. Impairment of overall and regional high amplitude colon contractions in severe slow transit constipation measured by wireless motility capsules. Gastroenterology. 2011;140(5):S531. No appropriate comparison.
Banerjee R, Reddy DN. Endoscopy-assisted wireless intragastric pH monitoring. Gastrointest Endosc. 2007;65(1):182. No original data; not wireless motility capsule. [pmid: 17185108].
Berry PA, Srirajaskanthan R, Anderson SH. An urgent call to the magnetic resonance scanner: potential dangers of capsule endoscopy. Clin Gastroenterol Hepatol. 2010;8(5):A26. No original data; not wireless motility capsule. [pmid: 19747984].
Biao H, Guozheng Y, Peng Z. Multi-sensor radiotelemetry system for intestinal motility measurement. J Med Eng Technol. 2009;33(1):66-71. No subjects with gastroparesis or constipation. [pmid: 19116855].
Bosworth BP, Cohen M, Weine DM, Scherl EJ. Colonic pH is lower in patients with mild ulcerative colitis compared to normal controls. Gastroenterology. 2009;136(5):A682-A683. Other exclusion.
Bredenoord AJ, Stolk MF, Al-toma A. Unintentional video capsule bronchoscopy. Eur J Gastroenterol Hepatol. 2009;21(5):593. Not wireless motility capsule. [pmid: 19190498].
Brun, Michalek W, Surjanhata BC, Parkman HP, Semler JR, Kuo B. Comparative analysis of phase III migrating motor complexes in stomach and small bowel using wireless motility capsule and antroduodenal manometry. Neurogastroenterol Motil. 2012;24(4):332-e165. No subjects with gastroparesis or constipation; other exclusion. [pmid: 22292793].
Brun M, Michalek W, McCallum R, Koch KL, Sitrin MD, Wo JM, Hasler WL, Parkman HP, Semler JR, Kuo B. Comparison of small bowel postprandial response in healthy, gastroparetic and constipated subjects as measured by Wireless Motility Capsule (WMC). Gastroenterology. 2010;138(5):S459. No appropriate comparison.
Brun M, Michalek W, Surjanhata B, Kuo B. Small bowel transit time (Sbtt) by Wireless Motility Capsule (WMC): Normal values and analysis of pressure profiles in different subgroups of patients with slow sbtt. Gastroenterology. 2011;140(5):S865. No appropriate comparison.
Brun R, Michalek W, Kuo B. Cephalic phase of small bowel fed response as measured by wireless motility capsule (WMC). Neurogastroenterol. Motil. 2011;23:15. No appropriate comparison.
Brun R, Surjanhata B, Kuo B. PH profiles of gi tract by wireless motility capsule (WMC) in healthy (H), gastroparetics (GP) and constipated (C). Neurogastroenterol. Motil. 2011;23:15. No appropriate comparison.
Brun R, Surjanhata B, Michalek W, Baker JR, Wilding G, Hasler W, Kuo B. Mild and severe gastroparesis (gp) as defined by wireless motility capsule (wmc)-comparison of clinical characteristics and pressure profiles. Neurogastroenterol. Motil. 2011;23:37. No appropriate comparison.
Buchanan LA, Reddy SC, Gray M, Eversmann J, Wo JM. Motility parameters and luminal pH does not correlate with small intestinal bacterial overgrowth in patients with chronic idiopathic constipation. Gastroenterology. 2011;140(5):S813. No appropriate comparison.
Bucur MC, Michalek W, McCallum R, Koch KL, Sitrin MD, Chey WD, Hasler WL, Katz LA, Parkman HP, Rao SS, Semler JR, Kuo B. The impact of using different standardized meals in the assessment of motility of upper gastrointestinal tract. Gastroenterology. 2009;136(5):A781. No appropriate comparison; no outcome of interest.
Cassilly D, Kantor S, Knight LC, Maurer AH, Fisher RS, Semler J, Parkman HP. Gastric emptying of a non-digestible solid: assessment with simultaneous SmartPill pH and pressure capsule, antroduodenal manometry, gastric emptying scintigraphy. Neurogastroenterol Motil. 2008;20(4):311-9. Does not apply to key question; other exclusion. [pmid: 18194154].
Chaw CS, Yazaki E, Evans DF. The effect of pH change on the gastric emptying of liquids measured by electrical impedance tomography and pH-sensitive radiotelemetry capsule. Int J Pharm. 2001;227(1-2):167-75. No subjects with gastroparesis or constipation; not wireless motility capsule. [pmid: 11564551].
Chen HB, Huang Y, Chen SY, Song HW, Li XL, Dai DL, Xie JT, He S, Zhao YY, Huang C, Zhang SJ, Yang LN. Small bowel preparations for capsule endoscopy with mannitol and simethicone: a prospective, randomized, clinical trial. J Clin Gastroenterol. 2011;45(4):337-41. Not wireless motility capsule; no appropriate comparison. [pmid: 20871410].
Dukes G, Barton M, Stephens K, Haberer L, Richards D, Loehrer F, Yuan J, Verbeke K, Hobson A, Young M, Williams P. Pharmacokinetics, safety/tolerability, and effect on gastric emptying of the oral motilin receptor agonist, GSK1322888, in healthy male Caucasian and Japanese Asian volunteers. Neurogastroenterol. Motil. 2011;23:45. No appropriate comparison. [pmid: 20939848].
Endo H, Matsuhashi N, Inamori M, Ohya T, Iida H, Mawatari H, Nozaki Y, Yoneda K, Akiyama T, Fujita K, Takahashi H, Yoneda M, Abe Y, Kobayashi N, Kirikoshi H, Kubota K, Saito S, Nakajima A. Abdominal surgery affects small bowel transit time and completeness of capsule endoscopy. Dig Dis Sci. 2009;54(5):1066-70. Not wireless motility capsule. [pmid: 18719999].
Farrar JT, Berkley C, Zworykin VK. Telemetering of intraenteric pressure in man by an externally energized wireless capsule. Science. 1960;131(3416):1814. No original data Not wireless motility capsule; no appropriate comparison. [pmid: 13821627].
Fernandez-Urien I, Borobio E, Elizalde I, Irisarri R, Vila JJ, Urman JM, Jimenez J. Z-line examination by the PillCam SB: prospective comparison of three ingestion protocols. World J Gastroenterol. 2010;16(1):63-8. Not wireless motility capsule. [pmid: 20039450].
Ferreira F, Bastos P, Cardoso H, Nunes AC, Macedo G. Retention of endoscopic capsule in an umbilical hernia. Endoscopy. Suppl 2. UCTN. 2011;43:E111-2. Not wireless motility capsule. [pmid: 21425000].
Gao YJ, Ge ZZ, Chen HY, Li XB, Dai J, Ye CA, Xiao SD. Endoscopic capsule placement improves the completion rate of small-bowel capsule endoscopy and increases diagnostic yield. Gastrointest Endosc. 2010;72(1):103-8. Not wireless motility capsule. [pmid: 20304397].
Gelfond D, Wilding G, Semler JR, O'Hara T, Borowitz D. Reproducibility of proximal small intestinal pH profiles in patients with cystic finbrosis and controls. Pediatr. Pulmonol. 2010;45:425. No appropriate comparison.
Girelli CM, Maiero S, Porta P, Cannizzaro R. Small bowel capsule endoscopy performance in octogenarians: a case-control study. J Gerontol A Biol Sci Med Sci. 2011;66(1):68-73. Not wireless motility capsule. [pmid: 20974730].
Gerson LB. Tu1484 Cost-Effectiveness of Wireless Capsule Motilty for Patients Wtih Suspected Functional Gastrointestinal Disorders. Gastroenterology. 2012;142(5, Supplement 1):S-845. No outcome of interest.
Gray M, Reddy SC, Falkner KC, Buchanan LA, Eversmann J, Cave MC, Dryden GW, Wo JM. Gut hormone profile is altered in patients with chronic idiopathic constipation. Gastroenterology. 2011;140(5):S479. No outcome of interest.
Guerrero R, Lara LF, Browning JD. A case of diarrhea, ataxia, and capsule endoscope retention. Dig Dis Sci. 2007;52(11):3174-7. No subjects with gastroparesis or constipation Not wireless motility capsule. [pmid: 17406819].
Hasler WL, Coleski R, Chey WD, Koch KL, McCallum RW, Wo JM, Kuo B, Sitrin MD, Katz LA, Hwang J, Semler JR, Parkman HP. Differences in intragastric pH in diabetic vs. idiopathic gastroparesis: relation to degree of gastric retention. Am J Physiol Gastrointest Liver Physiol. 2008;294(6):G1384-91. No appropriate comparison; no outcome of interest. [pmid: 18403619].
Hasler WL, Kuo B, Gudleski GD, Lackner JM, Baker J. Relation of wireless motility capsule gastric emptying times and gastrointestinal pressure parameters to symptom reports in gastroparesis: The search for a motor cause of symptoms. Gastroenterology. 2011;140(5):S803. No appropriate comparison.
Hasler WL, McCallum R, Rao SS, Paulson JA, Koch KL, Sitrin MD, Saad RJ, Chey WD, DiBaise JK, Parkman HP, Kuo B, Semler JR. Region-specific motor patterns and pH profiles in unprepared human colon quantified by simultaneous radiography and wireless capsule measurements. Gastroenterology. 2009;136(5):A225-A226. Does not apply to key question.
Hasler WL, Parkman H, Rao S, Chey WD, Mccallum R, Kuo B, Koch K, Sitrin M, Semler JR. Efficacy of colon propulsion in health and constipation measured by wireless motility capsules: Role of associated IBS and relation to colon contractile activity. Neurogastroenterol. Motil. 2010;22:8. No subjects with gastroparesis or constipation; no appropriate comparison.
Hasler WL, Rao SS, Parkman HP, Saad RJ, Chey WD, McCallum R, Kuo B, Koch KL, Sitrin MD, DiBaise JK, Rohde B, Semler JR. Bristol stool form in slow transit constipation correlates inversely with regional colon contractile activity measured by a wireless motility capsule. Gastroenterology. 2010;138(5):S628. No appropriate comparison.
Hejazi R, Reddymasu S, Semler J, McCallum R. Postprandial gastric motility parameters assessed by the wireless motility capsule method are complimentary to gastric transit time measurement for the diagnosis of gastroparesis. Am. J. Gastroenterol. 2011;106:S515. No appropriate comparison.
Huang B, Yan G, Zan P, Li Q. Study on gastric interdigestive pressure activity based on phase space reconstruction and FastICA algorithm. Med Eng Phys. 2009;31(3):320-7. No original data; no subjects with gastroparesis or constipation. [pmid: 18672390].
Iddan G, Meron G, Glukhovsky A, Swain P. Wireless capsule endoscopy. Nature. 2000;405(6785):417. No original data; no appropriate comparison. [pmid: 10839527].
Iida H, Endo H, Sekino Y, Sakai E, Uchiyama T, Ozono K, Fujiwara K, Hosono M, Nonaka T, Sakamoto Y, Fujita K, Yoneda M, Koide T, Takahashi H, Tokoro C, Goto A, Abe Y, Gotoh E, Maeda S, Nakajima A, Inamori M. A New Non-Invasive Modality for Recording Sequential Images and the pH of the Small Bowel. Hepatogastroenterology. 2011;59(114). No subjects with gastroparesis or constipation.
Kalantzis C, Triantafyllou K, Papadopoulos AA, Alexandrakis G, Rokkas T, Kalantzis N, Ladas SD. Effect of three bowel preparations on video-capsule endoscopy gastric and small-bowel transit time and completeness of the examination. Scand J Gastroenterol. 2007;42(9):1120-6. Not wireless motility capsule. [pmid: 17710680].
Katsinelos P, Tziomalos K, Fasoulas K, Paroutoglou G, Koufokotsios A, Mimidis K, Terzoudis S, Maris T, Beltsis A, Geros C, Chatzimavroudis G. Can capsule endoscopy be used as a diagnostic tool in the evaluation of nonbleeding indications in daily clinical practice? A prospective study. Med Princ Pract. 2011;20(4):362-7. Not wireless motility capsule. [pmid: 21576998].
Kelley SR, Lohr JM. Retained wireless video enteroscopy capsule: a case report and review of the literature. J Surg Educ. 2009;66(5):296-300. No original data; not wireless motility capsule. [pmid: 20005505].
Kloetzer L, Kuo B, Semler J. The discriminative ability of the smartpill test in defining motility dysfunction in upper GI tract. Neurogastroenterol. Motil. 2009;21:6-7. No appropriate comparison. [pmid: 19140954].
Korenblit J, Gournani K, Oppong Y, et al. A retrospective analysis of wireless capsule endoscopy performance at a large academic referral center. Gastrointest Endosc. 2012;75(4):AB267-AB8. No subjects with gastroparesis or constipation.
Liao Z, Gao R, Li F, Xu C, Zhou Y, Wang JS, Li ZS. Fields of applications, diagnostic yields and findings of OMOM capsule endoscopy in 2400 Chinese patients. World J Gastroenterol. 2010;16(21):2669-76. Not wireless motility capsule. [pmid: 20518090].
Magdeburg R, Riester T, Hummel F, Lohr M, Post S, Sturm J. Ileus secondary to wireless capsule enteroscopy. Int J Colorectal Dis. 2006;21(6):610-3. No subjects with gastroparesis or constipation; not wireless motility capsule. [pmid: 16411112].
Maqbool S, Parkman HP, Friedenberg FK. Wireless capsule motility: comparison of the SmartPill GI monitoring system with scintigraphy for measuring whole gut transit. Dig Dis Sci. 2009;54(10):2167-74. Does not apply to key question Other exclusion. [pmid: 19655250].
Meduri K, Attaluri A, Valestin J, Schey R, Rao SS. Is small bowel and colonic pH altered in small intestinal bacterial overgrowth?. Gastroenterology. 2011;140(5):S532. No appropriate comparison.
Michalek W, Kuo B. Analysis of upper GI migrating motor complexes using invasive and non-invasive techniques. Neurogastroenterol. Motil. 2010;22:64-65. No subjects with gastroparesis or constipation; no appropriate comparison.
Michalek W, Bucur MC, McCallum R, Koch KL, Sitrin MD, Chey WD, Hasler WL, Parkman HP, Rao SS, Semler JR, Kuo B. A comparison of small bowel pH profiles in healthy subjects and patients with gastroparesis as measured by a non-invasive wireless capsule. Gastroenterology. 2009;136(5):A683-A684. No appropriate comparison.
Michalek W, Bucur MC, McCallum R, Koch KL, Sitrin MD, Chey WD, Hasler WL, Parkman HP, Rao SS, Semler JR, Kuo B. Impact of age on upper gastrointestinal function in healthy and gastroparetic populations, as measured by a non-invasive wireless capsule. Gastroenterology. 2009;136(5):A144. No appropriate comparison.
Michalek W, Chang K, Kuo B. Spectral analysis of GI motility comparing various gastric regions. Neurogastroenterol. Motil. 2010;22:64. No appropriate comparison.
Michalek W, Neuman S, Kloetzer L, Foy C, Semler JR, Kuo B. Impact of acid suppression on upper gastrointestinal function as measured by a non-invasive wireless pH and motility capsule. Gastroenterology. 2009;136(5):A186-A187. No appropriate comparison.
Michalek W, Parkman HP, Rohde B, Buckley PE, Powers J, Semler JR, Kuo B. Measuring gastric contractility during the fed and fasting state: Invasive versus non-invasive comparison. Gastroenterology. 2010;138(5):S467-S468. No appropriate comparison; no outcome of interest.
Michalek W, Parkman HP, Rohde B, Buckley PE, Powers J, Semler JR, Kuo B. Spectral analysis of the dominant frequency of upper GI motility-assessment of invasive versus non-invasive techniques. Gastroenterology. 2010;138(5):S467. No subjects with gastroparesis or constipation.
Michalek W, Parkman H, Rhode B, Buckley P, Powers J, Semler J, Kuo B. Optimal pressure thresholds for UGI motility assessment: Invasive vs non-invasive techniques. Neurogastroenterol. Motil. 2010;22:65. No appropriate comparison.
Michalek W, Semler JR, Kuo B. Impact of acid suppression on upper gastrointestinal pH and motility. Dig Dis Sci. 2011;56(6):1735-42. Does not apply to key question; other exclusion. [pmid: 21086166].
Mikolajczyk A, Surma B, Rubin D. Assessment of tandem measurements of PH and total gut transit time in healthy volunteers. Am. J. Gastroenterol. 2011;106:S502-S503. No appropriate comparison.
Mojaverian P, Reynolds JC, Ouyang A, Wirth F, Kellner PE, Vlasses PH. Mechanism of gastric emptying of a nondisintegrating radiotelemetry capsule in man. Pharm Res. 1991;8(1):97-100. No appropriate comparison. [pmid: 2014217].
Monkemuller K, Olano C, Fry LC, Ulbricht LJ. Small-bowel endoscopy. Endoscopy. 2009;41(10):872-7. No original data; not wireless motility capsule. [pmid: 19798613].
Monthira M, Saab R, Hasler W, Kuo B, Chey WD. Do circadian changes in colonic motility differ between healthy volunteers and patients with chronic constipation? Insights yielded by a noninvasive, wireless pH and motility capsule. Neurogastroenterol. Motil. 2009;21:37. No appropriate comparison; no outcome of interest.
Mreyoud A, Rozov I, Moore J, Wilding GE, Khawam E, Lackner JM, Semler JR, Sitrin MD. Assessment of drug effects on gastric emptying and contractility using wireless capsule manometry. Gastroenterology. 2009;136(5):A536. No subjects with gastroparesis or constipation; no appropriate comparison.
Mungan Z, Pinarbasi B, Akyuz F, Bektas H, Akyuz A. Wireless endoscopy capsule remaining safely for a long time. Dig Dis Sci. 2008;53(5):1422-3. Not wireless motility capsule. [pmid: 18343997].
Nagula S, Jarnagin WR, O'Reilly EM, Schattner MA. Capsule-induced small-bowel obstruction during video capsule endoscopy in a patient with carcinomatosis. Dig Dis Sci. 2010;55(6):1778-80. No subjects with gastroparesis or constipation; not wireless motility capsule. [pmid: 19657736].
Nakaji K. Retrieval of impacted capsule endoscopy at the cricopharyngeus. Dig Endosc. 2010;22(1):76. Not wireless motility capsule. [pmid: 20078673].
Nakamura M, Ohmiya N, Miyahara R, Ando T, Watanabe O, Kawashima H, Itoh A, Hirooka Y, Niwa Y, Goto H. Are symptomatic changes in irritable bowel syndrome correlated with the capsule endoscopy transit time? A pilot study using the 5-HT4 receptor agonist mosapride. Hepatogastroenterology. 2011;58(106):453-8. No subjects with gastroparesis or constipation; not wireless motility capsule. [pmid: 21661412].
Nakamura M, Ohmiya N, Shirai O, Takenaka H, Kenji, Morishima, Miyahara R, Ando T, Watanabe O, Kawashima H, Itoh A, Hirooka Y, Niwa Y, Goto H. Advance of video capsule endoscopy and the detection of anatomic landmarks. Hepatogastroenterology. 2009;56(96):1600-5. Not wireless motility capsule. [pmid: 20214201].
Nathan SR, Biernat L. Aspiration--an important complication of small-bowel video capsule endoscopy. Endoscopy. Suppl 1. 2007;39:E343. Not wireless motility capsule. [pmid: 18273788].
Ogata H, Kumai K, Imaeda H, Aiura K, Hisamatsu T, Okamoto S, Iwao Y, Sugino Y, Kitajima M, Hibi T. Clinical impact of a newly developed capsule endoscope: usefulness of a real-time image viewer for gastric transit abnormality. J Gastroenterol. 2008;43(3):186-92. No subjects with gastroparesis or constipation ; not wireless motility capsule. [pmid: 18373160].
Pallotta N, Fiorino G, Romeo E, Cesarini M, Ciccantelli B, Vincoli G, Vernia P, Carabotti M, Cucchiara S, Corazziari E. Different segmental transit time (TT) through the small bowel May affect wireless capsule (WC) endoscopy. Gastroenterology. 2009;136(5):A350. No subjects with gastroparesis or constipation; not wireless motility capsule.
Parkman HP. Assessment of gastric emptying and small-bowel motility: scintigraphy, breath tests, manometry, and SmartPill. Gastrointest Endosc Clin N Am. 2009;19(1):49-55. vi. No original data. [pmid: 19232280].
Parkman HP, Pizzuto C, Semler J. Kuo Assessment of gastric contractility with wireless capsule motility: use of short 5 min intervals. Neurogastroenterol. Motil. 2009;21:74-75. No appropriate comparison.
Pastore S, Gortani G, Maschio M, Di Leo G, Ventura A. Two lumens, one diagnosis. J Pediatr. 2011;159(3):511. Not wireless motility capsule ; not adult. [pmid: 21645910].
Purdy M, Heikkinen M, Juvonen P, Voutilainen M, Eskelinen M. Characteristics of patients with a retained wireless capsule endoscope (WCE) necessitating laparotomy for removal of the capsule. In Vivo. 2011;25(4):707-10. Not wireless motility capsule. [pmid: 21709019].
Qasim A, Ryan B, Breslin N, O'Morain C. Gastric retention and wireless capsule endoscopy in adults: a modified technique for direct duodenal deployment. Gut. 2010;59(7):1004-5. author reply 1005. Not wireless motility capsule ; not adult. [pmid: 20581250].
Qian JM. Pay attention to the complications encountered in capsule endoscopy. Zhonghua Nei Ke Za Zhi. 2008;47(1):3. No original data; not wireless motility capsule. [pmid: 18346314].
Rao SSC, Valestin J, Semler J. Can wireless motility capsule (WMC) recording distinguish patients with dyssynergic defecation from non-dyssynergic constipation?. Neurogastroenterol. Motil. 2011;23:22. No appropriate comparison.
Rauch S, Krueger K, Turan A, Roewer N. Gastric emptying in critically ill trauma patients using a novel motility capsule. Eur. J. Anaesthesiol. 2009;26:170. No appropriate comparison.
Rauch S, Krueger K, Turan A, Roewer N, Sessler DI. Clinical experience in the placement of a novel motility capsule by using a capsule delivery device in critical care patients. Endoscopy. Suppl 2. 2010;42:E77-8. No original data; no appropriate comparison. [pmid: 20195974].
Reddy SC, Buchanan LA, Gray M, Eversmann J, Wright R, Wo JM. Effects on segmental GI transit and physiologic parameters by lubiprostone in patients with chronic idiopathic constipation. Gastroenterology. 2011;140(5):S31. Not wireless motility capsule; no appropriate comparison.
Repici A, Barbon V, De Angelis C, Luigiano C, De Caro G, Hervoso C, Danese S, Preatoni P, Pagano N, Comunale S, Pennazio M, Rizzetto M. Acute small-bowel perforation secondary to capsule endoscopy. Gastrointest Endosc. 2008;67(1):180-3. Not wireless motility capsule. [pmid: 17981271].
Ringel-Kulka T, Maier DM, DeMaria N, Galanko J, Jackson J, Fedor-Hammonds L, Ringel Y. Alterations in intestinal transit in subgroups of patients with functional bowel disorders and healthy controls - A wireless motility capsule study. Gastroenterology. 2010;138(5):S626. No appropriate comparison.
Ringel-Kulka T, Siddle JP, Maier DM, Galanko JA, Semler JR, Ringel Y. Intestinal fermentation assessed by intraluminal pH in subjects with abdominal bloating. Gastroenterology. 2011;140(5):S709. No subjects with gastroparesis or constipation.
Rogers AM, Kuperman E, Puleo FJ, Shope TR. Intestinal obstruction by capsule endoscopy in a patient with radiation enteritis. JSLS. 2008;12(1):85-7. Not wireless motility capsule; no outcome of interest. [pmid: 18402746].
Saad RJ, Chey WD, Rao SS, Hasler WL, Katz LA, Koch KL, Kuo B, Lackner JM, Parkman HP, McCallum R, Miller C, Sarosiek I, Semler J, Sitrin MD, Wilding GE. Reduced stool frequency does not predict colonic and whole gut transit in constipated patients. Gastroenterology. 2009;136(5):A373. Other exclusion.
Saad RJ, Semler JR, Wilding GE, Chey WD. The effect of age on regional and whole gut transit times in healthy adults. Gastroenterology. 2010;138(5):S127. No subjects with gastroparesis or constipation; no appropriate comparison.
Saad RJ, Wilding GE, Semler JR, Chey WD. Obesity is associated with changes in gastrointestinal and colonic transit in constipated but not healthy adults. Neurogastroenterol. Motil. 2011;23:22. No appropriate comparison.
Sachdeva P, Kantor S, Knight LC, Maurer AH, Fisher RS, Parkman HP. Use of a high caloric liquid meal (Ensure Plus) as a alternative meal for gastric emptying scintigraphy. Gastroenterology. 2010;138(5):S715-S716. No subjects with gastroparesis or constipation; no outcome of interest.
Said EM. Capsule endoscopy in a district general hospital. BMJ. 2008;337:a905. Not wireless motility capsule. [pmid: 18647783].
Sarosiek I, Alvarez A, Romero R, Semler J, McCallum RW. Prolonged cecal residence time identified by wireless technology: A new symptoms explantation for some patients with chronic constipation. Neurogastroenterol. Motil. 2011;23:22-23. Not wireless motility capsule; no appropriate comparison.
Sarosiek I, Rao S, Koch KL, Parkman HP, Sarosiek J, Semler J, McCallum RW. Identification of cecal residence time using wireless technology: A new concept pertaining to constipation and delayed colon transit. Neurogastroenterol. Motil. 2009;21:25. No appropriate comparison; other exclusion.
Sarosiek I, Sochacka B, Roeser K, Sarosiek J, McCallum R. Does small intestinal bacterial overgrowth affect pH readings as recorded by wireless motility capsule technology in the GI tract?. Gastroenterology. 2010;138(5):S669. No appropriate comparison; no outcome of interest.
Sarosiek I, Sochacka B, Roeser K, Sarosiek J, Mccallum RW. Influence of small intestinal bacterial overgrowth on motility index parameters and transit time recorded by wireless motility capsule technology. Neurogastroenterol. Motil. 2010;22:27-28. No appropriate comparison.
Schnoll-Sussman F. Achieving complete small-bowel capsule endoscopy: is it possible and does it matter?. Gastrointest Endosc. 2010;72(1):109-11. No original data Not wireless motility capsule. [pmid: 20620277].
Semler JR, Swallow EW, Kuo B. Su1014 Prevalence of Repeat Testing for GI Symptoms Potentially Indicative of Functional and Motility Disorders. Gastroenterology. 2012;142(5, Supplement 1):S-399-S-400. No outcome of interest.
Shiff AD, Gurudu S, Decker GA, Leighton JA. False-positive wireless video capsule secondary to performing a simultaneous sigmoidoscopy. Am J Gastroenterol. 2009;104(4):1070. Not wireless motility capsule. [pmid: 19319129].
Sidhu R, McAlindon ME. Age should not be a barrier to performing capsule endoscopy in the elderly with anaemia. Dig Dis Sci. 2011;56(8):2497-8. No subjects with gastroparesis or constipation; not wireless motility capsule. [pmid: 21706203].
Sidhu R, Sanders DS, Kapur K, Hurlstone DP, McAlindon ME. Capsule endoscopy changes patient management in routine clinical practice. Dig Dis Sci. 2007;52(5):1382-6. Not wireless motility capsule. [pmid: 17357836].
Tacheci I, Ryska A, Rejchrt S, Kopacova M, Horava V, Bures J. Spontaneous disintegration of a retained video capsule in a patient with cryptogenic multifocal ulcerous stenosing enteritis: a rare complication. Endoscopy. Suppl 2. 2008;40:E104-5. Not wireless motility capsule. [pmid: 19085708].
Tanimura T, Adachi K, Furuta K, Ohara S, Morita T, Koshino K, Miki M, Kinoshita Y. Usefulness of catheterless radiotelemetry pH monitoring system to examine the relationship between duodenal acidity and upper gastrointestinal symptoms. J Gastroenterol Hepatol. 2011;26(1):98-103. Not wireless motility capsule. [pmid: 21175801].
Thorne N, Culler S, Griffin L, Koch K, Long JD. Do patients with delayed transit constipation have a higher prevalence of delayed upper gut transit?. Neurogastroenterol. Motil. 2010;22:36-37. No appropriate comparison. [pmid: 19712111].
Timm DA, Willis H, Thomas W, Willis D, Sanders L, Boileau T, Holmberg D, Slavin JL. The use of a new wireless motility device (SmartPill(registered trademark)) for measurement of gastrointestinal transit time after dietary fiber intervention. Gastroenterology. 2010;138(5):S462. No appropriate comparison.
Timm D, Willis H, Thomas W, Sanders L, Boileau T, Slavin J. The use of a wireless motility device (SmartPill(R)) for the measurement of gastrointestinal transit time after a dietary fibre intervention. Br J Nutr. 2011;105(9):1337-42. Other exclusion. [pmid: 21138605].
Triantafyllou K, Kalantzis C, Papadopoulos AA, Apostolopoulos P, Rokkas T, Kalantzis N, Ladas SD. Video-capsule endoscopy gastric and small bowel transit time and completeness of the examination in patients with diabetes mellitus. Dig Liver Dis. 2007;39(6):575-80. Not wireless motility capsule. [pmid: 17433797].
Triantafyllou K, Kalli T, Danias NG. Spontaneous resolution of capsule endoscope retention in a normal small bowel after 2.5 years. Endoscopy. Suppl 2. 2010;42:E87-8. Not wireless motility capsule. [pmid: 20195980].
Um S, Poblete H, Zavotsky J. Small bowel perforation caused by an impacted endocapsule. Endoscopy. Suppl 2. 2008;40:E122-3. No subjects with gastroparesis or constipation; not wireless motility capsule. [pmid: 18633864].
Venecourt-Jackson E, Maharaj I. A rare complication of wireless capsule endoscope. N Z Med J. 2009;122(1289):81-4. No original data; not wireless motility capsule. [pmid: 19305454].
Visser L, Lieshout L. Unexpected cause of iron deficiency detected by capsule endoscopy. Neth J Med. 2009;67(9):317. author reply 317. No subjects with gastroparesis or constipation. [pmid: 19841493].
Wang TD. A novel capsule endoscope: do we need new kids on the block?. Gastrointest Endosc. 2009;69(2):260-1. No original data. [pmid: 19185688].
Ward EM, Devault KR, Bouras EP, Stark ME, Wolfsen HC, Davis DM, Nedrow SI, Achem SR. Successful oesophageal pH monitoring with a catheter-free system. Aliment Pharmacol Ther. 2004;19(4):449-54. Not wireless motility capsule. [pmid: 14871285].
Watson BW, Meldrum SJ, Riddle HC, Brown RL, Sladen GE. pH profile of gut as measured by radiotelemetry capsule. Br Med J. 1972;2(5805):104-6. No subjects with gastroparesis or constipation; not wireless motility capsule. [pmid: 5018285].
Williams RE 3rd, Bauman WA, Spungen AM, Vinnakota RR, Farid RZ, Galea M, Korsten MA. SmartPill technology provides safe and effective assessment of gastrointestinal function in persons with spinal cord injury. Spinal Cord. 2012;50(1):81-4. Does not apply to key question; other exclusion. [pmid: 21876549].
Williams RE, Vinnakota RR, Dhungel N, Farid RZ, Galea MD, Kothari TH, Spungen AM, Bauman W, Korsten MA. Gastroparesis in asymptomatic persons with paraplegia: Diagnosis made with smartpill(registered trademark) Technology. Gastroenterology. 2010;138(5):S345. No appropriate comparison.
Williams RE, Vinnakota RR, Farid RZ, Dhungel N, Galea MD, Kothari TH, Spungen AM, Bauman W, Korsten MA. Neurogenic bowel in persons with spinal cord injury: An evaluation using smartpill(registered trademark) technology. Gastroenterology. 2010;138(5):S587. No appropriate comparison; no outcome of interest.
Willis HJ, Thomas W, Willis DJ, Slavin JL. Feasibility of measuring gastric emptying time, with a wireless motility device, after subjects consume fiber-matched liquid and solid breakfasts. Appetite. 2011;57(1):38-44. Does not apply to key question; other exclusion. [pmid: 21435365].
Zarate N, Mohammed SD, O'Shaughnessy E, Newell M, Yazaki E, Williams NS, Lunniss PJ, Semler JR, Scott SM. Accurate localization of a fall in pH within the ileocecal region: validation using a dual-scintigraphic technique. Am J Physiol Gastrointest Liver Physiol. 2010;299(6):G1276-86. Does not apply to key question; other exclusion. [pmid: 20847301].
Zarate N, Mohammed S, O'Shaughnessy E, Newell M, Yazaki E, Semler J, Scott SM. Accurate localisation of a fall in pH within the ileo-caecal region. Neurogastroenterol. Motil. 2009;21:43. No subjects with gastroparesis or constipation; no appropriate comparison.