# Forms

Title Review Form

This form is a copy of the online software Distiller by Evidence Partners. It gives an example showing a title citation with refid, title, and authors of a given citation, then the choice of yes or no to include, answering the question that asks Is this citation potentially relevant to the wireless motility capsule review i.e. it evaluates the wireless motility capsule (SmartPill), gastric or conlonic transit, motility?

Abstract Review Form

This form is a copy of the online software Distiller by Evidence Partners. It gives an example showing a title citation with refid, title, and authors of a given citation, then the abstract of that reference. Then, you can chose to exclude based on our exclusion criteria, include, flag for handsearch, mark as unclear, or add comments. A table reminding the reviewers of the included tests for review.

Article Review Form

This form is a copy of the online software Distiller by Evidence Partners. It gives an example showing a title citation with refid, title, and authors of a given citation, then the abstract of that reference, as well as a link to the full text pdf of the article. Then, the reviewer can choose to include based on our inclusion criteria, exclude, flag for handsearch, and add comments. There is a reminder box with our included tests.

Data Abstraction Forms