# Detailed Electronic Database Search Strategies

PubMed Strategy

Search # | Search String | # Hits
#1 | “Capsule Endoscopy”[mh] | 1316
#2 | (Wireless[tiab] OR radiotelemetr*[tiab]) AND (motility[tiab] OR capsule*[tiab]) | 708
#3 | Smartpill*[tiab] | 13
#4 | #1 OR #2 OR #3 | 1800
#5 | (animal[mh] NOT human [mh]) | 3685271
#6 | #4 NOT #5 | 1751

EMBASE Strategy

Search # | Search String | # Hits
#1 | (Wireless:ti,ab OR radiotelemetr*:ti,ab) AND (motility:ti,ab OR capsule*:ti,ab) | 1090
#2 | Smartpill:ti,ab | 74
#3 | #1 OR #2 | 1106
#4 | ([animals]/lim NOT [humans]/lim) | 4640790
#5 | #3 NOT #4 | 1033