# Abbreviations

ACG: American College of Gastroenterology
AGA: American Gastroenterological Association
AHRQ: Agency for Healthcare Research and Quality
ANMS: American Neurogastroenterology and Motility Society
AUC: area under the curve
CI: confidence interval
COV: coefficient of variance
cph: contractions per hour
CTT: colonic transit time
EPC: Evidence-based Practice Center
FDA: U.S. Food and Drug Administration
G PM: gastric pressure measurements
G/SB PM: gastric/small bowel pressure measurements
GES: gastric emptying scintigraphy
GES-2hr: gastric emptying via scintigraphy at 2 hours
GES-4hr: gastric emptying via scintigraphy at 4 hours
GET: gastric emptying time
GI: gastrointestinal
GRADE: Grading of Recommendations Assessment Development and Evaluation
hr: hours
KQ: key question
min: minutes
mmHg: millimeters of mercury
NA or N/A: not applicable
NR: not reported
PPI: proton pump inhibitor
ROC: receiver operating characteristic
ROM: radiopaque markers
SB: small bowel
SB PM: small bowel pressure measurements
SBTT: small bowel transit time
SD: standard deviation
T50: time of 50% emptying
T90: time of 90% emptying
U.S.: United States
WGTT: whole gut transit time
WMC: wireless motility capsule