# References

1 Bolen J, Helmick CG, Sacks JJ, Langmaid G. (2002). Prevalence of self-reported arthritis or chronic joint symptoms among adults--United States, 2001. MMWR Morb Mortal Wkly Rep.
2 Husted JA, Gladman DD, Farewell VT, Cook RJ. (2001). Health-related quality of life of patients with psoriatic arthritis: a comparison with patients with rheumatoid arthritis. Arthritis Rheum.
3 Sokoll KB, Helliwell PS. (2001). Comparison of disability and quality of life in rheumatoid and psoriatic arthritis. J Rheumatol.
4 Borman P, Toy GG, Babaoglu S, Bodur H, Ciliz D, Alli N. (2006). A comparative evaluation of quality of life and life satisfaction in patients with psoriatic and rheumatoid arthritis. Clin Rheumatol.
5 Mau W, Listing J, Huscher D, Zeidler H, Zink A. (2005). Employment across chronic inflammatory rheumatic diseases and comparison with the general population. J Rheumatol.
6 Michaud K, Messer J, Choi HK, Wolfe F. (2003). Direct medical costs and their predictors in patients with rheumatoid arthritis: a three-year study of 7,527 patients. Arthritis Rheum.
7 Hallert E, Husberg M, Skogh T. (2006). Costs and course of disease and function in early rheumatoid arthritis: a 3-year follow-up (the Swedish TIRA project). Rheumatology (Oxford).
8 Huscher D, Merkesdal S, Thiele K, Zeidler H, Schneider M, Zink A. (2006). Cost of illness in rheumatoid arthritis, ankylosing spondylitis, psoriatic arthritis and systemic lupus erythematosus in Germany. Ann Rheum Dis.
9 Ozminkowski RJ, Burton WN, Goetzel RZ, Maclean R, Wang S. (2006). The impact of rheumatoid arthritis on medical expenditures, absenteeism, and short-term disability benefits. J Occup Environ Med.
10 Pugner KM, Scott DI, Holmes JW, Hieke K. (2000). The costs of rheumatoid arthritis: an international long-term view. Semin Arthritis Rheum.
11 Orozco G, Rueda B, Martin J. Genetic basis of rheumatoid arthritis. Biomed Pharmacother.
12 Turesson C, Schaid DJ, Weyand CM, Jacobsson LT, Goronzy JJ, Petersson IF, et al. (2005). The impact of HLA-DRB1 genes on extra-articular disease manifestations in rheumatoid arthritis. Arthritis Res Ther.
13 Muller-Ladner U, Pap T, Gay RE, Neidhart M, Gay S. (2005). Mechanisms of disease: the molecular and cellular basis of joint destruction in rheumatoid arthritis. Nat Clin Pract Rheumatol.
14 Choy EH, Panayi GS. (2001). Cytokine pathways and joint inflammation in rheumatoid arthritis. N Engl J Med.
15 Greiner A, Plischke H, Kellner H, Gruber R. (2005). Association of anti-cyclic citrullinated peptide antibodies, anti-citrullin antibodies, and IgM and IgA rheumatoid factors with serological parameters of disease activity in rheumatoid arthritis. Ann N Y Acad Sci.
16 Arnett FC, Edworthy SM, Bloch DA, McShane DJ, Fries JF, Cooper NS, et al. (1988). The American Rheumatism Association 1987 revised criteria for the classification of rheumatoid arthritis. Arthritis Rheum.
17 Anandarajah AP, Ritchlin CT. (2004). Pathogenesis of psoriatic arthritis. Curr Opin Rheumatol.
18 Helliwell PS, Taylor WJ. (2005). Classification and diagnostic criteria for psoriatic arthritis. Ann Rheum Dis.
19 Taylor W, Gladman D, Helliwell P, Marchesoni A, Mease P, Mielants H. (2006). Classification criteria for psoriatic arthritis: development of new criteria from a large international study. Arthritis Rheum.
20 Chen Y, Jobanputra P, Barton P, Jowett S, Bryan S, Clark W, et al. (2006). A systematic review of the effectiveness of adalimumab, etanercept and infliximab for the treatment of rheumatoid arthritis in adults and an economic evaluation of their cost-effectiveness. Heath Technology Assessment.
21 Wailoo A, Brennan A, Bansback N, Nixon R, Wolfe F, Michaud K. (2006). Modeling the cost effectiveness of etanercept, adalimumab and anakinra compared to infliximab in the treatment of patients with rheumatoid arthritis in the Medicare program.
22 Balk EM, Lau J, Bonis PA. (2005). Reading and critically appraising systematic reviews and meta-analyses: a short primer with a focus on hepatology. J Hepatol.
23 Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, et al. (2001). Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med.
24 Anonymous. (2001). Undertaking systematic reviews of research on effectiveness: CRD’s guidance for those carrying out or commissioning reviews. CRD Report Number 4.
25 Deeks JJ, Dinnes J, D’Amico R, Sowden AJ, Sakarovitch C, Song F, et al. (2003). Evaluating non-randomised intervention studies. Health Technol Assess.
26 Gartlehner G, Hansen RA, Nissman D, Lohr KN, Carey TS. (2006). A simple and valid tool distinguished efficacy from effectiveness studies. J Clinic Epidemiol.
27 Atkins D, Eccles M, Flottorp S, Guyatt GH, Henry D, Hill S, et al. (2004). Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res.
28 Guyatt G, Gutterman D, Baumann MH, Addrizzo-Harris D, Hylek EM, Phillips B, et al. (2006). Grading strength of recommendations and quality of evidence in clinical guidelines: report from an American College of Chest Physicians task force. Chest.
29 Kirwan J, Hallgren R, Mielants H, Wollheim F, Bjorck E, Persson T, et al. (2004). A randomised placebo controlled 12 week trial of budesonide and prednisolone in rheumatoid arthritis. Ann Rheum Dis.
30 Capell H, Madhok R, Porter D, Munro R, McInnes I, Hunter J, et al. (2007). Combination therapy with sulphasalazine and methotrexate is more effective than either drug alone in rheumatoid arthritis (RA) patients with a suboptimal response to sulphasalazine: Results from the double blind placebo controlled mascot study. Ann Rheum Dis.
31 Dougados M, Combe B, Cantagrel A, Goupille P, Olive P, Schattenkirchner M, et al. (1999). Combination therapy in early rheumatoid arthritis: a randomised, controlled, double blind 52 week clinical trial of sulphasalazine and methotrexate compared with the single components. Ann Rheum Dis.
32 Emery P, Breedveld FC, Lemmel EM, Kaltwasser JP, Dawes PT, Gomor B, et al. (2000). A comparison of the efficacy and safety of leflunomide and methotrexate for the treatment of rheumatoid arthritis. Rheumatology (Oxford).
33 Haagsma C, van Riel P, de Jong A, van de Putte L. (1997). Combination of sulphasalazine and methotrexate versus the single components in early rheumatoid arthritis: a randomized, controlled, double-blind, 52 week clinical trial. Br J Rheum.
34 Osiri M, Shea B, Robinson V, Suarez Almazor M, Strand V, Tugwell P, et al. (2003). Leflunomide for treating rheumatoid arthritis. Cochrane Database Syst Rev.
35 Smolen J, Kalden J, Scott D, Rozman B, Kvien T, Larsen A, et al. (1999). Efficacy and safety of leflunomide compared with placebo and sulphasalazine in active rheumatoid arthritis: a double-blind, randomised, multicentre trial. Lancet.
36 Larsen A, Kvien TK, Schattenkirchner M, Rau R, Scott DL, Smolen JS, et al. (2001). Slowing of disease progression in rheumatoid arthritis patients during long-term treatment with leflunomide or sulfasalazine. Scand J Rheum.
37 Strand V, Cohen S, Schiff M, Weaver A, Fleischmann R, Cannon G, et al. (1999). Treatment of active rheumatoid arthritis with leflunomide compared with placebo and methotrexate. Arch Intern Med.
38 Cohen S, Cannon G, Schiff M, Weaver A, Fox R, Olsen N, et al. (2001). Two-year, blinded, randomized, controlled trial of treatment of active rheumatoid arthritis with leflunomide compared with methotrexate. Utilization of leflunomide in the treatment of rheumatoid arthritis. Arthritis Rheum.
39 Boers M, Verhoeven AC, Markusse HM, van de Laar MA, Westhovens R, van Denderen JC, et al. (1997). Randomised comparison of combined step-down prednisolone, methotrexate and sulphasalazine with sulphasalazine alone in early rheumatoid arthritis. Lancet.
40 Landewe RB, Boers M, Verhoeven AC, Westhovens R, van de Laar MA, Markusse HM, et al. (2002). COBRA combination therapy in patients with early rheumatoid arthritis: long-term structural benefits of a brief intervention. Arthritis Rheum.
41 Maillefert JF, Combe B, Goupille P, Cantagrel A, Dougados M. (2003). Long term structural effects of combination therapy in patients with early rheumatoid arthritis: five year follow up of a prospective double blind controlled study. Ann Rheum Dis.
42 Goekoop-Ruiterman YP, de Vries-Bouwstra JK, Allaart CF, van Zeben D, Kerstens PJ, Hazes JM, et al. (2005). Clinical and radiographic outcomes of four different treatment strategies in patients with early rheumatoid arthritis (the BeSt study): a randomized, controlled trial. Arthritis Rheum.
43 Mottonen T, Hannonen P, Leirisalo-Repo M, Nissila M, Kautiainen H, Korpela M, et al. (1999). Comparison of combination therapy with single-drug therapy in early aheumatoid arthritis: a randomised trial. Lancet.
44 Korpela M, Laasonen L, Hannonen P, Kautiainen H, Leirisalo-Repo M, Hakala M, et al. (2004). Retardation of joint damage in patients with early rheumatoid arthritis by initial aggressive treatment with disease-modifying antirheumatic drugs: five-year experience from the Fin-Raco Study. Arthritis Rheum.
45 O’Dell J, Leff R, Paulsen G, Haire C, Mallek J, Eckhoff P, et al. (2002). Treatment of rheumatoid arthritis with methotrexate and hydroxychloroquine, methotrexate and sulfasalazine, or a combination of the three medications: results of a two-year, randomized, double-blind, placebo-controlled trial. Arthritis Rheum.
46 O’Dell JR, Haire CE, Erikson N, Drymalski W, Palmer W, Eckhoff PJ, et al. (1996). Treatment of rheumatoid arthritis with methotrexate alone, sulfasalazine and hydroxychloroquine, or a combination of all three medications. N Engl J Med.
47 Svensson B, Boonen A, Albertsson K, van der Heijde D, Keller C, Hafstrom I. (2005). Low-dose prednisolone in addition to the initial disease-modifying antirheumatic drug in patients with early active rheumatoid arthritis reduces joint destruction and increases the remission rate: a two-year randomized trial. Arthritis Rheum.
48 Clark W, Jobanputra P, Barton P, Burls A. (2004). The clinical and cost-effectiveness of anakinra for the treatment of rheumatoid arthritis in adults: a systematic review and economic analysis. Health Technol Assess.
49 Gartlehner G, Hansen RA, Jonas BL, Thieda P, Lohr KN. (2006). The comparative efficacy and safety of biologics for the treatment of rheumatoid arthritis: a systematic review and metaanalysis. J Rheumatol.
50 Geborek P, Crnkic M, Petersson IF, Saxne T. (2002). Etanercept, infliximab, and leflunomide in established rheumatoid arthritis: clinical experience using a structured follow up programme in southern Sweden. Ann Rheum Dis.
51 Hochberg MC, Tracy JK, Hawkins-Holt M, Flores RH. (2003). Comparison of the efficacy of the tumour necrosis factor alpha blocking agents adalimumab, etanercept, and infliximab when added to methotrexate in patients with active rheumatoid arthritis. Ann Rheum Dis.
52 Kristensen LE, Saxne T, Geborek P. (2006). The LUNDEX, a new index of drug efficacy in clinical practice: results of a five-year observational study of treatment with infliximab and etanercept among rheumatoid arthritis patients in southern Sweden. Arthritis Rheum.
53 Weaver AL, Lautzenheiser RL, Schiff MH, Gibofsky A, Perruquet JL, Luetkemeyer J, et al. (2006). Real-world effectiveness of select biologic and DMARD monotherapy and combination therapy in the treatment of rheumatoid arthritis: results from the RADIUS observational registry. Curr Med Res Opin.
54 Bathon JM, Martin RW, Fleischmann RM, Tesser JR, Schiff MH, Keystone EC, et al. (2000). A comparison of etanercept and methotrexate in patients with early rheumatoid arthritis. N Engl J Med.
55 Genovese MC, Bathon JM, Martin RW, Fleischmann RM, Tesser JR, Schiff MH, et al. (2002). Etanercept versus methotrexate in patients with early rheumatoid arthritis: two-year radiographic and clinical outcomes. Arthritis Rheum.
56 Genovese MC, Bathon JM, Fleischmann RM, Moreland LW, Martin RW, Whitmore JB, et al. (2005). Longterm safety, efficacy, and radiographic outcome with etanercept treatment in patients with early rheumatoid arthritis. J Rheumatol.
57 Breedveld FC, Weisman MH, Kavanaugh AF, Cohen SB, Pavelka K, van Vollenhoven R, et al. (2006). The PREMIER study: A multicenter, randomized, double-blind clinical trial of combination therapy with adalimumab plus methotrexate versus methotrexate alone or adalimumab alone in patients with early, aggressive rheumatoid arthritis who had not had previous methotrexate treatment. Arthritis Rheum.
58 Listing J, Strangfeld A, Rau R, Kekow J, Gromnica-Ihle E, Klopsch T, et al. (2006). Clinical and functional remission: even though biologics are superior to conventional DMARDs overall success rates remain low--results from RABBIT, the German biologics register. Arthritis Res Ther.
59 Genovese MC, Cohen S, Moreland L, Lium D, Robbins S, Newmark R, et al. (2004). Combination therapy with etanercept and anakinra in the treatment of patients with rheumatoid arthritis who have been treated unsuccessfully with methotrexate. Arthritis Rheum.
60 Combe BG, Codreanu C, Fiocco U, Gaubitz M, Geusens PP, Kvien TK, et al. (2006). Double-blind comparison of etanercept and sulphasalazine, alone and combined, in patients with active rheumatoid arthritis despite receiving sulphasalazine. Ann Rheum Dis.
61 Edwards JC, Szczepanski L, Szechinski J, Filipowicz-Sosnowska A, Emery P, Close DR, et al. (2004). Efficacy of B-cell-targeted therapy with rituximab in patients with rheumatoid arthritis. N Engl J Med.
62 Hyrich KL, Symmons DP, Watson KD, Silman AJ. (2006). Comparison of the response to infliximab or etanercept monotherapy with the response to cotherapy with methotrexate or another disease-modifying antirheumatic drug in patients with rheumatoid arthritis: Results from the British Society for Rheumatology Biologics Register. Arthritis Rheum.
63 Klareskog L, van der Heijde D, de Jager JP, Gough A, Kalden J, Malaise M, et al. (2004). Therapeutic effect of the combination of etanercept and methotrexate compared with each treatment alone in patients with rheumatoid arthritis: double-blind randomised controlled trial. Lancet.
64 van der Heijde D, Klareskog L, Singh A, Tornero J, Melo-Gomes J, Codreanu C, et al. (2006). Patient reported outcomes in a trial of combination therapy with etanercept and methotrexate for rheumatoid arthritis: the TEMPO trial. Ann Rheum Dis.
65 van der Heijde D, Klareskog L, Rodriguez-Valverde V, Codreanu C, Bolosiu H, Melo-Gomes J, et al. (2006). Comparison of etanercept and methotrexate, alone and combined, in the treatment of rheumatoid arthritis: two-year clinical and radiographic results from the TEMPO study, a double-blind, randomized trial. Arthritis Rheum.
66 van Riel PL, Taggart AJ, Sany J, Gaubitz M, Nab HW, Pedersen R, et al. (2006). Efficacy and safety of combination etanercept and methotrexate versus etanercept alone in patients with rheumatoid arthritis with an inadequate response to methotrexate: The ADORE study. Ann Rheum Dis.
67 Zink A, Listing J, Kary S, Ramlau P, Stoyanova-Scholz M, Babinsky K, et al. (2005). Treatment continuation in patients receiving biological agents or conventional DMARD therapy. Ann Rheum Dis.
68 St Clair EW, van der Heijde DM, Smolen JS, Maini RN, Bathon JM, Emery P, et al. (2004). Combination of infliximab and methotrexate therapy for early rheumatoid arthritis: a randomized, controlled trial. Arthritis Rheum.
69 Smolen JS, Han C, van der Heijde D, Emery P, Bathon JM, Keystone E, et al. (2006). Infliximab treatment maintains employability in patients with early rheumatoid arthritis. Arthritis Rheum.
70 Finckh A, Simard JF, Duryea J, Liang MH, Huang J, Daneel S, et al. (2006). The effectiveness of anti-tumor necrosis factor therapy in preventing progressive radiographic joint damage in rheumatoid arthritis: a population-based study. Arthritis Rheum.
71 BlueCross BlueShield Technology Evaluation Center (TEC). (2003). Special report: evidence on sequencing of conventional and biological disease-modifying anti-rheumatic drugs.
72 Kremer JM, Westhovens R, Leon M, Di Giorgio E, Alten R, Steinfeld S, et al. (2003). Treatment of rheumatoid arthritis by selective inhibition of T-cell activation with fusion protein CTLA4Ig. N Engl J Med.
73 Kremer JM, Dougados M, Emery P, Durez P, Sibilia J, Shergy W, et al. (2005). Treatment of rheumatoid arthritis with the selective costimulation modulator abatacept: twelve-month results of a phase iib, double-blind, randomized, placebo-controlled trial. Arthritis Rheum.
74 Emery P, Kosinski M, Li T, Martin M, Williams GR, Becker JC, et al. (2006). Treatment of rheumatoid arthritis patients with abatacept and methotrexate significantly improved health-related quality of life. J Rheumatol.
75 Kremer JM, Genant HK, Moreland LW, Russell AS, Emery P, Abud-Mendoza C, et al. (2006). Effects of abatacept in patients with methotrexate-resistant active rheumatoid arthritis: a randomized trial. Ann Intern Med.
76 Genovese MC, Becker JC, Schiff M, Luggen M, Sherrer Y, Kremer J, et al. (2005). Abatacept for rheumatoid arthritis refractory to tumor necrosis factor alpha inhibition. N Engl J Med.
77 Navarro Sarabia F, Ariza Ariza R, Hernandez Cruz B, Villanueva I. (2005). Adalimumab for treating rheumatoid arthritis. Cochrane Database Syst Rev.
78 van de Putte LB, Rau R, Breedveld FC, Kalden JR, Malaise MG, van Riel PL, et al. (2003). Efficacy and safety of the fully human anti-tumour necrosis factor alpha monoclonal antibody adalimumab (D2E7) in DMARD refractory patients with rheumatoid arthritis: a 12 week, phase II study. Ann Rheum Dis.
79 Keystone EC, Kavanaugh AF, Sharp JT, Tannenbaum H, Hua Y, Teoh LS, et al. (2004). Radiographic, clinical, and functional outcomes of treatment with adalimumab (a human anti-tumor necrosis factor monoclonal antibody) in patients with active rheumatoid arthritis receiving concomitant methotrexate therapy: a randomized, placebo-controlled, 52-week trial. Arthritis Rheum.
80 Furst DE, Schiff MH, Fleischmann RM, Strand V, Birbara CA, Compagnone D, et al. (2003). Adalimumab, a fully human anti tumor necrosis factor-alpha monoclonal antibody, and concomitant standard antirheumatic therapy for the treatment of rheumatoid arthritis: results of STAR (Safety Trial of Adalimumab in Rheumatoid Arthritis). J Rheumatol.
81 van de Putte LB, Atkins C, Malaise M, Sany J, Russell AS, van Riel PL, et al. (2004). Efficacy and safety of adalimumab as monotherapy in patients with rheumatoid arthritis for whom previous disease modifying antirheumatic drug treatment has failed. Ann Rheum Dis.
82 Weinblatt ME, Keystone EC, Furst DE, Moreland LW, Weisman MH, Birbara CA, et al. (2003). Adalimumab, a fully human anti-tumor necrosis factor alpha monoclonal antibody, for the treatment of rheumatoid arthritis in patients taking concomitant methotrexate: the ARMADA trial. Arthritis Rheum.
83 Weinblatt ME, Keystone EC, Furst DE, Kavanaugh AF, Chartash EK, Segurado OG. (2006). Long term efficacy and safety of adalimumab plus methotrexate in patients with rheumatoid arthritis: ARMADA 4 year extended study. Ann Rheum Dis.
84 Bresnihan B, Alvaro-Gracia JM, Cobby M, Doherty M, Domljan Z, Emery P, et al. (1998). Treatment of rheumatoid arthritis with recombinant human interleukin-1 receptor antagonist. Arthritis Rheum.
85 Nuki G, Bresnihan B, Bear MB, McCabe D. (2002). Long-term safety and maintenance of clinical improvement following treatment with anakinra (recombinant human interleukin-1 receptor antagonist) in patients with rheumatoid arthritis: extension phase of a randomized, double-blind, placebo-controlled trial. Arthritis Rheum.
86 Jiang Y, Genant HK, Watt I, Cobby M, Bresnihan B, Aitchison R, et al. (2000). A multicenter, double-blind, dose-ranging, randomized, placebo-controlled study of recombinant human interleukin-1 receptor antagonist in patients with rheumatoid arthritis: radiologic progression and correlation of Genant and Larsen scores. Arthritis Rheum.
87 Cohen S, Hurd E, Cush J, Schiff M, Weinblatt ME, Moreland LW, et al. (2002). Treatment of rheumatoid arthritis with anakinra, a recombinant human interleukin-1 receptor antagonist, in combination with methotrexate: results of a twenty-four-week, multicenter, randomized, double-blind, placebo-controlled trial. Arthritis Rheum.
88 Cohen SB, Woolley JM, Chan W. (2003). Interleukin 1 receptor antagonist anakinra improves functional status in patients with rheumatoid arthritis. J Rheumatol.
89 Cohen SB, Moreland LW, Cush JJ, Greenwald MW, Block S, Shergy WJ, et al. (2004). A multicentre, double blind, randomised, placebo controlled trial of anakinra (Kineret), a recombinant interleukin 1 receptor antagonist, in patients with rheumatoid arthritis treated with background methotrexate. Ann Rheum Dis.
90 Jobanputra P, Barton P, Bryan S, Burls A. (2002). The effectiveness of infliximab and etanercept for the treatment of rheumatoid arthritis: a systematic review and economic evaluation. Health Technol Assess.
91 van der Heijde D, Klareskog L, Boers M, Landewe R, Codreanu C, Bolosiu HD, et al. (2005). Comparison of different definitions to classify remission and sustained remission: 1 year TEMPO results. Ann Rheum Dis.
92 Blumenauer B, Judd M, Cranney A, Burls A, Coyle D, Hochberg M, et al. (2003). Etanercept for the treatment of rheumatoid arthritis. Cochrane Database Syst Rev.
93 Moreland LW, Schiff MH, Baumgartner SW, Tindall EA, Fleischmann RM, Bulpitt KJ, et al. (1999). Etanercept therapy in rheumatoid arthritis. A randomized, controlled trial. Ann Intern Med.
94 Mathias SD, Colwell HH, Miller DP, Moreland LW, Buatti M, Wanke L. (2000). Health-related quality of life and functional status of patients with rheumatoid arthritis randomly assigned to receive etanercept or placebo. Clin Ther.
95 Weinblatt ME, Kremer JM, Bankhurst AD, Bulpitt KJ, Fleischmann RM, Fox RI, et al. (1999). A trial of etanercept, a recombinant tumor necrosis factor receptor:Fc fusion protein, in patients with rheumatoid arthritis receiving methotrexate. N Engl J Med.
96 Lan JL, Chou SJ, Chen DY, Chen YH, Hsieh TY, Young M. (2004). A comparative study of etanercept plus methotrexate and methotrexate alone in Taiwanese patients with active rheumatoid arthritis: a 12-week, double-blind, randomized, placebo-controlled study. J Formos Med Assoc.
97 Moreland LW, Baumgartner SW, Schiff MH, Tindall EA, Fleischmann RM, Weaver AL, et al. (1997). Treatment of rheumatoid arthritis with a recombinant human tumor necrosis factor receptor (p75)-Fc fusion protein. N Engl J Med.
98 Blumenauer B, Judd M, Wells G, Burls A, Cranney A, Hochberg M, et al. (2002). Infliximab for the treatment of rheumatoid arthritis. Cochrane Database Syst Rev.
99 Taylor P, Steuer A, Gruber J, McClinton C, Cosgrove D, Blomley M, et al. (2006). Ultrasonographic and radiographic results from a two-year controlled trial of immediate or one-year-delayed addition of infliximab to ongoing methotrexate therapy in patients with erosive early rheumatoid arthritis. Arthritis Rheum.
100 Maini R, St Clair EW, Breedveld F, Furst D, Kalden J, Weisman M, et al. (1999). Infliximab (chimeric anti-tumour necrosis factor alpha monoclonal antibody) versus placebo in rheumatoid arthritis patients receiving concomitant methotrexate: a randomised phase III trial. ATTRACT Study Group. Lancet.
101 Maini RN, Breedveld FC, Kalden JR, Smolen JS, Furst D, Weisman MH, et al. (2004). Sustained improvement over two years in physical function, structural damage, and signs and symptoms among patients with rheumatoid arthritis treated with infliximab and methotrexate. Arthritis Rheum.
102 Smolen JS, Han C, Bala M, Maini RN, Kalden JR, van der Heijde D, et al. (2005). Evidence of radiographic benefit of treatment with infliximab plus methotrexate in rheumatoid arthritis patients who had no clinical improvement: a detailed subanalysis of data from the anti-tumor necrosis factor trial in rheumatoid arthritis with concomitant therapy study. Arthritis Rheum.
103 Lipsky PE, van der Heijde DM, St Clair EW, Furst DE, Breedveld FC, Kalden JR, et al. (2000). Infliximab and methotrexate in the treatment of rheumatoid arthritis. Anti-tumor necrosis factor trial in rheumatoid arthritis with concomitant therapy study group. N Engl J Med.
104 Breedveld FC, Emery P, Keystone E, Patel K, Furst DE, Kalden JR, et al. (2004). Infliximab in active early rheumatoid arthritis. Ann Rheum Dis.
105 Abe T, Takeuchi T, Miyasaka N, Hashimoto H, Kondo H, Ichikawa Y, et al. (2006). A multicenter, double-blind, randomized, placebo controlled trial of infliximab combined with low dose methotrexate in Japanese patients with rheumatoid arthritis. J Rheumatol.
106 Kavanaugh A, St Clair EW, McCune WJ, Braakman T, Lipsky P. (2000). Chimeric anti-tumor necrosis factor-alpha monoclonal antibody treatment of patients with rheumatoid arthritis receiving methotrexate therapy. J Rheumatol.
107 Westhovens R, Yocum D, Han J, Berman A, Strusberg I, Geusens P, et al. (2006). The safety of infliximab, combined with background treatments, among patients with rheumatoid arthritis and various comorbidities: a large, randomized, placebo-controlled trial. Arthritis Rheum.
108 Emery P, Fleischmann R, Filipowicz-Sosnowska A, Schechtman J, Szczepanski L, Kavanaugh A, et al. (2006). The efficacy and safety of rituximab in patients with active rheumatoid arthritis despite methotrexate treatment: results of a phase IIB randomized, double-blind, placebo-controlled, dose-ranging trial. Arthritis Rheum.
109 Glenny AM, Altman DG, Song F, Sakarovitch C, Deeks JJ, D’Amico R, et al. (2005). Indirect comparisons of competing interventions. Health Technol Assess.
110 Durez P, Nzeusseu Toukap A, Lauwerys BR, Manicourt DH, Verschueren P, Westhovens R, et al. (2004). A randomised comparative study of the short term clinical and biological effects of intravenous pulse methylprednisolone and infliximab in patients with active rheumatoid arthritis despite methotrexate treatment. Ann Rheum Dis.
111 Jones G, Crotty M, Brooks P. (2000). Interventions for treating psoriatic arthritis. Cochrane Database Syst Rev.
112 Kaltwasser J, Nash P, Gladman D, Rosen C, Behrens F, Jones P, et al. (2004). Efficacy and safety of leflunomide in the treatment of psoriatic arthritis and psoriasis: a multinational, double-blind, randomized, placebo-controlled clinical trial. Arthritis Rheum.
113 Nash P, Thaci D, Behrens F, Falk F, Kaltwasser JP. (2006). Leflunomide improves psoriasis in patients with psoriatic arthritis: an in-depth analysis of data from the TOPAS study. Dermatology.
114 Mease PJ, Gladman DD, Ritchlin CT, Ruderman EM, Steinfeld SD, Choy EH, et al. (2005). Adalimumab for the treatment of patients with moderately to severely active psoriatic arthritis: results of a double-blind, randomized, placebo-controlled trial. Arthritis Rheum.
115 Antoni CE, Kavanaugh A, Kirkham B, Tutuncu Z, Burmester GR, Schneider U, et al. (2005). Sustained benefits of infliximab therapy for dermatologic and articular manifestations of psoriatic arthritis: results from the infliximab multinational psoriatic arthritis controlled trial (IMPACT). Arthritis Rheum.
116 Kavanaugh A, Antoni CE, Gladman D, Wassenberg S, Zhou B, Beutler A, et al. (2006). The Infliximab Multinational Psoriatic Arthritis Controlled Trial (IMPACT): results of radiographic analyses after 1 year. Ann Rheum Dis.
117 Antoni C, Krueger GG, de Vlam K, Birbara C, Beutler A, Guzzo C, et al. (2005). Infliximab improves signs and symptoms of psoriatic arthritis: results of the IMPACT 2 trial. Ann Rheum Dis.
118 Kavanaugh A, Antoni C, Krueger GG, Yan S, Bala M, Dooley LT, et al. (2006). Infliximab improves health related quality of life and physical function in patients with psoriatic arthritis. Ann Rheum Dis.
119 Mease PJ, Goffe BS, Metz J, VanderStoep A, Finck B, Burge DJ. (2000). Etanercept in the treatment of psoriatic arthritis and psoriasis: a randomised trial. Lancet.
120 Mease PJ, Kivitz AJ, Burch FX, Siegel EL, Cohen SB, Ory P, et al. (2004). Etanercept treatment of psoriatic arthritis: safety, efficacy, and effect on disease progression. Arthritis Rheum.
121 Woolacott N, Bravo Vergel Y, Hawkins N, Kainth A, Khadjesari Z, Misso K, et al. (2006). Etanercept and infliximab for the treatment of psoriatic arthritis: a systematic review and economic evaluation. Health Technol Assess.
122 Mease PJ, Kivitz AJ, Burch FX, Siegel EL, Cohen SB, Ory P, et al. (2006). Continued inhibition of radiographic progression in patients with psoriatic arthritis following 2 years of treatment with etanercept. J Rheumatol.
123 Scott D, Smolen J, Kalden J, van de Putte L, Larsen A, Kvien T, et al. (2001). Treatment of active rheumatoid arthritis with leflunomide: two year follow up of a double blind, placebo controlled trial versus sulfasalazine. Ann Rheum Dis.
124 Puolakka K, Kautiainen H, Mottonen T, Hannonen P, Korpela M, Julkunen H, et al. (2004). Impact of initial aggressive drug treatment with a combination of disease-modifying antirheumatic drugs on the development of work disability in early rheumatoid arthritis: a five-year randomized followup trial. Arthritis Rheum.
125 Kosinski M, Kujawski SC, Martin R, Wanke LA, Buatti MC, Ware JE, et al. (2002). Health-related quality of life in early rheumatoid arthritis: impact of disease and treatment response. Am J Manag Care.
126 Kremer J, Genovese M, Cannon G, Caldwell J, Cush J, Furst D, et al. (2002). Concomitant leflunomide therapy in patients with active rheumatoid arthritis despite stable doses of methotrexate. A randomized, double-blind, placebo-controlled trial. Ann Intern Med.
127 Strand V, Tugwell P, Bombardier C, Maetzel A, Crawford B, Dorrier C, et al. (1999). Function and health-related quality of life: results from a randomized controlled trial of leflunomide versus methotrexate or placebo in patients with active rheumatoid arthritis. Leflunomide Rheumatoid Arthritis Investigators Group. Arthritis Rheum.
128 Emery P, Breedveld FC, Jubb RW, Sorensen H, Oed C, Loew-Friedrich I. (1999). Efficacy and safety of leflunomide vs. methotrexate in rheumatoid arthritis (RA): results of a double-blind, randomized, 2-year trial. Arthritis Rheum.
129 Westhovens R, Cole JC, Li T, Martin M, Maclean R, Lin P, et al. (2006). Improved health-related quality of life for rheumatoid arthritis patients treated with abatacept who have inadequate response to anti-TNF therapy in a double-blind, placebo-controlled, multicentre randomized clinical trial. Rheumatology (Oxford).
130 Kavanaugh A, Antoni C, Mease P, Gladman D, Yan S, Bala M, et al. (2006). Effect of infliximab therapy on employment, time lost from work, and productivity in patients with psoriatic arthritis. J Rheumatol.
131 Anonymous. (2003). Dexamethasone package insert.
132 Anonymous. (2003). PredniSONE package insert.
133 Anonymous. (2006). MethylPREDNIsolone package insert.
134 Anonymous. (2002). Cortisone Acetate package insert.
135 Anonymous. (2002). Cortef (hydrocortisone) package insert.
136 Anonymous. (2005). Arava (leflunomide) package insert.
137 Anonymous. (2004). Hydroxychloroquine package insert.
138 Anonymous. (2005). Methotrexate package insert.
139 Anonymous. (2006). Azulfidine (sulfasalazine) package insert.
140 American College of Rheumatology (ACR). (2002). Guidelines for the management of rheumatoid arthritis: 2002 Update. Arthritis Rheum.
141 American College of Rheumatology (ACR). (2006). ACR Hotline: Update on safety issues concerning TNF inhibitors.
142 Anonymous. (2005). Orencia (abatacept) package insert.
143 Anonymous. (2006). Humira (adalimumab) package insert.
144 Anonymous. (2004). Kineret (anakinra) package insert.
145 Anonymous. (2006). Enbrel (etanercept) package insert.
146 Anonymous. (2006). Remicade (infliximab) package insert.
147 Anonymous. (2007). Rituxan (rituximab) package insert.
148 International Conference on Harmonisation (ICH). (1994). International conference on harmonisation of technical requirements for registration of pharmaceuticals for human use ICH harmonised tripartite guideline clinical safety data management: definitions and standards for expedited reporting E2A.
149 Doran MF, Crowson CS, Pond GR, O’Fallon WM, Gabriel SE. (2002). Predictors of infection in rheumatoid arthritis. Arthritis Rheum.
150 Maetzel A, Wong A, Strand V, Tugwell P, Wells G, Bombardier C. (2000). Meta-analysis of treatment termination rates among rheumatoid arthritis patients receiving disease-modifying anti-rheumatic drugs. Rheumatology (Oxford).
151 O’Dell JR, Petersen K, Leff R, Palmer W, Schned E, Blakely K, et al. (2006). Etanercept in combination with sulfasalazine, hydroxychloroquine, or gold in the treatment of rheumatoid arthritis. J Rheumatol.
152 Cannon GW, Holden WL, Juhaeri J, Dai W, Scarazzini L, Stang P. (2004). Adverse events with disease modifying antirheumatic drugs (DMARD): a cohort study of leflunomide compared with other DMARD. J Rheumatol.
153 Suissa S, Ernst P, Hudson M, Bitton A, Kezouh A. (2004). Newer disease-modifying antirheumatic drugs and the risk of serious hepatic adverse events in patients with rheumatoid arthritis. Am J Med.
154 Suissa S, Hudson M, Ernst P. (2006). Leflunomide use and the risk of interstitial lung disease in rheumatoid arthritis. Arthritis Rheum.
155 Wolfe F, Caplan L, Michaud K. (2006). Treatment for rheumatoid arthritis and the risk of hospitalization for pneumonia: associations with prednisone, disease-modifying antirheumatic drugs, and anti-tumor necrosis factor therapy. Arthritis Rheum.
156 Baecklund E, Iliadou A, Askling J, Ekbom A, Backlin C, Granath F, et al. (2006). Association of chronic inflammation, not its treatment, with increased lymphoma risk in rheumatoid arthritis. Arthritis Rheum.
157 Chakravarty EF, Michaud K, Wolfe F. (2005). Skin cancer, rheumatoid arthritis, and tumor necrosis factor inhibitors. J Rheumatol.
158 Schaible TF. (2000). Long term safety of infliximab. Can J Gastroenterol.
159 Geborek P, Bladstrom A, Turesson C, Gulfe A, Petersson IF, Saxne T, et al. (2005). Tumour necrosis factor blockers do not increase overall tumour risk in patients with rheumatoid arthritis, but may be associated with an increased risk of lymphomas. Ann Rheum Dis.
160 Weinblatt M, Combe B, Covucci A, Aranda R, Becker JC, Keystone E. (2006). Safety of the selective costimulation modulator abatacept in rheumatoid arthritis patients receiving background biologic and nonbiologic disease-modifying antirheumatic drugs: A one-year randomized, placebo-controlled study. Arthritis Rheum.
161 Feltelius N, Fored CM, Blomqvist P, Bertilsson L, Geborek P, Jacobsson LT, et al. (2005). Results from a nationwide postmarketing cohort study of patients in Sweden treated with etanercept. Ann Rheum Dis.
162 Moreland LW, Weinblatt ME, Keystone EC, Kremer JM, Martin RW, Schiff MH, et al. (2006). Etanercept treatment in adults with established rheumatoid arthritis: 7 years of clinical experience. J Rheumatol.
163 Dixon WG, Watson K, Lunt M, Hyrich KL, Silman AJ, Symmons DP. (2006). Rates of serious infection, including site-specific and bacterial intracellular infection, in rheumatoid arthritis patients receiving anti-tumor necrosis factor therapy: Results from the British Society for Rheumatology Biologics Register. Arthritis Rheum.
164 Bongartz T, Sutton AJ, Sweeting MJ, Buchan I, Matteson EL, Montori V. (2006). Anti-TNF antibody therapy in rheumatoid arthritis and the risk of serious infections and malignancies: systematic review and meta-analysis of rare harmful effects in randomized controlled trials. J Am Med Assoc.
165 Wallis RS, Broder MS, Wong JY, Hanson ME, Beenhouwer DO. (2004). Granulomatous infectious diseases associated with tumor necrosis factor antagonists. Clin Infect Dis.
166 Lee JH, Slifman NR, Gershon SK, Edwards ET, Schwieterman WD, Siegel JN, et al. (2002). Life-threatening histoplasmosis complicating immunotherapy with tumor necrosis factor alpha antagonists infliximab and etanercept. Arthritis Rheum.
167 Slifman NR, Gershon SK, Lee JH, Edwards ET, Braun MM. (2003). Listeria monocytogenes infection as a complication of treatment with tumor necrosis factor alpha-neutralizing agents. Arthritis Rheum.
168 Harley CR, Frytak JR, Tandon N. (2003). Treatment compliance and dosage administration among rheumatoid arthritis patients receiving infliximab, etanercept, or methotrexate. Am J Manag Care.
169 Saag KG, Koehnke R, Caldwell JR, Brasington R, Burmeister LF, Zimmerman B, et al. (1994). Low dose long-term corticosteroid therapy in rheumatoid arthritis: an analysis of serious adverse events. Am J Med.
170 Svensson B, Ahlmen M, Forslind K. (2003). Treatment of early RA in clinical practice: a comparative study of two different DMARD/corticosteroid options. Clin Exp Rheumatol.
171 Fleischmann RM, Schechtman J, Bennett R, Handel ML, Burmester GR, Tesser J, et al. (2003). Anakinra, a recombinant human interleukin-1 receptor antagonist (r-metHuIL-1ra), in patients with rheumatoid arthritis: A large, international, multicenter, placebo-controlled trial. Arthritis Rheum.
172 Fleischmann RM, Tesser J, Schiff MH, Schechtman J, Burmester GR, Bennett R, et al. (2006). Safety of extended treatment with anakinra in patients with rheumatoid arthritis. Ann Rheum Dis.
173 Flendrie M, Creemers MC, Welsing PM, den Broeder AA, van Riel PL. (2003). Survival during treatment with tumour necrosis factor blocking agents in rheumatoid arthritis. Ann Rheum Dis.
174 Langer HE, Missler-Karger B. (2003). Kineret: efficacy and safety in daily clinical practice: an interim analysis of the Kineret response assessment initiative (kreative) protocol. Int J Clin Pharmacol Res.
175 Schiff MH, Burmester GR, Kent JD, Pangan AL, Kupper H, Fitzpatrick SB, et al. (2006). Safety analyses of adalimumab (HUMIRA) in global clinical trials and US postmarketing surveillance of patients with rheumatoid arthritis. Ann Rheum Dis.
176 Wasserman MJ, Weber DA, Guthrie JA, Bykerk VP, Lee P, Keystone EC. (2004). Infusion-related reactions to infliximab in patients with rheumatoid arthritis in a clinical practice setting: relationship to dose, antihistamine pretreatment, and infusion number. J Rheumatol.
177 Askling J, Fored CM, Brandt L, Baecklund E, Bertilsson L, Coster L, et al. (2005). Risk and case characteristics of tuberculosis in rheumatoid arthritis associated with tumor necrosis factor antagonists in Sweden. Arthritis Rheum.
178 Bergstrom L, Yocum DE, Ampel NM, Villanueva I, Lisse J, Gluck O, et al. (2004). Increased risk of coccidioidomycosis in patients treated with tumor necrosis factor alpha antagonists. Arthritis Rheum.
179 Gomez-Reino JJ, Carmona L, Valverde VR, Mola EM, Montero MD. (2003). Treatment of rheumatoid arthritis with tumor necrosis factor inhibitors may predispose to significant increase in tuberculosis risk: a multicenter active-surveillance report. Arthritis Rheum.
180 Keane J, Gershon S, Wise RP, Mirabile-Levens E, Kasznica J, Schwieterman WD, et al. (2001). Tuberculosis associated with infliximab, a tumor necrosis factor alpha-neutralizing agent. N Engl J Med.
181 Listing J, Strangfeld A, Kary S, Rau R, von Hinueber U, Stoyanova-Scholz M, et al. (2005). Infections in patients with rheumatoid arthritis treated with biologic agents. Arthritis Rheum.
182 Mohan AK, Cote TR, Block JA, Manadan AM, Siegel JN, Braun MM. (2004). Tuberculosis following the use of etanercept, a tumor necrosis factor inhibitor. Clin Infect Dis.
183 Salliot C, Gossec L, Ruyssen-Witrand A, Luc M, Duclos M, Guignard S, et al. (2006). Infections during tumour necrosis factor-{alpha} blocker therapy for rheumatic diseases in daily practice: a systematic retrospective study of 709 patients. Rheumatology.
184 Wolfe F, Michaud K, Anderson J, Urbansky K. (2004). Tuberculosis infection in patients with rheumatoid arthritis and the effect of infliximab therapy. Arthritis Rheum.
185 Askling J, Fored CM, Brandt L, Baecklund E, Bertilsson L, Feltelius N, et al. (2005). Risks of solid cancers in patients with rheumatoid arthritis and after treatment with tumour necrosis factor antagonists. Ann Rheum Dis.
186 Askling J, Fored CM, Baecklund E, Brandt L, Backlin C, Ekbom A, et al. (2005). Haematopoietic malignancies in rheumatoid arthritis: lymphoma risk and characteristics after exposure to tumour necrosis factor antagonists. Ann Rheum Dis.
187 Brown SL, Greene MH, Gershon SK, Edwards ET, Braun MM. (2002). Tumor necrosis factor antagonist therapy and lymphoma development: twenty-six cases reported to the Food and Drug Administration. Arthritis Rheum.
188 Lebwohl M, Blum R, Berkowitz E, Kim D, Zitnik R, Osteen C, et al. (2005). No evidence for increased risk of cutaneous squamous cell carcinoma in patients with rheumatoid arthritis receiving etanercept for up to 5 years. Arch Dermatol.
189 Setoguchi S, Solomon DH, Weinblatt ME, Katz JN, Avorn J, Glynn RJ, et al. (2006). Tumor necrosis factor alpha antagonist use and cancer in patients with rheumatoid arthritis. Arthritis Rheum.
190 Wolfe F, Michaud K. (2004). Lymphoma in rheumatoid arthritis: the effect of methotrexate and anti-tumor necrosis factor therapy in 18,572 patients. Arthritis Rheum.
191 Chung ES, Packer M, Lo KH, Fasanmade AA, Willerson JT. (2003). Randomized, double-blind, placebo-controlled, pilot trial of infliximab, a chimeric monoclonal antibody to tumor necrosis factor-alpha, in patients with moderate-to-severe heart failure: results of the anti-TNF Therapy Against Congestive Heart Failure (ATTACH) trial. Circulation.
192 Jacobsson LT, Turesson C, Gulfe A, Kapetanovic MC, Petersson IF, Saxne T, et al. (2005). Treatment with tumor necrosis factor blockers is associated with a lower incidence of first cardiovascular events in patients with rheumatoid arthritis. J Rheumatol.
193 Kwon HJ, Cote TR, Cuffe MS, Kramer JM, Braun MM. (2003). Case reports of heart failure after therapy with a tumor necrosis factor antagonist. Ann Intern Med.
194 Wolfe F, Michaud K. (2004). Heart failure in rheumatoid arthritis: rates, predictors, and the effect of anti-tumor necrosis factor therapy. Am J Med.
195 Mohan N, Edwards ET, Cupps TR, Oliverio PJ, Sandberg G, Crayton H, et al. (2001). Demyelination occurring during anti-tumor necrosis factor alpha therapy for inflammatory arthritides. Arthritis Rheum.
196 De Bandt M, Sibilia J, Le Loet X, Prouzeau S, Fautrel B, Marcelli C, et al. (2005). Systemic lupus erythematosus induced by anti-tumour necrosis factor alpha therapy: a French national survey. Arthritis Res Ther.
197 Flendrie M, Vissers WH, Creemers MC, de Jong EM, van de Kerkhof PC, van Riel PL. (2005). Dermatological conditions during TNF-alpha-blocking therapy in patients with rheumatoid arthritis: a prospective study. Arthritis Res Ther.
198 Shin IS, Baer AN, Kwon HJ, Papadopoulos EJ, Siegel JN. (2006). Guillain-Barre and Miller Fisher syndromes occurring with tumor necrosis factor alpha antagonist therapy. Arthritis Rheum.
199 Food and Drug Administration. (2006). FDA alert on rituximab.
200 Ruderman EM, Markenson J. (2003). Granulomatous infections and tumor necrosis factor antagonists therapy: update through June 2002. Arthritis Rheum.
201 Wood AJ. (2000). Thrombotic thrombocytopenic purpura and clopidogrel--a need for new approaches to drug safety. N Engl J Med.
202 Baecklund E, Ekbom A, Sparen P, Feltelius N, Klareskog L. (1998). Disease activity and risk of lymphoma in patients with rheumatoid arthritis: nested case-control study. Br Med J.
203 Coletta AP, Clark AL, Banarjee P, Cleland JG. (2002). Clinical trials update: RENEWAL (RENAISSANCE and RECOVER) and ATTACH. Eur J Heart Fail.
204 Shakoor N, Michalska M, Harris CA, Block JA. (2002). Drug-induced systemic lupus erythematosus associated with etanercept therapy. Lancet.
205 Miller LG, Hays RD. (2000). Adherence to combination antiretroviral therapy: synthesis of the literature and clinical implications. AIDS Read.
206 Rheumatoid Arthritis Clinical Trial Archive Group. (1995). The effect of age and renal function on the efficacy and toxicity of methotrexate in rheumatoid arthritis. J Rheumatol.
207 Bathon JM, Fleischmann RM, Van der Heijde D, Tesser JR, Peloso PM, Chon Y, et al. (2006). Safety and efficacy of etanercept treatment in elderly subjects with rheumatoid arthritis. J Rheumatol.
208 Fleischmann RM, Baumgartner SW, Tindall EA, Weaver AL, Moreland LW, Schiff MH, et al. (2003). Response to etanercept (Enbrel) in elderly patients with rheumatoid arthritis: a retrospective analysis of clinical trial results. J Rheumatol.
209 Schiff MH, Yu EB, Weinblatt ME, Moreland LW, Genovese MC, White B, et al. (2006). Long-term experience with etanercept in the treatment of rheumatoid arthritis in elderly and younger patients: patient-reported outcomes from multiple controlled and open-label extension studies. Drugs & aging.
210 Tesser J, Fleischmann R, Dore R, Bennett R, Solinger A, Joh T, et al. (2004). Concomitant medication use in a large, international, multicenter, placebo controlled trial of anakinra, a recombinant interleukin 1 receptor antagonist, in patients with rheumatoid arthritis. J Rheumatol.
211 Schiff MH, DiVittorio G, Tesser J, Fleischmann R, Schechtman J, Hartman S, et al. (2004). The safety of anakinra in high-risk patients with active rheumatoid arthritis: six-month observations of patients with comorbid conditions. Arthritis Rheum.
212 Katz JA, Antoni C, Keenan GF, Smith DE, Jacobs SJ, Lichtenstein GR. (2004). Outcome of pregnancy in women receiving infliximab for the treatment of Crohn’s disease and rheumatoid arthritis. Am J Gastroenterol.
213 Chakravarty EF, Sanchez-Yamamoto D, Bush TM. (2003). The use of disease modifying antirheumatic drugs in women with rheumatoid arthritis of childbearing age: a survey of practice patterns and pregnancy outcomes. J Rheumatol.
214 Goekoop-Ruiterman YP, de Vries-Bouwstra JK, Allaart CF, van Zeben D, Kerstens PJ, Hazes JM, et al. (2007). Comparison of treatment strategies in early rheumatoid arthritis: a randomized trial. Ann Intern Med.
215 Ledingham J, Deighton C. (2005). Update on the British Society for Rheumatology guidelines for prescribing TNFalpha blockers in adults with rheumatoid arthritis (update of previous guidelines of April 2001). Rheumatology (Oxford).
216 Sokka T, Pincus T. (2003). Eligibility of patients in routine care for major clinical trials of anti-tumor necrosis factor alpha agents in rheumatoid arthritis. Arthritis Rheum.