# Acknowledgments

We acknowledge the continuing support of Beth Collins-Sharp, Ph.D., R.N., Director of the AHRQ Evidence-based Practice Center (EPC) Program, and Carmen Kelly, Pharm.D., R.Ph., the AHRQ Task Order Officer for this project.

The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at RTI International and the University of North Carolina (UNC). We would particularly acknowledge Timothy Carey, M.D., M.P.H., for insightful comments on the first draft and helpful suggestions throughout the project, and Lynn Whitener, Dr.P.H., M.S.L.S., our EPC Librarian. We also express our gratitude to RTI staff Loraine Monroe, our EPC Document Specialist, Tammeka Swinson, Research Analyst, and Jennifer Drolet, M.A., editor.

- Beth A. Collins-Sharp, R.N.
- Director
- Evidence-based Practice Center Program
- Agency for Healthcare Research and Quality
- Rockville, MD

- Carmen Kelly, Pharm.D., R.Ph.
- Task Order Officer
- Evidence-based Practice Center Program
- Agency for Healthcare Research and Quality
- Rockville, MD