# 3 Results

We identified 2,153 citations from our searches (Appendix B). Figure 1 documents the results of the literature search. Working from 619 articles retrieved for full review, we included 161 for background and excluded 302 at this stage (Appendix D). We included 156 published articles reporting on 103 studies: 22 head-to-head randomized controlled trials (RCTs), 1 head-to-head nonrandomized controlled trial, 13 placebo-controlled trials, 10 meta-analyses or systematic reviews, and 55 observational studies. Our findings include studies rated good or fair, unless a particular study rated poor provides some unique information that we judged to be of interest. We included 2 poor-quality pooled data analyses on subgroups. Most studies were of fair quality; we designate in the text only those of good or poor quality. Evidence tables for included studies, by key question (KQ), can be found in Appendix E.

Figure 1

Results of literature search*

*Number of included articles differs from number of included studies because some studies have multiple publications.

We excluded articles based on eligibility criteria or methodological criteria (quality rating) as explained in Chapter 2. We excluded six studies that originally met eligibility (inclusion) criteria but were subsequently rated as poor quality after full review (Appendix H). The main reasons for poor ratings were high loss to followup and selection bias.

Of the 103 included studies, 51 (50 percent) were supported by pharmaceutical companies; 21 (20 percent) were funded by governmental or independent funds; and 11 (11 percent) were supported by a combination of pharmaceutical and government funding. We could not determine the source of support for 20 (19 percent) studies.

This chapter is organized by key question and, within each question, by disease (first rheumatoid arthritis [RA] and then psoriatic arthritis [PsA]). We then present findings in order by class of drugs, types of drugs, and combinations of drugs as appropriate to the condition and the particular key question. Generally, the chapter is organized using the following main analytic categories: corticosteroids vs. corticosteroids, synthetic disease-modifying antirheumatic drugs (DMARDs) vs. synthetic DMARDs, synthetic DMARD combinations (with or without corticosteroids) vs. synthetic DMARD combinations, biologics vs. biologics, biologics vs. corticosteroids, biologics vs. synthetic DMARDs, biologics plus synthetic DMARDs vs. biologics, and biologics plus synthetic DMARDs vs. synthetic DMARDs (see Table 3 in the introduction).

Across all key questions and both diseases, we have included head-to-head studies with either active or placebo controls (or both), observational studies, and other systematic reviews. When comparative evidence is available, we discuss it before presenting placebo-controlled trials. This occurs for RA only for KQ 3 and KQ 4 on harms and subgroups. PsA involves only placebo-controlled trials.

Table 8 below gives the numbers of trials or studies for drug class comparisons, only for RA, and reported only from head-to-head trials or studies; when some groupings have important subcomparisons, we note these in Table 8 as well. We do not, however, offer an exhaustive list of all possible comparisons among corticosteroids, synthetic DMARDs, and biologic DMARDs simply because of the sheer number of potential combinations of drugs within classes and across classes, which cannot be clearly and concisely presented here.

Table 8

Number of head-to-head trials or studies by drug comparison for rheumatoid arthritis

Drug Comparison | Number of Trials or Studies; Quality Rating
Corticosteroids vs. corticosteroids | 1; 1 fair
Synthetic DMARDs vs. synthetic DMARDs | 7; 1 good, 6 fair
Synthetic DMARD combinations | 11; 5 good, 6 fair
Biologic DMARDs vs. biologic DMARDs | 8; 2 good, 6 fair
Biologic DMARDs vs. synthetic DMARDs | 4; 4 fair
Biologic DMARD + synthetic DMARD combinations | 10; 2 good, 8 fair

DMARD, disease modifying anti-rheumatic drug.

* No head-to-head drug comparison studies were available for psoriatic arthritis; all were placebo-controlled studies.

Table 9 lists abbreviations and full names of diagnostic scales and health status or quality-of-life instruments encountered in these studies. For further details about such instruments and scales, see Appendix I.

Table 9

Diagnostic scales and quality-of-life instruments

Abbreviated Name | Complete Name of Measure or Instrument | Range of Scores | Improvement Denoted by
ACR-N | American College of Rheumatology percent improvement from baseline to endpoint | 0 to 100 percent | Increase
ACR 20/50/70^*^ | American College of Rheumatology response scores based on 20, 50, or 70 percent criteria for improvement | 0 to 100 percent | Increase
ASHI | Arthritis-Specific Health Index (Medical Outcomes Study Short Form SF-36 Arthritis-specific Health Index) | 0 to 100 | Increase
DAS^*^ | Disease Activity Score | 0 to 10 | Decrease
DAS 28 | Disease Activity Score Short Form | 0 to10 | Decrease
EQ-5D^*^ | EuroQol EQ-5D Quality of Life Questionnaire | 0 to 1 | Increase
HAQ^*^ (D-HAQ) | Health Assessment Questionnaire (Dutch Version) | 0 to 3 | Decrease
HAQ-DI | Disability Index of the Heath Assessment Questionnaire | 0 to 3 | Decrease
Larsen Scale^*^ | Larsen Scale for Grading Radiographs in Rheumatoid Arthritis | 0 to 250 | Decrease
PASI^*^ | Psoriasis Area and Severity Index | 0 to 72 | Decrease
PsARC^*^ | Psoriatic Arthritis Response Criteria | 0 to 100 percent | Increase
SF-36^*^ | Medical Outcomes Study Short Form 36 Health Survey | 0 to 100 | Increase
Sharp Scale | Sharp Scoring System for Radiographic Rheumatoid Arthritis | Erosion: 0 to 170 Narrowing: 0 to 144 | Decrease
SHS^*^ | Sharp/van der Heijde Method (SHS) for Scoring Radiographs (SHS is frequently modified by individual authors to meet study requirements and needs; there is no standard modified SHS) | Erosion: 0 to 160 for hands; 0 to 120 for feet Joint space narrowing: 0 to 168 Total: 0 to 448 | Decrease
SOFI | Signals of Functional Impairment Scale | 0 to 44 | Decrease

* These key scales are defined in Appendix I.

## Key Question 1: Reductions in Symptoms, Limitations of Disease Progression, and Maintenance of Remission

This key question concerned three main topics for both diseases. Specifically, “for patients with rheumatoid arthritis or psoriatic arthritis, do drug therapies differ in their ability to reduce patient-reported symptoms, to slow or limit progression of radiographic joint damage, or to maintain remission?” As noted earlier, we address first the evidence about RA and then the information about PsA. Tables 10 and 11 provide selected study-specific information on outcomes, broken out by primary outcomes in Table 10 and by radiologic outcomes in Table 11, for ease of comparison. Evidence Tables 1 (for head-to-head studies) and 2 (for systematic reviews and meta-analyses) in Appendix E document details about all these studies.

Table 10

Study characteristics, symptom response, and quality ratings of studies in adults with rheumatoid arthritis

Study | Study Design N Duration | Study Population | Comparison (dose) | Results | Quality Rating
Corticosteroids vs. Corticosteroids
Kirwan et al., 2004^29^ | RCT 143 12 weeks | Population-based; active RA; mean disease duration 9 years | BUD (3 mg/day) vs. BUD (9 mg/day) vs. PNL (7.5 mg/day) | No significant difference between 9 mg BUD and PNL for ACR 20, DAS (ACR 20: 42% vs. 56%; P = 0.11) | Fair
Synthetic DMARDs vs. Synthetic DMARDs
Capell et al., 2007^30^ | RCT 165 (Phase 1 run-in: 687) 6 months (18 months for those with DAS ≥ 2.4 at 6 months) | Scotland; 8 NHS sites; active RA; mean disease duration 1.6 to 1.8 years | SSZ (≤4 g/day) vs. MTX (≤25 mg/week) | At 18 months, no significant difference in DAS for SSZ vs. MTX (−0.30 vs. −0.26; P = 0.79); no significant difference in any ACR responses | Fair
Dougados et al., 1999^31^ | RCT 209 (146) 52 weeks (5 year followup) | Multinational; DMARD naive; mean disease duration 2.3 to 3.4 months | SSZ (2 to 3 g/day) vs. MTX (7.5 to 15 mg/week) | No significant difference in DAS between SSZ vs. MTX (−1.15 vs. −0.87; P = NS, NR); no significant difference in ACR 20 responses; P = NR | Fair
Emery et al., 2000^32^ | RCT 999 1 year with optional 2nd year | Mean disease duration 3.5 to 3.8 years | LEF (20 mg/day) vs. MTX (10 to 15 mg/week) | Lower ACR 20 responses at 12 months (50.5% vs. 64.8%; P<0.001); no significant differences in ACR at 2 years (64.3% vs. 71.7%; P = NS, NR) | Fair
Haagsma et al., 1997^33^ | RCT 105 52 weeks | Netherlands academic and peripheral clinics; DMARD naive; mean disease duration 2.6 to 3.1 months | SSZ (1 to 3 g/day) vs. MTX (7.5 to 15 mg/week | No significant difference in DAS for SSZ vs. MTX (−1.6 vs. −1.7; P = NS, NR) | Fair
Osiri et al., 2003^34^ | Systematic review and meta-analysis 1,732 2 years | 6 trials; active RA | LEF (10 to 20 mg/day) vs. MTX (7.5 to 15 mg/week) | Lower ACR 20 responses for LEF vs. MTX at 12 months (OR, 1.43; 95% CI, 1.15–1.77; P = 0.001); no significant differences in ACR response rates at 2 years | Good
Osiri et al., 2003 (cont’d) | | | LEF (10 to 20 mg/day) vs. SSZ (2 g/day) | Higher ACR 20 and ACR 50 responses for LEF vs. SSZ at 24 months (ACR 20: OR, 0.35; 95% CI, 0.16–0.77; P = 0.009) (ACR 50: OR, 0.32; 95% CI, 0.15–0.67; P = 0.003); no significant differences in any ACR response rates at 6 and 12 months
Smolen et al., 1999;^35^ Larsen et al., 2001^36^ | RCT 358 24 weeks (12 and 24 month followup) | Mean disease duration 5.7 to 7.6 years | LEF (20 mg/day) vs. SSZ (2 g/day) | Similar ACR 20 response rates (48% vs. 44%; P = NR) | Fair
Strand, et al., 1999^37,38^ | RCT 482 12 months (1 year continuation) | Mean disease duration 6.5 to 7 years | LEF (20 mg/day) vs. MTX (7.5 to 15 mg/week) | At 1 year, ACR 20 numerically higher for LEF but not significant (52% vs. 46%; P = NR); at 2 years, ACR 20 difference not significant (79% vs. 67%; P = 0.019) | Fair
Synthetic DMARD Combinations vs. Monotherapy or Combinations, With or Without Corticosteroids
Boers et al., 1997;^39^ Landewe et al., 2002^40^ COBRA Study | RCT 155 (148) 56 weeks (5-year followup) | Multicenter; early RA; mean disease duration 4 months | SSZ (2 g/day) + MTX (7.5 mg/day stopped after 40 weeks) + PNL (60 mg/day tapered over 28 weeks) vs. SSZ | Pooled disease index: mean change better in combo group than SSZ alone at 28 weeks (1.4 vs. 0.8; P < 0.0001) vs. no longer significant at 52 weeks (1.1 vs. 0.9; P = 0.20) (Pooled index included tender joint count, grip strength, ESR, VAS, MACTAR questionnaire) | Good
Capell et al., 2007^30^ | RCT 165 (Phase 1 run-in: 687) 6 months (18 months for those with DAS ≥2.4 at 6 months) | Scotland, 8 NHS sites; active RA; mean disease duration 1.6 to 1.8 years | SSZ (≤4 g/day) + MTX (≤25 mg/week) vs. SSZ (≤4 g/day) vs. MTX (≤25 mg/week) | Combination therapy better than monotherapy MTX or SSZ for DAS (−0.67, −0.30, −0.26; P = 0.039 for SSZ + MTX vs. SSZ; P= 0.023 for SSZ + MTX vs. MTX) No significant difference in ACR responses | Fair
Dougados et al., 1999^31^ Maillefert et al., 2003^41^ | RCT 209 (146) 52 weeks (5 year followup) | Multinational; DMARD naive; mean disease duration 2.3 to 3.4 months | SSZ (2 to 3 g/day) + MTX (7.5 to 15 mg/week) vs. SSZ (2 to 3 g/day) vs. MTX (7.5 to 15 mg/week) | No significant difference in ACR responses (65 vs. 59 vs. 59; P = NS, NR) DAS change (−1.26 vs. −1.15 vs. −0.87; P = 0.019) DAS change NS at year 5 | Fair
Goekoop- Ruiterman et al., 2005^42^ BeSt study | RCT 508 12 months | Multicenter; early RA; median duration between diagnosis and inclusion 2 weeks (IQR 1to 5); median duration of symptoms 23 weeks (IQR 14 to 53) | 1: sequential monotherapy starting with MTX (15 mg/week) vs. 2: step- up combination therapy (MTX, then SSZ, then HCQ, then PRED) vs. 3: combination with tapered high-dose PRED (60 mg/d to 7.5 mg/day) vs. 4: combination (MTX 25 to 30 mg/week) with INF (3 mg/kg every 8 weeks, per DAS, could be titrated to 10 mg/kg) | DAS ≤ 2.4: 53%, 64%, 71%, 74%; P = 0.004 for 1 vs. 3; P = 0.001 for 1 vs. 4; P = NS for other comparisons | Good
Haagsma et al., 1997^33^ | RCT 105 52 weeks | Netherlands academic and peripheral clinics; DMARD naive; mean disease duration 2.6 to 3.1 months | MTX (7.5 to 15 mg/week) + SSZ (2 to 3 g/day) vs. SSZ (1 to 3 g/day) vs. MTX (7.5 to 15 mg/week) | No significant difference in ACR or DAS responses | Fair
Mottonen et al., 1999;^43^ Korpela et al., 2004^44^ FIN-RACo study | RCT 199 24 months (5 year follow-up) | Multicenter; early RA; mean disease duration 7.3 to 8.6 months | MTX (7.5 to 10 mg/week) + HCQ (300 mg/day) + SSZ (2 g/day) + PNL (5 to 10 mg/day) vs. DMARD (SSZ could be changed to MTX or 3rd line) ± PNL | Remission (defined by ACR preliminary criteria modified by authors) higher in combination group (37.9% vs. 18.4%; P = 0.011); ACR 50 higher in combination group (71% vs. 58%; P = 0.058); (5-year remission, NS, 28% vs. 22%; P = NS) | Fair
O’Dell et al., 2002^45^ | RCT 171 2 years | Mean disease duration 5.8 to 7.9 years | 1: MTX (7.5 titrated to 17.5 mg/week) + SSZ (2 g/day) + HCQ (400 mg/day) vs. 2: MTX + HCQ vs. 3: MTX + SSZ | ACR 20: 78%, 60%, 49% 1 vs. 2: P = 0.05 1 vs. 3: P = 0.002 | Good
O’Dell et al., 1996^46^ | RCT 102 2 years | Poor response to at least 1 DMARD; mean disease duration 6 to 10 years | 1: MTX (7.5 to 17.5 mg/week) + SSZ (1 g/day) + HCQ (400 mg/day) vs. 2: MTX (7.5 to 17.5 mg/week) vs. 3: SSZ (1 g/day) + HCQ (400 mg/day) | 50% improvement (defined by authors): 77%, 40%, 33% 1 vs. 3: P < 0.001 1 vs. 2: P = 0.003 | Good
Svensson et al., 2005^47^ | Open-label trial 250 2 years | Population-based; active RA; duration 1 year or less | DMARD (SSZ or MTX, dosages NR) + PNL (7.5 mg/day) vs. DMARD | More patients in DMARD + PNL combination group achieve remission (DAS < 2.6) than DMARD-only group (55.5% vs. 43.8%; P = 0.0005) | Fair
Biologic DMARDs vs. Biologic DMARDs
Clark et al., 2004^48^ | Meta-analysis NR | Patients who have failed MTX treatment; mean disease duration varied | ANA vs. Anti-TNF as a class | Significantly lower ACR 20 response rates of anakinra than anti-TNF as a class. Risk difference: −0.21 (95% CI, −0.32–0.10) | Good
Gartlehner et al., 2006^49^ | Meta-analysis 5,248 | Patients who have failed MTX treatment; mean disease duration varied | ADA (40 mg every other week), ANA (100 mg/day), ETA (25 mg twice weekly), INF (3 to 10 mg every 8 weeks) | No difference in efficacy among anti-TNF drugs; greater efficacy of anti-TNF drugs than anakinra on ACR 20: RR, 0.61 (95% CI, 0.39–0.96) | Good
Geborek et al., 2002^50^ | Nonrandomize d, open-label trial 369 12 months | Population-based; active RA; had failed at least 2 DMARDs; mean disease duration 14.5 years | ETA (25 mg twice weekly) vs. INF (3 mg/kg or higher) | Higher ACR 20 responses for ETA at 3 (data NR; P < 0.02) and 6 months (data NR; P < 0.05); no significant differences in ACR response rates at 12 months (data NR) | Fair
Hochberg et al., 2003^51^ | Meta-analysis 1,053 | Patients who have failed MTX treatment; mean disease duration varied | ADA (40 mg every other week), ETA (25 mg twice weekly), INF (3 to 10 mg every 8 weeks) | No difference in ACR 20 response rates among anti-TNF drugs | Fair
Kristensen et al., 2002^52^ | Prospective cohort study 949 36 months | Inadequate response to at least 2 DMARDs | ETA (25 mg twice weekly) vs. INF (3 mg/kg or higher) | No difference in ACR 50 response at 36 months (data NR) | Fair
Wailoo et al., 2006^21^ | Meta-analysis 6,694 | Patients with RA; mean disease duration varied | INF, ETA, ANA, ADA | No difference in ACR 50 response rates among anti-TNF drugs | Fair
Weaver et al., 2006^53^ | Prospective cohort study 1,371 12 months | Population-based; patients with active RA who required change in therapy; mean disease duration 9.3 years | ETA (25 mg twice weekly) vs. INF (3.8 mg/kg or higher) | Higher mACR 20 response rates for ETA than INF (41% vs. 26%; P = NR) | Fair
Biologic DMARDs vs. Synthetic DMARDs
Bathon et al., 2000;^54^ Genovese et al., 2002;^55^ Genovese et al., 2005^56^ ERA study | RCT 632 (512) 12 months (1 year open-label extension) | Early, aggressive RA; MTX-naive; mean disease duration 11.7 months | ETA (10 or 25 mg twice weekly) vs. MTX (20 mg/week) | Significantly greater improvement of ACR-N for ETA 25 mg than for MTX (data NR; P < 0.05) | Fair
Breedveld et al., 2006^57^ PREMIER study | RCT 799 2 years | Early, aggressive RA; MTX-naive; mean disease duration NR (< 3 years) | ADA (40 mg biweekly) vs. MTX (20 mg/week) | Lower ACR 50 response rates for ADA than MTX (37% vs. 43%; P = NR) | Fair
Geborek et al., 2002^50^ | Nonrandomized, open-label trial 369 12 months | Population-based; active RA; had failed at least 2 DMARDs; mean disease duration 14.5 years | ETA (25 mg twice weekly) vs. INF (3 mg/kg or higher) vs. LEF (20 mg/day) | Higher ACR 20/50 responses for ETA and INF at 3 months (data NR; P < 0.05) and for ETA at 6 months (data NR; P < 0.05); results for 12 months: NR | Fair
Listing et al., 2006^58^ | Prospective cohort study 1,083 12 months | Population-based; patients with active RA who required change in therapy; mean disease duration 9.6 years | Biologics as a class (ADA, ANA, ETA, INF; dose NR) vs. DMARDs as a class (dose NR) | Significantly higher chance of remission for biologics than DMARDs (OR, 1.95; 95% CI, 1.20–3.19) | Fair
Weaver et al., 2006^53^ | Prospective cohort study 1,371 12 months | Population-based; patients with active RA who required change in therapy; mean disease duration 9.3 years | ETA (25 mg twice weekly) vs. INF (3.8 mg/kg or higher) vs. MTX (10 to 15 mg/week) | Higher mACR 20 response rates for ETA than INF (41% vs. 26%; P = NR) | Fair
Biologic DMARDs + Biologic DMARDs vs. Biologic DMARDs
Genovese et al., 2004^59^ | RCT 242 24 weeks | Inadequate control of disease with MTX; mean disease duration 9.9 years | ETA (25 mg twice weekly) + AKA (100 mg/day) vs. ETA (25 mg/week) | Higher ACR 50 response rates for ETA monotherapy (31% vs. 41%; P = 0.914) | Fair
Biologic DMARDs + Synthetic DMARDs vs. Biologic DMARDs
Breedveld et al., 2006^57^ PREMIER study | RCT 799 2 years | Early, aggressive RA; MTX-naive; mean disease duration NR (< 3 years) | ADA (40 mg biweekly) + MTX (20 mg/week) vs. ADA (40 mg biweekly) | Significantly higher ACR 50 response rates for ADA + MTX than ADA (59% vs. 37%; P < 0.001) | Fair
Combe et al., 2006^60^ | RCT 260 24 weeks | Active RA despite SSZ treatment; mean disease duration 6.6 years | ETA (25 mg twice weekly) + SSZ (2, 2.5, or 3 g/day) vs. ETA (25 mg twice weekly) | Similar ACR 20 response rates between ETA + SSZ and ETA (74% vs. 74%; P = NR) | Fair
Edwards et al., 2004^61^ | RCT 161 24 weeks | Active RA despite MTX treatment; mean disease duration 10.4 years | RIT (1,000 mg/days 1&15) + MTX (>10 mg/day) vs. RIT (1,000 mg/days 1&15) vs. MTX | Higher ACR 50 response rates for the RIT + MTX combination than for RIT monotherapy (43% vs. 33%; P = NR) | Fair
Hyrich et al., 2006^62^ | Prospective cohort study 2,711 6 months | Population-based; patients with active RA who required change in therapy; mean disease duration 14.3 years | ETA (25 mg twice weekly) + MTX (dose NR) vs. ETA (25 mg twice weekly) + other DMARD (dose NR) vs. ETA (25 mg twice weekly) INF (3 mg/kg) + MTX (dose NR) vs. INF (3 mg/kg) + other DMARD (dose NR) vs. INF (3 mg/kg) | Significantly higher EULAR response rates for ETA + MTX than ETA (OR, 1.98; 1.45–2.71) Higher EULAR response rates for INF + MTX than INF (OR, 1.35; 0.92–2.00) | Good
Klareskog et al., 2004;^63^ van der Heijde et al., 2006;^64^ van der Heijde et al., 2006^65^ TEMPO study | RCT 686 (503 for 2 year results) 52 weeks (2 years, 100 weeks) | Active RA; had failed at least 1 DMARD other than MTX; mean disease duration 6.6 years | ETA (25 mg twice weekly) + MTX (7.5 titrated to 20 mg/week) vs. MTX (7.5 titrated to 20 mg/week) | Significantly higher area under curve of ACR-N for ETA + MTX than ETA (18.3%-years vs. 14.7%-years; P < 0.0001) at 24 weeks | Fair
Van Riel et al., 2006^66^ | Open-label RCT 315 16 weeks | Inadequate control of disease with MTX; mean disease duration 10.9 years | ETA (25 mg twice weekly) + MTX (>12.5 mg/week) vs. ETA (25 mg twice weekly) | Similar proportions of patients achieved an improvement of > 1.2 units of DAS 28 (75% vs. 73%; P = 0.66) | Fair
Weaver et al., 2006^53^ | Prospective cohort study 3,034 12 months | Population-based; patients with active RA who required change in therapy; mean disease duration 8.3 years | ETA (25 mg twice weekly) + MTX (dose NR) vs. ETA (25 mg twice weekly) | Similar mACR 20 response rates for ETA + MTX and ETA (43% vs. 41%; P = NR) | Fair
Zink et al., 2005^67^ | Retrospective cohort study 1,523 1 year | Patients with RA who had a change in treatment regimen | ETA + MTX vs. ETA (dosages NR) INF + MTX vs. INF, (dosages NR) | Discontinuation due to lack of efficacy: Greater in ETA monotherapy vs. combination (ETA + MTX: 16.9%; ETA: 19.9%; P = NR) Greater in INF monotherapy than combination (INF + MTX: 17.9%, INF: 45%) | Good
Biologic DMARDS + Synthetic DMARDs vs. Synthetic DMARDs
Breedveld et al., 2006^57^ PREMIER study | RCT 799 2 years | Early, aggressive RA; MTX-naive; mean disease duration NR (< 3 years) | ADA (40 mg biweekly) + MTX (20 mg/week) vs. MTX (20 mg/week) | Significantly higher ACR 50 response rates for ADA + MTX than MTX (59% vs. 43%; P < 0.001) | Fair
Combe et al., 2006^60^ | RCT 260 24 weeks | Active RA despite SSZ treatment; mean disease duration 6.6 years | ETA (25 mg twice weekly) + SSZ (2, 2.5, or 3 g/day) vs. SSZ (2, 2.5, or 3 g/day) | Higher ACR 20 response rates between ETA + SSZ and SSZ (74% vs. 28%; P = NR) | Fair
Klareskog et al., 2004;^63^ van der Heijde et al., 2006;^64^ van der Heijde et al., 2006^65^ TEMPO study | RCT 686 (503 for 2 year results) 52 weeks (2 years, 100 weeks) | Active RA; had failed at least 1 DMARD other than MTX; mean disease duration 6.6 years | ETA (25 mg twice weekly) + MTX (7.5 titrated to 20 mg/week) vs. MTX (7.5 titrated to 20 mg/week) | Significantly higher area under curve of ACR-N for ETA + MTX than MTX (18.3%-years vs. 12.2%-years; P < 0.0001) at 24 weeks | Fair
St Clair et al., 2004;^68^ Smolen et al., 2006^69^ ASPIRE study | RCT 1,049 54 weeks | Early, aggressive RA; MTX-naive; mean disease duration 0.9 years | INF (3 mg/kg/8 weeks) + MTX (20 mg/week) vs. INF (6 mg/kg/8 weeks) + MTX (20 mg/week) vs. MTX (20 mg/week) | Significantly greater improvement of ACR-N for INF 3 mg + MTX and INF 6 mg + MTX than MTX (38.9% vs. 46.7% vs. 26.4%; P < 0.001) | Fair

ACR-N, American College of Rheumatology percent improvement from baseline to endpoint; ADA, adalimumab; ANA, anakinra; BUD, budesonide; CI, confidence interval; Combo, combination therapy; DAS, disease activity score; DMARD, disease-modifying antirheumatic drug; ESR, erythrocyte sedimentation rate; ETA, etanercept; EULAR, European League Against Rheumatism; HCQ, hydroxychloroquine; INF, infliximab; IQR, interquartile range; LEF, leflunomide; mACR, modified ACR; MACTAR, McMaster Toronto Arthritis Questionnaire; MTX, methotrexate; mg, milligram; NHS, National Health Service; NR, not reported; NS, not significant; OR, odds ratio; PNL, prednisolone; PRED, prednisone; RA, rheumatoid arthritis; RCT, randomized controlled trial; RIT, rituximab; SSZ, sulfasalazine; TNF, tumor necrosis factor; VAS, visual analog scale; vs., versus.

Table 11

Study characteristics and radiographic joint damage in adults with rheumatoid arthritis

Study | Study Design N Duration | Population with Early RA (< 3 years) | Comparison (dose) | Radiographic Outcomes
Synthetic DMARDs vs. Synthetic DMARDs
Capell et al., 2007^30^ | RCT 165 (Phase 1 run- in: 687) 6 months (18 months for those with DAS ≥ 2.4 at 6 months) | Yes (70% 1 year or less) | SSZ (≤4 g/day) vs. MTX (≤ 25 mg/week) | No significant difference in total modified Sharp/van der Heijde score change (Data NR)
Dougados et al., 1999^31^ | RCT 209 (146) 52 weeks (5 years) | Yes | SSZ (2 to 3 g/day) vs. MTX (7.5 to 15 mg/week) | Total modified Sharp/van der Heijde score change: 4.64 vs. 4.50 vs. 3.36; P = NS, NR; change at 5 years: 8.5 vs. 7.5; P = 0.7
Emery et al., 2000^32^ | RCT 999 1 year with optional 2nd year | No | LEF (20 mg/day) vs. MTX (10 to 15 mg/week) | Larsen score change at 1 year: 0.3 vs. 0.3; P = NS Larsen score change at 2 years: 1.27 vs. 1.31; P = NS, NR
Osiri et al., 2003^34^ | Systematic review and meta-analysis 1,732 2 years | No | LEF (10 to 20 mg/day) vs. MTX (7.5 to 15 mg/week) LEF (10 to 20 mg/day) vs. SSZ (2 g/day) | No differences in total Sharp score change or Larsen score change
Smolen et al., 1999;^35^ Larsen, et. al., 2001^36^ | RCT 358 24 weeks (12 and 24 month followup) | No | LEF (20 mg/day) vs. SSZ (2 g/day) | Larsen score change at 24 weeks: 0.01 vs. 0.01; P = NS Larsen score change at 1 year: 0.02 vs. 0.02; P = NS Larsen score change at 2 years: −0.07 vs. −0.03; P = NR
Strand et al., 1999^37^ | RCT 482 12 months (1 year continuation) | No | LEF (20 mg/day) vs. MTX (7.5 to 10 mg/week) | Total Sharp score change at 1 year: 0.53 vs. 0.88 (P = 0.05) Total Sharp score at 2 years: 1.6 vs. 1.2 (P = 0.659)
Synthetic DMARD Combinations vs. Monotherapy or Combinations, With or Without Corticosteroids
Boers et al., 1997;^39^ Landewe et al., 2002^40^ COBRA study | RCT 155 (148) 56 weeks (5 year followup) | Yes | SSZ (2 g/day) + MTX (7.5 mg/day stopped after 40 weeks) + PNL (60 mg/day tapered over 28 weeks) vs. SSZ | Median modified Sharp/van der Heijde score change improved at 28 weeks (1 vs. 4; P< 0.0001), 56 weeks (2 vs. 6; P < 0.004) and 80 weeks (4 vs. 12; P < 0.01). [At 5 years mean modified Sharp/van der Heijde score change per year was lower for combo (5.6 vs. 8.6; P= 0.001)]
Capell et al., 2007^30^ | RCT 165 (Phase 1 run- in: 687) 6 months (18 months for those with DAS ≥ 2.4 at 6 months) | Yes (70% 1 year or less) | SSZ (≤4 g/day) + MTX (≤25 mg/week) vs. SSZ (≤4 g/day) vs. MTX (≤25 mg/week) | No significant difference in total Sharp score (Data NR)
Dougados et al., 1999;^31^ Maillefert et al., 2003^41^ | RCT 209 (146) 52 weeks (5 year followup) | Yes | SSZ (2 to 3 g/day) + MTX (7.5 to 15 mg/week) vs. SSZ (2 to 3 g/day) vs. MTX (7.5 to 15 mg/week) | 5-year mean modified Sharp/van der Heijde score change: 8.5 vs. 7.5; P = 0.7
Goekoop-Ruiterman, 2005^42^ BeST study | RCT 508 12 months | Yes | 1: sequential monotherapy starting with MTX (15 mg/week) vs. 2: step-up combination therapy (MTX, then SSZ, then HCQ, then PRED) vs. 3: combination with tapered high-dose PRED (60 mg/d-7.5 mg/day) vs. 4: combination (MTX 25 to 30 mg/week) with INF (3 mg/kg every 8 weeks, per DAS, could be titrated to 10 mg/kg) | Median modified Sharp/van der Heijde score change: 2.0, 2.5, 1.0, 0.5; P = 0.003 for 1 vs. 3, P < 0.001 for 1 vs. 4; P = 0.007 for 2 vs. 3; P< 0.001 for 2 vs. 4
Mottonen et al., 1999; 43 Korpela et al., 2004^44^ FIN-RACo study | RCT 199 24 months (5 years) | Yes | MTX (7.5 to 10 mg/week) + HCQ (300 mg/day), + SSZ (2 g/day) + PNL (5 to 10 mg/day) vs. DMARD (SSZ could be changed to MTX or 3rd line) ± PNL | 2-year Larsen score change: 2 vs. 10; P = 0.002 2-year erosion score change: 2 vs. 3; P = 0.006 5-year median Larsen score: 11 vs. 24; P =0.001
Svensson et al., 2005^47^ | Open-label trial 250 2 years | Yes | DMARD (SSZ or MTX, dosages NR) + PNL (7.5 mg/day) vs. DMARD | Median modified Sharp/van der Heijde score change: 1.8 vs. 3.5; P = 0.019 Erosion score median change: 0.5 vs. 1.25; P = 0.007 Joint space narrowing score median change: 1.0 vs. 2.0; P = 0.08
Biologic DMARDs vs. Synthetic DMARDs
Bathon et al., 2000;^54^ Genovese et al., 2002^55^ Genovese et al., 2005^56^ ERA study | RCT 632 (512) 12 months (1 year open-label extension) | Yes; MTX-naive patients with early, aggressive RA | ETA (10 or 25 mg twice weekly) vs. MTX (20 mg/week) | At 1 year: Total modified Sharp score change: 1.00 vs. 1.59; P = 0.11 Erosion score change: 0.47 vs. 1.03; P = 0.002 Joint space narrowing score change: NR At 2 years: Total modified Sharp score change: 1.3 vs. 3.2; P = 0.001 Erosion score change: 0.7 vs. 1.9; P = 0.001 Joint space narrowing score change: NR
Breedveld et al., 2006^57^ PREMIER study | RCT 799 2 years | Yes; MTX-naive patients with early, aggressive RA | ADA (40 mg biweekly) vs. MTX (20 mg/week) | Total modified Sharp score change: 5.5 vs. 10.4; P < 0.001 Erosion score change: 3.0 vs. 6.4; P < 0.001 Joint space narrowing score change: 2.6 vs. 4.0; P < 0.001
Klareskog et al., 2004^63^ van der Heijde et al., 2006^64^ van der Heijde et al., 2006^65^ TEMPO study | RCT 686 (503 for 2 year results) 52 weeks (2 years, 100 weeks) | No | ETA (25 mg twice weekly) + MTX (7.5 titrated to 20 mg/week) vs. MTX (7.5 titrated to 20 mg/week) | At 1 year: Total modified Sharp score change: 0.52 vs. 2.80; P = 0.047 Erosion score change: 0.21 vs. 1.68; P < 0.008 Joint space narrowing score change: 0.32 vs. 1.12; P = NR (NS)
Biologic DMARDs + Synthetic DMARDs vs. Biologic DMARDs
Breedveld et al., 2006^57^ PREMIER study | RCT 799 2 years | Yes; MTX-naive patients with early, aggressive RA | ADA (40 mg biweekly) + MTX (20 mg/week) vs. ADA (40 mg biweekly) | Total modified Sharp score change: 1.9 vs. 5.5; P < 0.001 Erosion score change: 1.0 vs. 3.0; P < 0.001 Joint space narrowing score change: 0.9 vs. 2.6; P < 0.001
Klareskog et al., 2004^63^ van der Heijde et al., 2006^64^ van der Heijde et al., 2006^65^ TEMPO study | RCT 686 52 weeks | No | ETA (25 mg twice weekly) + MTX (20 mg/week) vs. ETA (25 mg twice weekly) | At 1 year: Total modified Sharp score change: −0.54 vs. 0.52; P = 0.0006 Erosion score change: −0.30 vs. 0.21; P < 0.0001 Joint space narrowing score change: −0.23 vs. 0.32; P = 0.0007 At 2 years: Total modified Sharp score change: −0.56 vs. 1.10; P < 0.05 Erosion score change: −0.76 vs. 0.36; P < 0.05 Joint space narrowing score change: 0.20 vs. 0.74; P = NR (NS)
Biologic DMARDs + Synthetic DMARDs vs. Synthetic DMARDs
Breedveld et al., 2006^57^ PREMIER study | RCT 799 2 years | Yes; MTX-naive patients with early, aggressive RA | ADA (40 mg biweekly) + MTX (20 mg/week) vs. MTX (20 mg/week) vs. ADA (40 mg biweekly) | Total modified Sharp score change: 1.9 vs. 10.4; P < 0.001 Erosion score change: 1.0 vs. 6.4; P < 0.001 Joint space narrowing score change: 0.9 vs. 4.0; P < 0.001
St Clair et al., 2004; 68 Smolen et al., 2006^69^ ASPIRE study | RCT 1,049 54 weeks | Yes; MTX-naive patients with early, aggressive RA | INF (3 mg/kg/8 weeks) + MTX (20 mg/week) vs. INF (6 mg/kg/8 weeks) + MTX (20 mg/week) vs. MTX (20 mg/week) | Modified Sharp/van der Heijde score change: 0.4 vs. 0.5 vs. 3.7; P < 0.001 Erosion score change: 0.3 vs. 0.1 vs. 3.0; P < 0.001 Joint space narrowing score change: 0.1 vs. 0.2 vs. 0.6; P < 0.001

ADA, adalimumab; Combo, combination therapy; DAS, disease activity score; DMARD, disease-modifying antirheumatic drug; ETA, etanercept; HCQ, hydroxychloroquine; INF, infliximab; LEF, leflunomide; MTX, methotrexate; PNL, prednisolone; PRED, prednisone; NR, not reported; NS, not significant; RA, rheumatoid arthritis; RCT, randomized controlled trial; SSZ, sulfasalazine.

### Rheumatoid Arthritis: Overview

A total of 21 RCTs, one nonrandomized controlled trial, five observational studies, and five systematic reviews or meta-analyses compared symptom response, radiographic joint damage, and remission. Details are found in Evidence Tables 1 and 2, Appendix E. Table 10 provides information on comparisons made, symptom response, and quality ratings. Table 11 provides information on radiographic joint damage, indicating whether the study populations included patients with early RA. The main drug classes compared include corticosteroids, synthetic DMARDs, biologic DMARDs (also referred to simply as biologics), and various combined strategies.

### Rheumatoid Arthritis: Key Points

#### Corticosteroids vs. corticosteroids

One head-to-head RCT found no significant differences between budesonide and prednisolone for outcomes assessed by the American College of Rheumatology (ACR) response criteria set for 20 percent improvement (ACR 20) or the disease activity score (DAS).29 The strength of evidence is low.

#### Synthetic DMARDs vs. synthetic DMARDs

One systematic review and meta-analysis,34 which included two RCTs, found methotrexate (MTX) resulted in higher ACR 20 responses at 1 year when compared with leflunomide (odds ratio [OR], 1.43; 95% CI, 1.15–1.77; P = 0.001), but statistical significance was lost at 2 years.38 Radiographic changes were similar for both leflunomide and MTX. The results were limited by the few number of studies included for meta-analysis. The strength of the evidence is moderate.

Three RCTs found similar response rates for patients receiving sulfasalazine and for those receiving MTX on outcomes measured by ACR 20, DAS, and radiologic data.30,31,33 The strength of evidence is moderate.

One RCT reported that leflunomide produced higher proportions of patients meeting ACR 20 and ACR 50 improvement criteria at 24 months than did sulfasalazine.36 Radiographic changes were similar for leflunomide and sulfasalazine. The strength of the evidence is low.

No fair or good evidence exists for comparing hydroxychloroquine monotherapy with other synthetic DMARD monotherapy.

#### Synthetic DMARD combinations

Studies of several different types of combination strategies favored, overall, combination strategies using two or three drugs over fewer drugs.

Of three RCTs,30,31,33 one supported combination therapy with sulfasalazine and MTX vs. monotherapy with either drug; the changes in DAS scores were greater for combination therapy (−1.26 for combination, −1.15 for sulfasalazine, and −0.87 for MTX) (P = 0.019).31 The other two trials reported no differences but focused on patients with early RA. The strength of evidence is moderate. All RCTs were funded by the makers of synthetic DMARDs.

Two RCTs found that, at 2 years, the combination of MTX, sulfasalazine, and hydroxychloroquine had better ACR 20 response rates than one or two drugs.45,46 The strength of evidence is moderate. Both RCTs were funded by the makers of synthetic DMARDs.

One open-label effectiveness trial suggested that combining one synthetic DMARD (MTX or sulfasalazine) with prednisolone delayed radiographic progression more than a synthetic DMARD alone (25.9 percent vs. 39.3 percent progressed based on modified Sharp/van der Heijde score; P = 0.033).47 One RCT39 with a 5-year follow-up cohort40 reported that combination therapy, which included two synthetic DMARDs (MTX and sulfasalazine) plus a stepped-down prednisolone treatment, demonstrated less radiographic progression than sulfasalazine alone (5-year mean change in Sharp Scale score, 5.6 vs. 8.6; P = 0.001). Another RCT43 with a 5-year follow-up cohort44 suggested that the combination of three synthetic DMARDs (MTX, sulfasalazine, and hydroxychloroquine) plus prednisolone had less radiographic change than one synthetic DMARD (5-year median Larsen Scale score, 11 vs. 24; P = 0.001). Although the data are limited to one study for each comparison, we judged the strength of evidence to be moderate for these combinations.

One complex effectiveness trial compared several strategies.42 The authors reported that either (1) MTX, sulfasalazine, and tapered high-dose prednisone or (2) MTX and infliximab resulted in less radiographic change over 12 months than (3) sequential DMARD therapy or (4) step-up combination therapy. The median increases in modified Sharp/van der Heijde scores were, respectively, 2.0, 2.5, 1.0, and 0.5 (P = 0.003 for group 1 vs. group 3; P < 0.001 for group 1 vs. group 4; P = 0.007 for group 2 vs. group 3; P < 0.001 for group 2 vs. group 4). The data are limited to one trial. The strength of evidence is low.

#### Biologic DMARDs

We did not find any head-to-head RCTs that compared one biologic DMARD with another. Existing direct head-to-head evidence is limited to a nonrandomized, open-label effectiveness trial50 and two prospective cohort studies;52,53 all compared etanercept with infliximab. These studies reported a faster onset of response for etanercept during the first months of therapy but no differences in efficacy thereafter. The faster onset of etanercept might be attributable partly to necessary dose adjustments for patients treated with infliximab. One study, however, attributed differences to lower rates of adherence among patients on infliximab than among those on etanercept. Generally, because of methodological limitations, findings of these studies must be interpreted cautiously.

Adjusted indirect comparisons, based on placebo-controlled RCTs, do not suggest any differences in efficacy among adalimumab, etanercept, and infliximab.21,48,49,51 This is consistent with results from the open-label effectiveness trial50 and two observational studies52,53 mentioned above.

Anakinra, however, appears to have lower efficacy than adalimumab, etanercept, and infliximab.48,49 Although not all results reached statistical significance, anakinra had consistently lower response rates on ACR 20 (relative risk [RR], 1.64; 95% CI, 1.04–2.56) and ACR 50 (RR, 1.89; 95% CI, 0.98–3.57) than anti-tumor necrosis factor (anti-TNF) drugs as a class (i.e., adalimumab, etanercept, and infliximab as a class). Individual comparisons of anakinra with adalimumab, etanercept, and infliximab consistently presented lower response rates for anakinra, but the confidence intervals were wide and the findings did not reach statistical significance.

The strength of evidence for these comparisons is moderate. No evidence from adjusted indirect comparisons exists for abatacept and rituximab. The strength of the evidence for the comparative effectiveness of biologics is low.

#### Biologic DMARD combinations

One RCT did not detect any synergistic effects of a combination treatment of etanercept and anakinra compared with etanercept monotherapy.59 The strength of evidence is low.

Four RCTs57,61,63,66 and two prospective cohort studies53,62 suggested that a combination of MTX with adalimumab,57 etanercept,63–66 infliximab,53,62 or rituximab61 led to statistically significantly greater improvements with biologic DMARDs than with monotherapy. A combination of etanercept with sulfasalazine did not achieve better outcomes than etanercept monotherapy.60 For most of these comparisons, however, the evidence is limited to a single study. All RCTs were funded by the makers of the biologic DMARDs. Except for the PREMIER study on adalimumab,57 none of these trials was conducted in patients with early RA. The strength of evidence is high for the comparison of etanercept with MTX and moderate for all the other comparisons. No evidence is available on abatacept, anakinra, rituximab, and combinations with synthetic DMARDs other than MTX and sulfasalazine.

Two studies found that a combination of adalimumab with MTX57 and infliximab with MTX68 in patients with early, aggressive (i.e., rapidly progressing) RA who were MTX-naive led to better clinical and radiographic outcomes than MTX monotherapy. Both RCTs were funded by the makers of the biologic DMARDs. The strength of the evidence supporting a greater efficacy of a combination treatment than monotherapy is moderate for the above comparisons.

The evidence on the comparative efficacy of biologic DMARDs and synthetic DMARDs is mixed. Population-based, observational evidence from prospective cohort studies indicated that biologic DMARDs as a class were more efficacious than synthetic DMARDs as a class. RCTs, however, did not indicate any substantial differences in clinical response between either adalimumab or etanercept and MTX.54–57,63–65 Radiographic outcomes, however, were statistically significantly better in patients treated with biologic DMARDs than patients treated with MTX. How such intermediate outcomes translate to the long-term clinical progression of the disease remains unclear.

All RCTs were funded by the makers of the biologic DMARDs. No studies were available comparing biologics with either corticosteroids or with synthetic DMARDs other than MTX. The strength of the evidence for the available comparisons is moderate.

None of the RCTs can be considered an effectiveness study. Of four population-based prospective cohort studies, only one was conducted in the United States. The generalizability of results to the average primary care population, therefore, remains unclear. The strength of evidence regarding comparative effectiveness is low.

One small study, which did not meet eligibility criteria, reported a higher efficacy of infliximab compared with pulse methylprednisolone. No other evidence comparing biologic DMARDs with corticosteroids was available.

### Rheumatoid Arthritis: Detailed Analysis

#### Corticosteroids vs. corticosteroids

We found one head-to-head RCT (N = 143) comparing two corticosteroids.29 It examined the efficacy of low-dose budesonide (3 mg/day), high-dose budesonide (9 mg/day), and prednisolone (7.5 mg/day) over 12 weeks. Mean disease duration of RA was 9 years. When comparing drugs, the percentage achieving ACR 20 response criteria for high-dose budesonide (9 mg) was significantly greater than that for lower dose budesonide (3 mg) (42 percent vs. 22 percent; P < 0.001), but the percentages for high-dose budesonide and prednisolone did not differ significantly (42 percent vs. 56 percent; P = 0.11). Similarly, high-dose budesonide and prednisolone did not differ significantly for tender joint count, swollen joint count, and the DAS.

#### Synthetic DMARDs vs. synthetic DMARDs

##### Leflunomide vs. MTX

We found two trials comparing leflunomide (20 mg/day) with MTX (studies ranging from 7.5 mg/week to 15 mg/week) and one systematic review with meta-analysis of leflunomide.32,34,37 Given that the systematic review included only two trials comparing these two agents, we describe these two studies in detail here first. One trial randomized 482 patients to leflunomide (n = 182) or MTX (n = 182) over 12 months.37 Mean disease duration of RA across these groups was 6.5 years to 7 years. The proportions of patients meeting ACR 20 response criteria at 12 months was higher for leflunomide than MTX but not statistically significantly so (52 percent vs. 46 percent; P = NR). Proportions meeting ACR 50 and ACR 70 criteria also did not differ significantly. Leflunomide had less disease progression by Sharp score than MTX (respectively, 0.53 vs. 0.88; P = 0.05).

A continuation study followed the same cohort for 2 years (leflunomide, n = 98; MTX, n = 101).38 At 2 years, leflunomide was associated with higher proportions of patients meeting ACR 20 response criteria than MTX (79 percent vs. 67 percent; P = 0.049). The percentages of patients meeting either ACR 50 or ACR 70 criteria at 2 years did not differ significantly, and the change in total Sharp score also did not differ significantly at 2 years (1.6 vs. 1.2; P = 0.659).

These 2-year follow-up results are limited by the 45 percent attrition rate from the initial study.

The other trial comparing leflunomide to MTX examined 999 patients for 12 months with an optional second year (leflunomide, n = 501; MTX, n = 498).32 Mean disease duration across the groups was 3.5 to 3.8 years. At 12 months, the proportion of patients meeting ACR 20 response criteria was lower for leflunomide than for MTX (50.5 percent vs. 64.8 percent; P < 0.001), but differences were not significant at 2 years (64.3 percent vs. 71.7 percent; P = NS, NR). Radiological outcomes at 12 months using Larsen Scale scores for joint narrowing were statistically equivalent (0.03 increase in both groups). After 2 years, no further increase in joint damage occurred in patients treated with leflunomide; patients taking MTX had a small improvement (data NR). The overall result was a small significant difference in Larsen Scale scores favoring MTX after 2 years (data NR).

In this systematic review including two trials comparing leflumonide with MTX (n = 1,481) there were significantly more responders on the ACR 20 at 12 months favoring MTX (OR, 1.43; 95% CI, 1.15–1.77; P = 0.001); however, by 2 years, the statistically significant difference favoring MTX disappears (OR, 1.28; 95% CI, 0.98–1.67; P = 0.07). ACR 50 and ACR 70 responses did not differ between leflunomide and MTX, and the two drugs also did not differ in delaying bone erosions or joint damage assessed by total Sharp score.34 This systematic review was limited by the small number of studies that the authors could use for meta-analysis.

##### Leflunomide and sulfasalazine

One study35 with a 2-year followup36 compared leflunomide with sulfasalazine. In addition, one systematic review did a meta-analysis of leflunomide against sulfasalazine.34 Given that the systematic review included only one trial with this comparison, we describe it in detail first.35 This study was a 24-week, double-blind, multinational RCT of 358 patients on 20 mg/day leflunomide (n = 133) or 2 g/day sulfasalazine (n = 133).35 Mean disease duration across groups was 5.7 to 7.6 years. ACR 20 response at 24 weeks was similar for leflunomide and sulfasalazine (48 percent vs. 44 percent; P = NR). ACR 50 response rates were also similar (33 percent leflunomide, 30 percent sulfasalazine). Larsen Scale scores were also similar for leflunomide and sulfasalazine, and the Larsen Scale change score at endpoint was 0.01 for both drugs. In the follow-up study, patients who completed the first study could opt to continue on the 12- and 24-month double-blind extension.36 At 12 months (leflunomide, n = 80; sulfasalazine, n = 76), ACR 20 response was similar for leflunomide and sulfasalazine (77 percent vs. 73 percent; P = NR). At 24 months (leflunomide, n = 28; sulfasalazine, n = 27), ACR 20 response was significantly greater for leflunomide (82 percent vs. 60 percent; P = 0.0085). Changes in Larsen Scale scores were also similar for leflunomide and sulfasalazine (mean change: 0.02 vs. 0.02 at 12 months, −0.07 vs. −0.03 at 24 months; P = NR). Changes in Sharp scores were also not significantly different (mean change: 0.97 vs. 1.38; P = 0.685). However, these long-term results are significantly limited by the attrition rates of 65 percent to 70 percent.

The systematic review with meta-analysis compared leflunomide (10 to 20 mg/day) with sulfasalazine (2 g/day).34 The analysis included the study described above.35,36 Response to the two drugs did not differ as measured by either ACR 20 or ACR 50 criteria at 6 months and 12 months. However, leflunomide was more efficacious at 24 months (ACR 20: OR, 0.35; 95% CI, 0.16–0.77; P = 0.009; ACR 50: OR, 0.32; 95% CI, 0.15–0.67; P = 0.003). The ACR 70 response was not different between groups at 6, 12, or 24 months. Leflunomide and SSZ also did not differ in delaying bone erosions or joint damage by Sharp score or Larsen Scale score at 6, 12, or 24 months. Again, these results are significantly limited because they include only the one study.35

##### Sulfasalazine and MTX

Three RCTs examined the efficacy of sulfasalazine and MTX.30,31,33 Overall, findings from these studies showed similar response rates between sulfasalazine and MTX for ACR, DAS, and radiological outcomes. Two of the trials included patients with disease burden of less than 1 year and used a lower dose of weekly MTX (7.5 mg) than the doses generally used in the United States.31,33 These trials also included a combination therapy arm, which we describe below (in the section on Synthetic DMARD combinations vs. synthetic DMARD combinations or synthetic DMARD monotherapy).

One trial randomized 209 patients to receive 2 g/day to 3 g/day sulfasalazine (n = 68), 7.5 mg/week to 15 mg/week MTX (n = 69), or a combination (n = 68) for 52 weeks.31 Mean disease duration for the groups ranged from 2.3 months to 3.4 months. The ACR 20 responses did not differ statistically (59 percent sulfasalazine; 59 percent MTX; P = NR). The DAS change score favored sulfasalazine therapy (−1.15, sulfasalazine; −0.87, MTX; P = NR), but the statistical analysis examined only the comparison with combination therapy (reported under “Synthetic DMARD combinations vs. synthetic DMARD combinations or synthetic DMARD monotherapy”). Radiological scores at 5 years did not differ significantly; the mean total modified Sharp/van der Heijde scores were 8.5 for sulfasalazine and 7.5 for MTX (P = 0.7).

Another RCT, lasting 52 weeks (N = 105), also demonstrated similar ACR 20 and DAS results for sulfasalazine and MTX.33 This trial compared 1 g/day to 3 g/day sulfasalazine (n = 34) with 7.5 mg/week to 15 mg/week MTX (n = 35) and with a combination (discussed later in this chapter); mean disease duration was 2.6 to 3.1 months. The mean change in DAS over 52 weeks was −1.6 in the sulfasalazine group and −1.7 in the MTX group (P = NS). ACR 20 response was 25 percent for sulfasalazine and 25 percent for MTX.

Finally, one trial included a population with a disease duration of up to 10 years.30 The investigators gave 687 patients sulfasalazine (up to 4 g/day) for 6 months. Those with DAS ≥ 2.4 were offered inclusion into a Phase II study and randomized to (1) sulfasalazine (n = 55), (2) MTX (n = 54) (maximum dose, 25 mg/week), and (3) sulfasalazine plus MTX (n = 56). At 18 months, the DAS change was similar for sulfasalazine and MTX alone (−0.30 vs. −0.26; P = 0.79). The ACR 20, 50, and 70 responses were also similar (ACR 20, 18 percent vs. 15 percent; ACR 50, 6 percent vs. 7 percent; ACR 70, 2 percent vs. 2 percent; P = NR). The modified Sharp/van der Heijde score, total erosions, and joint space narrowing also did not differ significantly (data NR). However, 18 months is a short period for observing radiological outcomes, and this study was not powered to detect radiological progression.

#### Synthetic DMARD combinations vs. synthetic DMARD combinations or synthetic DMARD monotherapy

##### Sulfasalazine plus MTX vs. sulfasalazine or MTX

Three RCTs compared the efficacy of sulfasalazine and MTX vs. that of either sulfasalazine or MTX alone.30,31,33 Findings from two of these randomized trials consistently reported no significant differences in ACR, DAS, or radiological outcomes.31,33 They included patients with disease duration of less than 1 year and again used a lower dose of weekly MTX (7.5 mg) than the doses generally used in the United States.31,33 The third trial included patients with RA duration of up to 10 years, and their DAS results favored the sulfasalazine-MTX combination therapy over monotherapy.30

One 52-week trial randomized 209 patients to receive 2 g/day to 3 g/day sulfasalazine and 7.5 mg/week to 15 mg/week MTX (n = 68), sulfasalazine (n = 68), or MTX (n = 69).31 ACR 20 responses were numerically higher in the combination group, but the groups did not differ statistically (ACR: 65 percent combination; 59 percent sulfasalazine; 59 percent MTX; P = NS, NR). The DAS change favored combination therapy (DAS change: −1.26 combination; −1.15 sulfasalazine; −0.87 MTX; P = 0.019). In a 5-year prospective followup of this cohort, however, when comparing combination therapy vs. monotherapy, the differences in DAS change scores became nonsignificant at year 5.^41^ Additionally, radiological scores did not differ at 5 years; the total modified Sharp/van der Heijde score was 7.5 for combination therapy and 8.5 for single therapy (P = 0.7). A 52-week RCT (N = 105) also reported no significant differences in ACR or DAS results between combination and single therapy in this population.33

Finally, another trial included a population with a disease duration of up to 10 years (mean, 1.6 to 1.8 years).30 It gave 687 patients sulfasalazine (up to 4 g/day) for 6 months. Those with DAS ≥ 2.4 were offered inclusion into a Phase II study and randomized to (1) sulfasalazine plus MTX (n = 56), (2) sulfasalazine (n = 55), and (3) MTX (n = 54) (maximum dose, 25 mg/week). At 18 months, the DAS was significantly better in the combination arm than in either the sulfasalazine or MTX arms (DAS change scores: −0.67, −0.30, −0.26; combination vs. sulfasalazine; P = 0.039; combination vs. MTX; P = 0.023). The ACR 20, 50, and 70 responses were all higher in the combination arm, but they were not statistically different across the three arms. Additionally, the total modified Sharp/van der Heijde score, total erosions, and joint space narrowing also did not differ significantly across arms (data NR). However, 18 months is a short period for radiological outcomes, and this study was not powered for radiological progression.

##### MTX plus hydroxychloroquine plus sulfasalazine vs. one or two synthetic DMARDs

Two RCTs examined the combination of MTX, sulfasalazine, and hydroxychloroquine against either one or two drugs.45,46 Both studies found that the combination of the three DMARDs was more effective than either one or two DMARDs.

The more recent study randomized 171 patients over 2 years to (1) MTX 7.5 mg/week titrated to 17.5 mg/week plus sulfasalazine 2 g/day plus hydroxychloroquine 400 mg/day, (2) MTX plus hydroxychloroquine, or (3) MTX plus sulfasalazine.45 Mean disease duration across groups was 5.8 to 7.9 years. After 2 years, patients receiving triple therapy had an ACR 20 of 78 percent; the figures were 60 percent for those treated with MTX and hydroxychloroquine (P = 0.05) and 49 percent for those treated with MTX and sulfasalazine (P = 0.002).

#### Synthetic DMARDs plus corticosteroid combinations vs. synthetic DMARDs

##### One synthetic DMARD plus corticosteroid vs. synthetic DMARD

One open-label RCT compared a combination therapy involving a synthetic DMARD (either MTX or sulfasalazine) and a corticosteroid with a synthetic DMARD only (N = 250).47 This study suggested that, for patients with early RA, combining a synthetic DMARD with prednisolone may help slow radiographic progression and extend remission. This 2-year, multicenter Swedish study compared prednisolone 7.5 mg/day added to a DMARD (n = 119) with a DMARD only (n = 131) in patients with early RA. Patients were eligible if they had been diagnosed with RA (1987 ACR criteria) in the past year and had been started by their treating rheumatologist on their first DMARD. The choice of DMARD had been left to the patient’s primary rheumatologist and included MTX (mean dose 10 mg/week) or sulfasalazine (2 g/day). The combination group had significantly less radiographic progression than the monotherapy group (25.9 percent vs. 39.3 percent based on modified Sharp/van der Heijde score; P = 0.033). Additionally, remission was higher in the combination group (DAS 28 < 2.6, 55.5 percent vs. 43.8 percent; P = 0.0005). This study can be considered an effectiveness trial based on design criteria.26 However, the results should be interpreted cautiously, given the open-label design and potential for measurement bias.

#### Two synthetic DMARDs plus corticosteroid vs. synthetic DMARD

One multicenter RCT, known as COBRA (Combinatietherapie Bij Reumatoide Artritis), assessed differences in efficacy between a combination of step-down prednisolone, MTX, and sulfasalazine and sulfasalazine only.39 The investigators randomized 155 Dutch patients with early RA for 56 weeks. Patients with active RA were included if they had had symptoms for fewer than 2 years and had not used DMARDs in the past. Patients were then followed indefinitely in an open-label prospective cohort (5-year follow-up data reported).40 Combination therapy included a stepped-down prednisolone treatment (60 mg/day tapered over 28 weeks), MTX (7.5 mg/week stopped after 40 weeks), and sulfasalazine (2 g/day). Mean duration of RA was 4 months. The authors applied a pooled index, which yielded a weighted change score of five disease activity measures: tender joint count, grip strength, erythrocyte sedimentation rate (ESR), assessor’s global assessment by visual analog scale (VAS), and the McMaster Toronto arthritis questionnaire (MACTAR) (score range not given). At 28 weeks, patients on combination therapy had an improved change score in this index (mean change 1.4 vs. 0.8; P < 0.0001). At 52 weeks, however, the change results on the pooled index were no longer significant (mean change 1.1 vs. 0.9; P = 0.20). In terms of radiographic progression, patients on combination therapy had statistically significantly less progression than the monotherapy patients on the modified Sharp/van der Heijde score at 28 weeks (1 vs. 4; P < 0.0001), 56 weeks (2 vs. 6; P < 0.004), and 80 weeks (4 vs. 12; P < 0.01). Over 5 years, the modified Sharp/van der Heijde change score per year was lower for combination therapy than for monotherapy (5.6 vs. 8.6; P = 0.001).40

#### Three synthetic DMARDs plus corticosteroid vs. synthetic DMARDs

The FIN-RACo (Finnish Rheumatoid Arthritis Combination Therapy) RCT assessed the efficacy of a complex combination of prednisolone (5 to 10 mg/day), MTX (7.5 to 10 mg/week), sulfasalazine (2 g/day), and hydroxychloroquine (300 mg/day) against that of monotherapy with a DMARD with or without prednisolone.43 The investigators randomized 199 patients with early RA to either combination therapy or monotherapy. Patients on monotherapy were initially started on sulfasalazine (2 to 3 g/day) but could be changed to MTX (7.5 to 15 mg/week), then changed to a third DMARD if needed (azathioprine, auranofin, hydroxychloroquine, injectable gold, penicillamine, or podophyllotoxin). If patients reached remission in the first year, they could be tapered and prednisolone and MTX could be discontinued at 9 months and 18 months, respectively. Adding prednisolone (up to 10 mg/day) in the monotherapy group was left up to the treating physician and allowed in patients with continuously active disease. After 2 years, remission (judged by the authors using modified ACR 20) was higher in the combination group (37.9 percent vs. 18.4 percent; P = 0.011); the proportions achieving ACR 50 response criteria were higher but did not reach statistical significance (71 percent vs. 58 percent; P = 0.058). Larsen Scale radiographic scores had also improved at 2 years (Larsen Scale score increase 2 vs. 10; P = 0.002). Subsequently, patients in this trial were followed for 5 years.44 Those in the monotherapy group were allowed to be treated with combinations of DMARDs if their response was insufficient. At 5 years, the median Larsen Scale score remained lower in the combination therapy group (11 vs. 24; P = 0.001). This trial can be considered an effectiveness trial given the flexibility of dosing in an effort to follow clinical practice.

##### Other complex combination strategies

One good-quality RCT examined four different treatment strategies over 12 months.42 The BeSt Study (Dutch acronym for Behandel Strategieen, “treatment strategies”) randomized 508 patients with early RA to one of four groups: (1) sequential DMARD, starting with MTX (15 mg/week), (2) step-up combination therapy with MTX (15 to 30 mg/week) followed by sulfasalazine (2 g/day), hydroxychloroquine, and prednisone, (3) initial combination therapy of MTX, sulfasalazine, and tapered high-dose prednisone 60 mg/day to 7.5 mg/day in 7 weeks, and (4) initial combination therapy with MTX 25 to 30 mg/week and infliximab 3 mg/kg every 8 weeks (dose titrated up to 10 mg/kg dependent upon DAS44 > 2.4). This design called for frequent changes in treatment strategy; the DAS (i.e., DAS in 44 joints) was calculated every 3 months and if it was greater than 2.4, the therapeutic strategies were adjusted. At 12 months, more patients in group 3 (MTX, sulfasalazine, tapered high-dose prednisone) and in group 4 (MTX with infliximab) reached a DAS of 2.4 or less. Respectively, these proportions were 53 percent, 64 percent, 71 percent, and 74 percent (P = 0.004 for group 1 vs. group 3; P = 0.001 for group 1 vs. group 4; P = NS for other comparisons). Additionally, the median change in modified Sharp/van der Heijde score was lower for groups 3 and 4 than for groups 1 and 2 (2.0, 2.5, 1.0, and 0.5, respectively; P = 0.003 for group 1 vs. group 3; P < 0.001 for group 1 vs. group 4; P = 0.007 for group 2 vs. group 3; P < 0.001 for group 2 vs. group 4).

#### Biologic DMARDs vs. biologic DMARDs

We did not identify any head-to-head RCTs. The head-to-head evidence was limited to one nonrandomized, open-label effectiveness trial50 and two fair-quality prospective cohort studies;52,53 all compared etanercept with infliximab. All three studies were primary care based with minimal exclusion criteria, enrolling patients who were starting treatments with biologic DMARDs. Mean disease durations ranged from 7.7 years to 14.7 years, indicating that most patients suffered from advanced RA; the proportion of patients with early RA in these studies remains unclear. One study was conducted in the United States;53 the other two were carried out in Sweden.50,52 In addition to these studies evaluating biologic monotherapies, an RCT compared etanercept monotherapy to a combination treatment of etanercept and anakinra.59

The nonrandomized, open-label effectiveness study (N = 369) assessed the effectiveness and safety of etanercept (25 mg twice weekly), infliximab (3 mg/kg or higher every 8 weeks), and leflunomide (20 mg/day).50 Study duration was 12 months. Comparisons of etanercept and infliximab with the leflunomide arm are reported in the section below comparing synthetic DMARDs with biologic DMARDs. Etanercept had significantly greater ACR 20 response rates at 3 months (P < 0.02; data NR) and 6 months (P < 0.05; data NR) and greater ACR 50 response rates at 3 months (P < 0.005; data NR) than infliximab. The authors attributed these differences partly to a high need of dose adjustments (57 percent) in the infliximab group during the first months of the study. No significant differences between the therapy groups could be detected after 6 months.

One prospective cohort study (N = 949) provided similar results. Etanercept treatments led to greater response rates than infliximab during the first months of treatment, but no differences were noted thereafter for up to 36 months.52 The authors of this study created an index called the LUNDEX (an index of drug efficacy in clinical practice developed at Lund University in Sweden, calculated as the proportion of starters still on the drug at time T times the proportion responding at time T), which takes adherence and efficacy together into consideration. Patients on etanercept achieved higher LUNDEX scores than patients on infliximab, which reflected a significantly lower level of adherence of patients on infliximab compared with those on etanercept (data NR; P < 0.001).

Findings from the U.S. prospective cohort study, which was based on the RADIUS (Rheumatoid Arthritis DMARD Intervention and Utilization Study) program and funded by the maker of etanercept, reported similar results.53 Etanercept-treated patients had greater response rates than infliximab-treated patients on the modified ACR 20 (mACR 20, which omits ESR and C-reactive protein [CRP] values because they are infrequently measured in clinical practice); percentage responses were 43 percent for etanercept plus MTX, 41 percent for etanercept monotherapy, 35 percent for infliximab plus MTX, and 26 percent for infliximab monotherapy (P = NR).

A well-conducted retrospective cohort study did not meet our eligibility criteria, but we present its findings here because it was the only study that examined radiographic progression for patients treated with etanercept or infliximab.70 This population-based study determined erosion progression and joint space narrowing on 372 Swiss patients who were monitored through the Swiss Clinical Quality Management System. Combination therapies of infliximab and synthetic DMARDs or etanercept and synthetic DMARDs did not present statistically significant differences in progression of erosion (Ratingen score; data NR) after a mean followup of 1.7 years. The combination of infliximab and synthetic DMARDs led, however, to statistically significantly lower joint space narrowing than etanercept and synthetic DMARDs (data NR). This difference was not obvious when the analysis was limited to MTX as the concomitant DMARD. The combination of infliximab and MTX was statistically significantly more efficacious on all outcome measures than etanercept monotherapy (data NR).

##### Indirect head-to-head comparisons of biologic DMARDs

Multiple placebo-controlled RCTs and meta-analyses20,71 provide evidence on the general efficacy of abatacept,72–76 adalimumab,77–83 anakinra,48,84–89 etanercept,63–65,90–97 infliximab,90,98–107 and rituximab.61,108 Most of these studies were conducted in patients who had failed synthetic DMARD treatment.

Using information from these placebo-controlled trials, four research groups did meta-analyses to produce adjusted indirect comparisons of biologic DMARDs.21,48,49,51 The underlying assumption for adjusted indirect comparisons to be valid is that the relative efficacy of an intervention is consistent across included studies.109 In the most recent analysis, findings suggested that efficacy does not differ substantially for adalimumab, etanercept, and infliximab (Figures 2 and 3).49 However, given the wide confidence intervals, clinically significant differences cannot be excluded with certainty.

Figure 2

Adjusted indirect comparisons of biologic DMARDs for ACR 20 response rates

Adapted from Gartlehner et al., 2006^49^

Figure 3

Adjusted indirect comparisons of biologic DMARDs for ACR 50 response rates

Adapted from Gartlehner et al., 2006^49^

Compared with point estimates for anakinra, point estimates favored adalimumab, etanercept, and infliximab (Figures 2 and 3).49 Not all differences reached statistical significance in adjusted indirect comparisons, which is likely attributable to a lack of power. Adjusted indirect comparisons of anti-TNF drugs as a class with anakinra showed a statistically significantly greater efficacy of the anti-TNF drugs on ACR 20 but not on ACR 50. Figures 2 and 3 summarize results of adjusted indirect comparisons of ACR 20 and ACR 50 responses.49

These findings are consistent with a good-quality German retrospective cohort study based on the RABBIT (German acronym for Rheumatoid Arthritis – Observation of Biologic Therapy) database, which reports higher discontinuation rates because of lack of efficacy for patients on anakinra than for patients on either etanercept or infliximab after 12 months of treatment (30 percent vs. 20 percent vs. 20 percent; P = NR).67

No indirect comparisons were available of abatacept and rituximab with other biologic DMARDs.

#### Biologic DMARDs vs. corticosteroids

One RCT, which did not meet our eligibility criteria because of its small sample size (N = 28), compared the efficacy of infliximab (3 mg/kg at weeks 0, 2, and 6) and pulse methylprednisolone (1 g/single infusion).110 We briefly summarize its findings here because it was the only study comparing these two treatments. Significantly higher proportions of patients treated with infliximab than with pulse methylprednisolone met ACR 20 criteria (67 percent vs. 8 percent; P < 0.05) and ACR 50 criteria (44 percent vs. 0 percent; P < 0.05). No quality-of-life measure improved with pulse methylprednisolone treatment.

#### Biologic DMARDs vs. synthetic DMARDs

Three RCTs, a nonrandomized trial, and a prospective cohort study determined the comparative efficacy and safety of various biologic and synthetic DMARDs. The RCTs compared adalimumab57 and etanercept54,63 with MTX; the nonrandomized trial compared etanercept and infliximab with leflunomide;50 and the cohort study assessed differences in class effects.58 No evidence exists on abatacept, anakinra, and rituximab or on synthetic DMARDs other than MTX and leflunomide.

##### Biologic DMARDs as a class vs. synthetic DMARDs as a class

A prospective cohort study examined differences in clinical and functional remission between biologics as a class (adalimumab, anakinra, etanercept, infliximab; n = 818) and DMARDs as a class (n = 265) in patients who had failed two previous DMARD treatments.58 This study was population-based and part of RABBIT, a German long-term, prospective cohort study of RA patients who had required a change in therapy in daily rheumatologic care. Patients on biologics were younger and had a significantly more active disease at baseline. In a multivariate logistic regression, adjusting for baseline confounders, the investigators determined that patients on biologics had a statistically significantly greater chance of remission (DAS < 2.6) after 12 months of treatment (OR, 1.95; 95% CI, 1.20–3.19). Likewise, patients treated with biologics had an almost four times higher likelihood of achieving functional independence than patients treated with synthetic DMARDs (OR, 3.88; 95% CI, 1.71–8.79). Nevertheless, both groups had a substantial risk of relapse during the treatment period. Approximately one-half of the patients who were in remission at 6 months achieved a sustained remission until 12 months (biologics, 55 percent; synthetic DMARDs, 58 percent).

##### Adalimumab vs. MTX

The PREMIER study was conducted in MTX-naive patients with early (disease duration < 3 years), aggressive RA.57 This multinational study randomized 799 patients with early RA to a combination of adalimumab (40 mg every other week) and MTX (20 mg/week), adalimumab monotherapy (40 mg every other week), or MTX monotherapy (20 mg/week). Two treatment arms of this 2-year study assessed differences in the efficacy of adalimumab monotherapy (40 mg every other week) and MTX monotherapy (20 mg/week). After 2 years, the proportion of patients who met ACR 50 criteria was lower for those on adalimumab than for those on MTX monotherapy (37 percent vs. 43 percent; P = NR). Radiographic progression, by contrast, was statistically significantly lower in patients treated with adalimumab than with MTX (5.5 vs. 10.4 Sharp units; P < 0.001). No difference was apparent in clinical remission (DAS 28 < 2.6) between the two treatment groups (both 25 percent); discontinuation rates because of lack of efficacy were similar in the adalimumab and MTX groups (19.0 percent vs. 17.9 percent; P = NR). We report on results of the other comparisons of the PREMIER study in the respective sections (below) on Biologic DMARDs plus synthetic DMARDs vs. biologic DMARDs and Biologic DMARDs plus synthetic DMARDs vs. synthetic DMARDs.

##### Etanercept vs. MTX

Two trials (in six publications) compared etanercept (10 mg or 25 mg twice weekly) with MTX (20 mg/week) over 52 weeks.54–56,63–65 The ERA (Early Rheumatoid Arthritis) study (N = 632) was conducted in patients with early RA who were MTX naive.54–56 The TEMPO (Trial of Etanercept and Methotrexate with Radiographic Patient Outcomes) trial63–65 randomized 686 patients to etanercept plus MTX (25 mg twice weekly plus up to 20 mg/week), etanercept monotherapy (25 mg twice weekly), and MTX monotherapy (up to 20 mg/week).63–65 Patients had active RA and had failed at least one DMARD other than MTX. About 57 percent of the study population was MTX naive. Patients who had either failed prior MTX treatment or experienced toxic effects were excluded from this study.

Both studies failed to show statistically significant differences between etanercept and MTX in clinical and health outcome measures (SF-36, the Health Assessment Questionnaire [HAQ], the Arthritis-Specific Health Index [ASHI]), and ACR 20/50/70 response rates at study endpoints (52 weeks). By contrast, radiographic outcomes were significantly better in patients on etanercept than in those on MTX. For example, in the ERA trial, 72 percent of patients on etanercept and 60 percent on MTX had no radiographic progression of disease (P = 0.007). Improved radiographic outcomes were maintained during an open-label extension of the ERA study to 2 years55 and 5 years.56

##### Etanercept or infliximab vs. leflunomide

No RCT compared biologic DMARDs to leflunomide. The only head-to-head evidence came from a nonrandomized, open-label study (N = 369) that accessed the efficacy and safety of etanercept (25 mg twice weekly), infliximab (3 mg/kg or higher every 8 weeks), and leflunomide (20 mg/day).50 This study has been described in greater detail in the section (above) on Biologic DMARDs vs. biologic DMARDs. At 3 months and 6 months, patients on etanercept had significantly higher ACR 20 and ACR 50 response rates than those on leflunomide (data NR; P < 0.05). Patients on infliximab achieved higher ACR 20 and ACR 50 response rates at 3 months (data NR; P < 0.05). The authors did not report 12-month data. Both etanercept and infliximab led to significant reductions in prednisolone dosage; by contrast, no reduction with leflunomide was seen. These findings must be viewed cautiously. Baseline characteristics of patients differed substantially between the leflunomide group and the biologic groups. Leflunomide patients were older and had significantly more joint damage than patients on etanercept or infliximab. Such differences can potentially confound results, introducing bias that would support differences in results among these treatment groups.

#### Biologic combination strategies: Biologic DMARD plus biologic DMARD vs. biologic DMARD

A 24-week RCT did not detect any synergistic effects of a combination treatment of etanercept (25 mg/week or 50 mg/week) and anakinra (100 mg/day) compared with etanercept monotherapy.59 Overall, 242 patients who were on stable doses of MTX treatment were enrolled. At endpoint, combination treatment did not lead to greater efficacy than etanercept only. Furthermore, the frequency of serious adverse events was substantially higher in the combination groups (14.8 percent for 50 mg etanercept plus anakinra, 4.9 percent for 25 mg etanercept plus anakinra, and 2.5 percent for etanercept only; P = NR). Likewise, withdrawals because of adverse events were higher in the combination groups than in the etanercept group (8.6 percent vs. 7.4 percent; P = NR).

#### Biologic DMARD plus synthetic DMARD vs. biologic DMARD

The majority of trials assessed a combination of a biologic DMARD and MTX against a monotherapy of the respective biologic DMARD.53,57,61–63,66 Only one trial used sulfasalazine as a synthetic DMARD in combination with a biologic DMARD.60 No evidence is available on combination treatments of abatacept or anakinra.

##### Adalimumab plus MTX vs. adalimumab

The PREMIER study was conducted in MTX-naive patients with early (disease duration < 3 years), aggressive RA.57 Details of this study are reported above in Biologic DMARDs vs. synthetic DMARDs. After 2 years, significantly more patients on the combination therapy exhibited responses on ACR 50 than patients on adalimumab monotherapy (59 percent vs. 37 percent; P < 0.001); in addition, they had statistically significantly less progression on a modified Sharp/van der Heijde score (1.9 vs. 5.5 Sharp units; P < 0.001). After 2 years of treatment, 49 percent of patients on the combination therapy and 23 percent on adalimumab monotherapy achieved remission (DAS 28 < 2.6; P < 0.001). Discontinuation rates because of lack of efficacy were lower in the combination group than in the monotherapy group (4.2 percent vs. 19.0 percent; P = NR). We report on results of the other comparisons of the PREMIER study in the respective sections on Biologic DMARDs vs. synthetic DMARDs and Biologic DMARDs plus synthetic DMARDs vs. synthetic DMARDs.

##### Etanercept plus MTX vs. etanercept

Two RCTs (in four publications)63–66 and two prospective cohort studies53,62 assessed differences in efficacy between an etanercept-MTX combination and etanercept monotherapy in patients with active, DMARD-resistant disease. Findings of these studies consistently supported greater efficacy for the combination therapy than for the etanercept monotherapy.

The TEMPO trial (described above in Biologic DMARDs vs. synthetic DMARDs) enrolled a mixed population of MTX-naive patients (about 57 percent) and patients who had been on prior MTX treatment (about 43 percent). Patients who had either failed prior MTX treatment or experienced toxic effects were excluded from this study. Results of the etanercept-MTX combination (25 mg twice weekly plus up to 20 mg/week) and the etanercept monotherapy (25 mg twice weekly) arms showed that the combination treatment was significantly more efficacious than etanercept alone. After 52 weeks, 69 percent in the combination group and 48 percent in the etanercept group achieved ACR 50 response criteria (P < 0.0001). Likewise, statistically significantly higher proportions of patients in the combination than in the monotherapy group met ACR 20 and ACR 70 response criteria. The proportion of patients achieving remission (DAS < 1.6) was 35 percent in the combination group and 16 percent in the monotherapy group (P < 0.0001). In addition, the combination regimen led to significantly better radiographic outcomes (changes in total Sharp score: −0.54 vs. 0.52; P < 0.0001) than the etanercept monotherapy.64

A German retrospective cohort study based on the RABBIT database did not find differences in discontinuation rates because of lack of efficacy between patients on etanercept monotherapy and those on an etanercept-MTX combination (20 percent vs. 17 percent; P = NR).67

Results of year 2 of the TEMPO trial confirmed the long-term sustainability of findings from efficacy RCTs.65 ACR response rates, DAS remission rates, quality-of-life measures, and radiographic progression were statistically significantly better in the combination group than in the etanercept monotherapy group. Attrition was 39 percent after 2 years and could compromise the internal validity of the long-term results.

The other three studies included a 16-week, open-label RCT (N = 315),66 a 12-month prospective cohort study,53 and a 6-month prospective cohort study.62 Their results were generally consistent with findings from the TEMPO trial. Both prospective cohort studies were population-based, one in the United States53 and the other in the United Kingdom,62 and both have a high generalizabilty.

The UK study also compared the effectiveness of the etanercept-MTX combination and a combination of etanercept and other DMARDs (leflunomide, azathioprine, sulfasalazine, hydroxychloroquine, cyclosporine A, penicillamine, gold, minocycline) as a class.62 After adjusting for potential confounders, the investigators reported statistically significantly higher response rates for MTX as a cotherapy than for other DMARDs (OR, 1.66; 95% CI, 1.14–2.42).

##### Etanercept plus sulfasalazine vs. etanercept

A 24-week RCT assessed the comparative efficacy of etanercept and sulfasalazine combination therapy (respectively, 25 mg twice weekly plus 2, 2.5, or 3 g/day), etanercept monotherapy (25 mg twice weekly), and sulfasalazine monotherapy (2, 2.5, or 3 g/day) in patients with active RA who had failed previous sulfasalazine treatment.60 Because sulfasalazine monotherapy resembles a placebo treatment (patients had to have failed it to be eligible), we focus on results from the combination (n = 101) and etanercept monotherapy (n = 103) arms. After 24 weeks, both groups had similar clinical responses on multiple outcome measures (ACR 20/50/70, DAS 28). On ACR 20, the primary efficacy variable, 74 percent of patients in both groups met the relevant response criteria. Likewise, results on patient-reported measures of quality of life (HAQ, EuroQOL, general health VAS) were similar for patients on the combination and monotherapy interventions.

##### Infliximab plus MTX vs. infliximab

No RCT examined the comparative efficacy and effectiveness of a combination of infliximab and MTX against infliximab monotherapy in patients with RA. The only comparative evidence comprises one U.S. and one U.K. prospective cohort study (already described).53,62 Both studies indicated that European League Against Rheumatism (EULAR) and modified ACR response rates were better for patients in the studies’ infliximab combination groups. Remission rates, however, were similar in both studies for the two regimens. At 6 months, U.K. patients in the combination group had higher EULAR response rates than those in the monotherapy group (OR, 1.35; 95% CI, 0.92–2.00).62 At 12 months, mACR 20 responses were similar for U.S. patients in the combination and the monotherapy groups (OR, 0.96; 95% CI, 0.76–1.21; P = 0.72).53

A German retrospective cohort study assessing discontinuation rates in clinical practice reported findings similar to those noted above. Discontinuation rates because of lack of efficacy were higher among patients on an infliximab monotherapy than among with those on an infliximab-MTX combination regimen (45 percent vs. 18 percent; P = NR).67 Overall discontinuation rates, however, were statistically significantly higher in the monotherapy than in the combination group (56 percent vs. 34 percent; hazard ratio, 1.9; 95% CI, 1.1–3.1).

##### Rituximab plus MTX vs. rituximab

One RCT enrolled patients with highly active, longstanding, DMARD-resistant RA to compare the efficacy of rituximab and MTX (1,000 mg on day 1 and day 15 plus MTX 10 mg or more/week), rituximab monotherapy (1,000 mg on day 1 and day 15), rituximab and cyclophosphamide, and MTX monotherapy.61 Because cyclophosphamide is not a drug of interest for this report and because MTX monotherapy resembles a placebo treatment (patients had to have failed MTX treatment to be eligible), we focus on results of the rituximab-MTX combination (n = 40) and the rituximab monotherapy (n = 40) arms. After 24 weeks, patients on the combination intervention experienced changes in DAS outcomes similar to those for patients on rituximab monotherapy (−2.6 vs. −2.2; P = NR). Similar proportions of patients in both treatment groups achieved a good or moderate EULAR response (83 percent vs. 85 percent; P = NR). However, the proportions of patients meeting all three ACR response criteria were higher for patients treated with the rituximab combination treatment than for patients on rituximab monotherapy (ACR 20, 73 percent vs. 65 percent; ACR 50, 43 percent vs. 33 percent; ACR 70, 23 percent vs. 15 percent; P = NR). Higher ACR response rates for the combination treatment were maintained during a 48-week, double-blinded followup. After 48 weeks, 35 percent of patients on the combination regimen and 15 percent of patients on rituximab monotherapy had an ACR 50 response.

#### Biologic combination strategies: Biologic DMARD plus synthetic DMARD vs. synthetic DMARD

The evidence is limited to two studies comparing a combination regimen of adalimumab plus MTX57 or a combination regimen of infliximab plus MTX68 with MTX monotherapy. Both studies were conducted in patients with early, aggressive RA.

##### Adalimumab plus MTX vs. MTX

The PREMIER study was conducted in MTX-naive patients with early (disease duration < 3 years), aggressive RA57 (see Biologic DMARDs plus synthetic DMARDs vs. biologic DMARDs). Two treatment arms of this 2-year study assessed differences in efficacy between a combination of adalimumab (40 mg every other week) and MTX (20 mg/week) and MTX monotherapy (20 mg/week).57 After 2 years, statistically significantly more patients on the combination therapy met ACR 50 response criteria than patients on MTX monotherapy (59 percent vs. 43 percent; P < 0.001); in addition, they had statistically significantly less progression on the modified SHS score (changes in total Sharp score: 5.5 vs. 10.4; P < 0.001). After 2 years of treatment, 49 percent of patients on the combination therapy and 25 percent on MTX monotherapy achieved remission (DAS 28 < 2.6; P < 0.001). Discontinuation rates because of lack of efficacy were lower in the combination than in the MTX group (4.2 percent vs. 17.9 percent; P = NR).

##### Infliximab plus MTX vs. MTX

The ASPIRE (Active-controlled Study of Patients Receiving Infliximab for the Treatment of Rheumatoid Arthritis of Early Onset) trial enrolled 1,049 patients with early RA (disease duration < 3 years) who were MTX-naive.68 This study compared the benefits of initiating treatment with MTX (20 mg/week) alone or of using two different combinations of MTX and infliximab (3 mg/kg or 6 mg/kg) over 54 weeks. At endpoint, patients in the combination groups had significantly higher ACR-N (ACR-N is the percentage of ACR improvement from baseline to endpoint) scores than patients on MTX monotherapy (38.9 percent [3 mg infliximab plus MTX] vs. 46.7 percent [6 mg infliximab plus MTX] vs. 26.4 percent [MTX]; P < 0.001); remission rates were 31 percent, 21 percent, and 15 percent, respectively. In addition, HAQ and SF-36 scores improved significantly more in the combination groups than in the MTX group. Fewer patients in the combination groups than in the MTX monotherapy group withdrew because of lack of efficacy (1.9 percent vs. 3.3 percent vs. 9.6 percent; P = NR). More patients in the combination groups than in the placebo group had serious adverse events (14 percent vs. 11 percent; P = NR) and serious infections (5.6 percent [3 mg/kg infliximab] vs. 5.0 percent [6 mg/kg infliximab] vs. 2.1 percent [MTX]; P = 0.02 and P = 0.04). Patients on the combination treatment also had a higher probability of maintaining their employability than did those on MTX alone.69

### Psoriatic Arthritis: Overview

Six RCTs and two systematic reviews examined symptom response, radiographic joint damage, and remission for psoriatic arthritis (PsA). Details are found in Evidence Tables 3 and 4 in Appendix E. Table 12 provides information on symptom response and quality ratings; Table 13 provides information on radiographic outcomes. The main drug classes examined include corticosteroids, synthetic DMARDs, biologic DMARDs, and combined strategies.

Table 12

Study characteristics, symptom response, and quality ratings of studies in adults with psoriatic arthritis

Study | Study Design N Duration | Study Population | Comparison (dose) | Results of Primary Outcome Measure | Quality Rating
Synthetic DMARDs vs. Placebo
Jones et al., 2000^111^ | Systematic review and meta-analysis 1,022 | Active PsA; concomitant MTX NR | MTX vs. placebo SSZ vs. placebo | Change in pooled index: MTX 0.65 units (95% CI, 0.00–1.30) SSZ 0.38 units (95% CI, 0.21–0.54) | Good
Kaltwasser et al., 2004^112,113^ | RCT 190 24 weeks | Active PsA; failed at least one DMARD; concomitant MTX 0% | LEF (100 mg/day 3 days then 20 mg/day) vs. placebo | PsARC at week 24: LEF 58.9% vs. placebo 29.7% (P < 0.0001) | Fair
Biologic DMARDs vs. Placebo
Mease et al., 2005 ADEPT Trial114 | RCT 313 24 weeks | Active PsA; failed at least one DMARD; concomitant MTX 51% | ADA (40 mg every other week) vs. placebo | ACR 20 at week 24: ADA 57% vs. placebo 15% (P < 0.001) | Fair
Antoni et al., 2005 IMPACT Study115,116 | RCT 104 50 weeks (16 blinded, 34 open-label) | Active PsA; failed at least one DMARD; concomitant MTX 56% | INF (5 mg/kg at weeks 0, 2, 6, 14 then every 8 weeks) vs. placebo 71% received a concomitant DMARD | ACR 20 at week 16: INF 65.4% vs. placebo 9.6% (P < 0.001) | Fair
Antoni et al., 2005 IMPACT 2 Study117,118 | RCT 200 14 weeks (early escape at 16 weeks) | Active PsA; failed at least one DMARD; concomitant MTX 46% | INF (5 mg/kg at weeks 0, 2, 6, 14, 22) vs. placebo 46% received concomitant MTX | ACR 20 at week 14: INF 58% vs. placebo 11% (P < 0.001) | Fair
Mease et al., 2000^119^ | RCT 60 12 weeks | Active PsA; failed at least one DMARD; concomitant MTX use 47% | ETA (25 mg twice a week) vs. placebo | PsARC at week 12: ETA 87% vs. placebo 23% (P < 0.0001) | Fair
Mease et al., 2004^120^ | RCT 205 24 weeks (with additional 48 weeks open- label) | Active PsA; failed at least one DMARD; concomitant MTX 47% | ETA (25 mg twice a week) vs. placebo | ACR 20 at week 24: ETA 59% vs. placebo 15% (P < 0.001) | Fair
Woolacott et al., 2006^121^ | Systematic review and meta-analysis 369 | Adults with PsA; concomitant MTX 46% to 56% | ETA (25 mg twice a week) vs. placebo (two studies) INF (5 mg/kg) vs. placebo (one study) | ACR 20 at week 12: ETA 65% (RR, 4.19 [95% CI, 2.74–6.42] ACR 20 at week 16: INF 65% (RR, 6.80; 95% CI, 2.89–16.01) | Good

ACR 20, American College of Rheumatology 20 percent improvement from baseline to endpoint; ADA, adalimumab; ADEPT, Adalimumab Effectiveness in Psoriatic Arthritis Trial; CI, confidence interval; DMARD, disease-modifying antirheumatic drug; ETA, etanercept; IMPACT, Infliximab Multinational Psoriatic Arthritis Controlled Trial; INF, infliximab; LEF, leflunomide; mg, milligram; MTX, methotrexate; NR, not reported; PsA, psoriatic arthritis; PsARC, Psoriatic Arthritis Response Scale; RCT, randomized controlled trial; RR, relative risk; SSZ, sulfasalazine; vs., versus.

Table 13

Study characteristics and radiographic joint damage in adults with psoriatic arthritis

Study | Study Design N Duration | Population with Early PsA (< 3 years) | Comparison (dose) | Radiographic Outcomes
Biologic DMARDs vs. Placebo
Mease et al., 2005 ADEPT Trial114 | RCT 313 24 weeks | No | ADA (40 mg every other week) vs. placebo | Mean change in the modified total Sharp score at week 24: ADA −0.1 vs. placebo 1.0 (P < 0.001) Erosion scores (mean change): ADA 0.0 vs. placebo 0.6 Joint space narrowing scores (mean change): ADA −0.2 vs. placebo 0.4 (P < 0.001 for both)
Mease et al., 2004^122^ | RCT 205 72 weeks (24 blinded, 48 open-label) | No | ETA (25 mg twice a week) vs. placebo | Mean annualized rate of change over 1 year of treatment in modified Sharp score: ETA −0.03 unit vs. placebo 1.00 unit (P = 0.0001)

ADA, adalimumab; ADEPT, Adalimumab Effectiveness in Psoriatic Arthritis Trial; DMARD, disease-modifying antirheumatic drug; ETA, etanercept; mg, milligram; PsA, psoriatic arthritis.

### Psoriatic Arthritis: Key Points

We did not find any head-to-head comparison for any of the drugs used to treat PsA. One systematic review found that, compared with placebo, parenteral high-dose MTX and sulfasalazine improved patient outcomes.111 The strength of evidence is low.

Leflunomide patients had higher response rates and quality-of-life outcomes than those in the placebo arm.112,113 The strength of evidence is moderate.

The use of three biologics—adalimumab, etanercept, and infliximab—led to better outcomes than did placebo.114–120,122 The strength of evidence is moderate.

### Psoriatic Arthritis: Detailed Analysis

Because of the lack of head-to-head trials, we reviewed placebo-controlled trials. We have summarized evidence on the general efficacy of synthetic and biologic DMARDs in the treatment of PsA. This, however, does not provide evidence on the comparative efficacy and tolerability of treatments for PsA.

#### Corticosteroids

We did not identify any studies that examined the use of corticosteroids in the treatment of PsA.

#### Synthetic DMARDs

One systematic review examined the efficacy of synthetic DMARDs used in placebo-controlled trials.111 The investigators used data from 13 RCTs that included 1,022 adults with PsA in a meta-analysis that focused on comparisons of sulfasalazine, auranofin, etretinate, fumaric acid, intramuscular injection of gold, azathioprine, efamol marine, and MTX with placebo. Two drugs (MTX and sulfasalazine) are of interest for our report. The primary outcome measure included individual component variables validated by the Outcome Measures in Rheumatology Clinical Trials (OMERACT) to create a pooled index; components used include acute phase reactants, disability, pain, patient global assessment, physician global assessment, swollen joint count, tender joint count, and radiographic changes of joints in any trial of 1 year or longer. The primary outcome was change in a pooled disease index.

##### MTX

In a systematic review, one study compared MTX with placebo; parenteral high-dose MTX (weekly dose of 7.5 mg to 15 mg) showed an overall improvement in the OMERACT index of 0.65 units (95% CI, 0.00–1.30), although the sample for this study was small (N = 37).

##### Sulfasalazine

The investigators pooled six trials involving comparisons of sulfasalazine (average dose of 2 g/day to 3 g/day) with placebo (N = 564). Sulfasalazine showed an improvement in the pooled index of 0.38 units (95% CI, 0.21–0.54).111

##### Leflunomide

One trial (two publications) evaluated the efficacy of leflunomide against placebo in 190 patients over 24 weeks;112,113 PsA was defined as having at least three swollen joints and three tender or painful joints and psoriasis over at least 3 percent of the body surface area. In this study, almost 50 percent of the patients were DMARD naive. Patients who were not DMARD naive were required to discontinue all synthetic DMARDs as well as biologic agents and investigational drugs 28 days before baseline.

The leflunomide group saw significantly greater response rates on a modified ACR 20 (36.3 percent) than the placebo group (20 percent; P = 0.014). The PsARC (Psoriatic Arthritis Response Criteria) is a composite measure requiring improvement in two factors (at least one being a joint score) and worsening in none among the following four factors: patient and physician global assessments (improvement defined as decrease by 1 unit; worsening defined as increase by ≥ 1 unit); and tender and swollen joint scores (the sums of all joints scored; improvement defined as decrease by ≥ 30 percent; worsening defined as increase by ≥ 30 percent). The PsARC was achieved in 58.9 percent of those on leflunomide and 29.7 percent of those on placebo (P = 0.0001). PASI 75 (Psoriasis Area and Severity Index) is a composite score (range 0 to 72) used to evaluate the severity of psoriatic lesions by assessing the extent of skin involvement, erythema, plaque thickness, and degree of scaling; the PASI 75 indicates a 75 percent improvement in psoriasis activity from baseline. In this study, 17.4 percent of the leflunomide group and 7.8 percent of the placebo group reached the PASI threshold (P = 0.048).

#### Biologic DMARDs

Five trials (eight articles) and one systematic review examined the efficacy of biologics against placebo in treating patients with PsA.114–122 One trial was of adalimumab, two of etanercept, and two of infliximab. All trials used a synthetic DMARD, usually MTX, as a base treatment in all patients. The systematic review examined etanercept and infliximab vs. placebo.121 All showed that the use of biologics led to significantly better outcomes than placebo.

##### Adalimumab

One trial examined the use of adalimumab (40 mg every other week) in 313 patients suffering from moderate to severe PsA (defined as having at least three swollen joints and three tender or painful joints) who had an inadequate response or intolerance to nonsteroidal anti-inflammatory drug (NSAID) therapy.114 Patients were allowed to continue current MTX therapy as long as the dose had been stable for 4 weeks. The double-blinded phase of the study lasted 24 weeks, but patients who failed to achieve at least a 20 percent decrease in both swollen and tender joint counts on two consecutive visits could receive rescue therapy with corticosteroids or synthetic DMARDs. A significantly higher percentage of the adalimumab group met ACR 20/50/70 response criteria than the placebo group (all P < 0.001). According to the PsARC, 60 percent of the adalimumab group and 23 percent of the placebo group responded (P = NR). PASI 75 was achieved by 59 percent of the adalimumab group and 1 percent of the placebo group (P < 0.001). At 24 weeks, the changes in the modified Sharp score, erosion score, and joint space narrowing score were significantly less in adalimumab-treated than placebo-treated patients (P = 0.001).

##### Etanercept

Two studies examined the efficacy of etanercept (25 mg twice weekly by subcutaneous injections) in 265 patients with active PsA who were not adequately responding to conventional DMARD therapies.119,120 In both studies, patients were allowed to continue MTX therapy as long as the dose had been stable for 4 weeks before entry into the study. One study lasted 12 weeks (N = 60);119 the other (N = 205) was double-blinded for 24 weeks.120 In both studies, the proportions of patients on etanercept meeting ACR 20 response criteria were significantly higher than those for patients on placebo. In the 12-week study, 87 percent of patients on etanercept and 23 percent of those on placebo achieved a PsARC response (P < 0.0001).119 The 24-week study had similar results at 12 weeks: 72 percent of patients on etanercept and 31 percent of those on placebo achieved a PsARC response (P = NR).120 PASI 75 criteria were met by a greater proportion of patients in the etanercept groups than the placebo groups in both studies. In the 12-week study, 26 percent of patients on etanercept met PASI 75 criteria vs. zero patients on placebo (P = 0.015); in the longer study, the figures were 23 percent on etanercept vs. 3 percent on placebo (P < 0.001). The longer study assessed the radiographic progression of disease at 24 weeks in 205 patients; the mean annualized change in the modified Sharp score was significantly lower in etanercept-treated patients (decrease of −0.03) than in placebo-treated patients (increase of 1.0; P = 0.0001).122

A recent systematic review pooled the 12-week data from these two studies; the ACR 20 threshold for improvement was achieved by 65 percent of the etanercept groups, with a pooled relative risk of 4.19 (95% CI, 2.74–6.42).121 The ACR 50 and ACR 70 criteria were achieved by 45 percent and 12 percent, respectively. In addition, the PsARC was reached by almost 85 percent, with a pooled relative risk of 2.6 (95% CI, 1.96–3.45).121

##### Infliximab

Two studies of infliximab compared with placebo included 304 patients with active PsA who had not adequately responded to conventional DMARD therapies.115,117 In both studies, patients were allowed to continue MTX therapy as long as the dose had been stable for 4 weeks before study entry. The earlier study (N = 104) was double-blinded for 16 weeks.115 The later trial was double-blinded for 24 weeks (N = 200 patients with cross-over allowed at week 16 for nonresponders); the primary outcomes were evaluated at 14 weeks and before any crossover.117 Both studies had the same dosing regimen of 5 mg/kg of infliximab at weeks 0, 2, 6, and 14; the longer study had an additional injection at week 22. In both studies, the percentages meeting ACR 20 response criteria were significantly greater for infliximab than for placebo. In the earlier study, 86 percent of the patients on infliximab and 12 percent on placebo achieved a PsARC response (P < 0.001). The longer study had similar results in patients achieving a PsARC response at 14 weeks: 77 percent of the patients on infliximab and 27 percent on placebo (P < 0.001). PASI 75 was achieved by a greater proportion of patients in the infliximab groups than the placebo groups in both studies: for the 16-week study, 68 percent on infliximab vs. zero on placebo (P < 0.01) and, for the later study, 50 percent on infliximab vs. 1 percent on placebo (P < 0.001).

## Key Question 2: Functional Capacity and Quality of Life

This question examined specifically the issue of whether, for patients with RA or PsA, drug therapies differed in their ability to improve functional capacity or quality of life. Findings are organized as for KQ 1: RA followed by PsA. Table 9 (above) lists the abbreviated and full names of all instruments and scales referred to in this section. Functional capacity, functional status, and functional ability are three concepts often used interchangeably to refer to similar capabilities. Quality of life is a far broader construct comprising physical health, mental or emotional health, a variety of symptom states (e.g., pain, fatigue), and coping, spiritual and other domains. For the purposes of this report we divided outcomes into functional capacity and health-related quality of life. We use the terms functional capacity, functional status, or functional ability to refer to condition-specific measures, such as the Health Assessment Questionnaire (HAQ), developed to assess function in patients with RA or PsA. We use health-related quality of life when referring to generic measures, such as the Medical Outcomes Study Short Form 36 Health Survey (SF-36), that have been developed to assess quality of life in both healthy persons and those with different conditions. We also attempted to use terminology consistent with reporting from individual studies; if the authors used the term functional ability rather than functional capacity, we used the same term. Outcomes for functional capacity and health-related quality of life were sometimes secondary outcomes in these studies; that is, studies were not all designed to detect a difference between groups for these two types of outcomes.

### Rheumatoid Arthritis: Overview

A total of 16 RCTS, two observational studies, and one systematic review compared functional capacity or quality-of-life outcomes between active drugs or between active drugs and placebo. Details are found in Evidence Tables 5 and 6 in Appendix E. Table 14 provides information on comparisons made, functional capacity, health-related quality of life, and quality ratings. The main drug classes compared include corticosteroids, synthetic DMARDs, biologic DMARDs, and combined strategies.

Table 14

Interventions, functional capacity, health-related quality of life, and quality ratings of studies in adults with rheumatoid arthritis

Study | Study Design N Duration | Study Population | Comparison (dose) | Functional Capacity | Health-Related Quality of Life | Quality Rating
Corticosteroids vs. Corticosteroids
Kirwan et al., 2004^29^ | RCT 143 12 weeks | Population- based; active RA; mean disease duration 9 years | BUD (3 mg/day) vs. BUD (9 mg/day) vs. PNL (7.5 mg/day) | Better improvement in mean HAQ scores for PNL PNL 0.393 units better than BUD 3 mg; P < 0.001 PNL 0.276 units better than BUD 9 mg; P < 0.01 | Better improvement in SF-36 physical component for PNL than for BUD (mean change 5.4 units better than BUD 3 mg, P < 0.01; 3.7 units better than BUD 9 mg, P < 0.05) | Fair
Synthetic DMARDs vs. Synthetic DMARDs
Capell et al., 2007^30^ | RCT 165 (Phase 1 run-in: 687) 6 months (18 months for those with DAS ≥2.4 at 6 months) | Scotland; 8 NHS sites; active RA; mean disease duration 1.6 to 1.8 years | SSZ (≤4 g/day) vs. MTX (≤25 mg/week) | No significant difference between groups in change from baseline HAQ (SSZ: −0.25; MTX: −0.19; P = 0.99) | NR | Fair
Dougados et al., 1999^31^ | RCT 209 (146) 52 weeks (5 year followup) | Multinational; DMARD naive; mean disease duration 2.3 to 3.4 months | SSZ (2 to 3 g/day) vs. MTX (7.5 to 15 mg/week) vs. SSZ (2 to 3 g/day) + MTX (7.5 to 15 mg/week) | No statistically significant difference in change from baseline HAQ to 1 year (SSZ −0.74 vs. MTX −0.73; P = NS) | NR | Fair
Emery et al., 2000^32^ | RCT 999 1 year with optional 2nd year | Mean disease duration 3.5 to 3.8 years | LEF (20 mg/day) vs. MTX (10 to 15 mg/week) | Change in HAQ at 12 months, minimal quantitative (data NR) but significant (P < 0.05); at 24 months, difference NS | NR | Fair
Haagsma et al., 1997^33^ | RCT 105 52 weeks | Netherlands academic and peripheral clinics; DMARD naive; mean disease duration 2.6 to 3.1 months | SSZ (1 to 3 g/day) vs. MTX (7.5 to 15 mg/week) | Difference in change from baseline HAQ to 52 weeks not significant (SSZ −0.32; 95% CI, −0.53 to −0.10, MTX −0.46; 95% CI, −0.68 to −0.25; P = NR) | NR | Fair
Osiri et al., 2003^34^ | Systematic review and meta-analysis 1,732 2 years | 6 trials; active RA | LEF (10 to 20 mg/day) vs. MTX (7.5 to 15 mg/week) LEF (10 to 20 mg/day) vs. SSZ (2 g/day) | MHAQ scores improved significantly in LEF group compared with MTX at 6, 12, and 24 months; at both 12 and 24 months, no difference in improvement in HAQ At 6 and 24 months, LEF group had greater improvements in HAQ-DI than SSZ At one year there was no difference in work productivity in LEF vs. MTX weighted mean difference −2.3 points: 95% CI, 6.37-1.77 | LEF showed better improvement than MTX in SF-36 physical component but not mental component | Good
Smolen et al., 1999^35^ Scott et al., 2001^123^ | RCT 358 (146) 24 weeks (12 and 24 month followup) | Mean disease duration 5.7 to 7.6 years | LEF (20 mg/day) vs. SSZ (2 g/day) | Improvement in HAQ scores at 24 weeks greater in LEF than SSZ (−0.50 vs. −0.29; P < 0.03) and continued in 2-year followup group at 6 and 24 months (−0.50 vs. −0.29; −0.65 vs. −0.36; both P < 0.01) | NR | Fair
Strand, et al., 1999^37^ Cohen, et al., 2001^38^ | RCT 482 12 months (1 year continuation) | Mean disease duration 6.5 to 7 years | LEF (20 mg/day) vs. MTX (7.5 to 15 mg/week) | Mean improvement in HAQ-DI greater in LEF than MTX at 12 months (−0.45 vs. −0.26; P ≤ 0.01) and MHAQ (−0.29 vs. - 0.15; P < 0.01) | Mean improvement in SF-36 physical greater in LEF than MTX at 12 months (7.6 vs. 4.6; P < 0.01) but not mental component (1.5 vs. 0.9; P = NS) | Fair
Synthetic DMARD Combinations
Boers et al., 1997;^39^ Landewe et al., 2002^40^ COBRA study | RCT 155 (148) 56 weeks (5- year followup) | Multicenter; early RA; mean disease duration 4 months | SSZ (2g/day) + MTX (7.5 mg/day stopped after 40 weeks) + PNL (60 mg/day tapered over 28 weeks) vs. SSZ | Mean change in HAQ: SSZ + MTX combination had greater improvements in functional capacity at 28 weeks (mean change in HAQ −1.1 vs. −0.6; P < 0.0001) but difference not significant at 56 weeks (−0.8 vs. −0.6; P < 0.06) | NR | Good
Capell et al., 2007^30^ | RCT 165 (Phase 1 run-in: 687) 6 months (18 months for those with DAS ≥2.4 at 6 months) | Scotland; 8 NHS sites; active RA; mean disease duration 1.6 to 1.8 years | SSZ (≤4 g/day) + MTX (≤25 mg/week) vs. SSZ (≤4 g/day) vs. MTX (≤ 25 mg/week) | Change from baseline HAQ: no significant difference between groups (SSZ + MTX −0.50 vs. SSZ −0.25; P = 0.51), (SSZ + MTX −0.50 vs. MTX −0.19; P = 0.57) | NR | Fair
Dougados et al., 1999^31^ Maillefert et al., 2003^41^ | RCT 209 (146) 52 weeks (5 year followup) | Multinational; DMARD naive; mean disease duration 2.3 to 3.4 months | SSZ (2 to 3 g/day) vs. MTX (7.5 to 15 mg/week) vs. SSZ (2 to 3 g/day) plus MTX (7.5 to 15 mg/week) | No statistically significant difference in change from baseline HAQ to 1 year (SSZ + MTX −0.70 vs. SSZ −0.74 vs. MTX −0.73; P= NS) or in mean HAQ at 5 years (combination 0.6 vs. either single therapy 0.6; P = 0.9) | NR | Fair
Goekoop-Ruiterman et al., 2005 42 BeSt study | RCT 508 12 months | Multicenter; early RA; median duration between diagnosis and inclusion 2 weeks (IQR 1 to 5), median duration of symptoms 23 weeks (IQR 14 to 53) | 1: sequential monotherapy starting with MTX (15 mg/week) vs. 2: step-up combination therapy (MTX, then SSZ, then HCQ, then PRED) vs. 3: combination with tapered high-dose PRED (60 mg/d to 7.5 mg/day) vs. 4: combination (MTX 25 to 30 mg/week) with INF (3 mg/kg every 8 weeks, per DAS, could be titrated to 10 mg/kg) | Better functional ability after 12 months for patients treated with 3 or 4 than those treated with group (mean D- HAQ scores for strategies 1 through 4 were 0.7, 0.7, 0.5, and 0.5, respectively; P < 0.05 for 1 vs. 3 and 4, NS for other comparisons) | NR | Good
Haagsma et al., 1997^33^ | RCT 105 52 weeks | Netherlands academic and peripheral clinics; DMARD naive; mean disease duration 2.6 to 3.1 months | SSZ (1 to 3 g/day) vs. MTX (7.5 to 15 mg/week) vs. SSZ (2 to 3 g/day) + MTX (7.5 to 15 mg/week) | Difference in change from baseline HAQ to 52 weeks NS (SSZ + MTX −0.51: 95% CI, −0.76 –−0.26 vs. SSZ −0.32: 95% CI, −0.53 –−0.10 vs. MTX −0.46: 95% CI, −0.68 –−0.25; P = NR) | NR | Fair
Mottonen et al., 1999;^43^ Korpela et al., 2004;^44^ Puolakka et al., 2004^124^ FIN-RACo study | RCT 199 24 months (5 year followup) | Multicenter; early RA; mean disease duration 7.3 to 8.6 months | MTX (7.5 to 10 mg/week) + HCQ (300 mg/day) + SSZ (2 g/day) + PNL (5 to 10 mg/day) vs. DMARD (SSZ could be changed to MTX or 3rd DMARD) ± PNL | Less work disability for combination group than monotherapy group (median 12.4 days per patient- observation year vs. 32.2; P = 0.008) | NR | Fair
Svensson et al., 2005^47^ | Open-label trial 250 2 years | Population- based; active RA; duration 1 year or less | DMARD (SSZ or MTX, dosages NR) + PNL (7.5 mg/day) vs. DMARD | Greater improvement in DMARD + PNL group than DMARD- only group (from mean HAQ of 1.0 to 0.4 at 1 year and 0.5 at 2 years vs. 1.0, 0.6, and 0.7; P = NR) Mean SOFI index decreased from 8 at baseline to 4 at 1 year and 4 at 2 years vs. 9, 6, and 7 respectively; P = NR) | NR | Fair
Biologic DMARDs vs. Biologic DMARDs
Weaver et al., 2006^53^ | Prospective cohort study 1,371 12 months | Population- based; patients with active RA who required change in therapy; mean disease duration 9.3 years | ETA (25 mg twice weekly) vs. INF (3.8 mg/kg or higher) | Greater mean percentage improvements in HAQ at 12 months in ETA than INF (17% vs. 1%; P = NR) | NR | Fair
Biologic DMARDs vs. Synthetic DMARDs
Bathon et al., 2000;^54^ Genovese et al., 2002;^55^ Genovese et al, 2005;^56^ Kosinski et al., 2002^125^ ERA study | RCT 632 (512) 12 months (1 year open- label extension) | Early, aggressive RA; MTX-naive; mean disease duration 11.7 months | ETA (10 or 25 mg twice weekly) vs. MTX (20 mg/week) | Better improvement in HAQ early in treatment (first 12 weeks) for ETA than MTX (P < 0.0001). No significant difference in HAQ scores during weeks 16 to 52 Significantly greater percentage of patients with at least a 0.5 unit improvement in HAQ-DI at 24 months for ETA 25 mg than for either ETA 10 mg or MTX (55% vs. 43% vs. 37%; P = 0.021 and P < 0.001, respectively) | Better improvement in SF-36 physical summary and SF-36 arthritis- specific health index for ETA group than the MTX group during first 12 weeks (P < 0.0001) No significant difference in weeks 16 to 52 | Fair
Breedveld et al., 2006 57 PREMIER study | RCT 799 2 years | Early, aggressive RA; MTX-naive; mean disease duration NR (< 3 years) | ADA (40 mg biweekly) vs. MTX (20 mg/week) | At 1 year, ADA and MTX monotherapy groups had similar improvement in HAQ-DI (−0.8 vs. −0.8; P = NR). Improvements remained similar after 2 years | NR | Fair
Klareskog et al., 2004;^63^ van der Heijde et al., 2006;^64^ van der Heijde et al., 2006^65^ TEMPO study | RCT 686 (503 for 2 year results) 52 weeks (2 years, 100 weeks) | Active RA; had failed at least 2 DMARDs; mean disease duration 6.6 years | ETA (25 mg twice weekly) vs. MTX (20 mg/week) | Similar improvement in mean HAQ scores for MTX and ETA (scores fell from 1.7 to 1.1 and 1.7 to 1.0; P = 0.3751) | NR | Good
Listing et al., 2006^58^ | Prospective cohort study 1,083 12 months | Population- based; patients with active RA who required change in therapy; mean disease duration 9.6 years | Biologics as a class (ADA, ANA, ETA, INF; dose NR) vs. DMARDs as a class (dose NR) | Severely disabled patients (≤50% of full function) in biologic group more likely to achieve physical independence (≥67% of full function, Hanover Functional Status Questionnaire) than DMARD group (OR, 3.88; 95% CI, 1.7–8.8) Functional remission (≥83% of full function) more often achieved in biologic group than in DMARD group (OR, 2.18; 95% CI, 1.04–4.6) | NR | Fair
Biologic DMARDs + Synthetic DMARDs vs. Biologic DMARDs
Breedveld et al., 2006^57^ PREMIER study | RCT 799 2 years | Early, aggressive RA; MTX- naive; mean disease duration NR (< 3 years) | ADA (40 mg biweekly) + MTX (20 mg/week) vs. ADA (40 mg biweekly) | At 1 year, ADA + MTX group had greater improvements in HAQ- DI than ADA alone (mean, −1.1 units vs. −0.8; P = 0.002). After 2 years, there was no difference (−1.0 vs. −0.9; P = 0.058) After 2 years, more ADA + MTX patients had improvement of ≥ 0.22 in HAQ-DI than ADA patients (72% vs. 58%; P < 0.05); had a greater percentage with HAQ-DI scores of 0 (33% vs. 19%; P < 0.001) | NR | Fair
Combe et al., 2006^60^ | RCT 260 24 weeks | Europe multicenter; active RA despite SSZ treatment; mean disease duration 6.6 years | ETA (25 mg twice weekly) + SSZ (2, 2.5, or 3 g/day) vs. ETA (25 mg twice weekly) | Mean percentage improvements in HAQ were similar for ETA + SSZ and ETA alone (40.2% vs. 35.3%, P = NS) | Mean percentage improvements in EuroQOL VAS were similar for ETA + SSZ and ETA alone (67.6% vs. 64.6%; P = NS) | Fair
Klareskog et al., 2004;^63^ van der Heijde et al., 2006;^64^ van der Heijde et al., 2006^65^ TEMPO study | RCT 696 (503 for 2 year results) 52 weeks (2 years, 100 weeks) | Europe multinational, multicenter; active RA; had failed at least 2 DMARDs; mean disease duration 6.6 years | ETA (25 mg twice weekly) + MTX (20 mg/week) vs. ETA (25 mg twice weekly) | At 52 weeks ETA + MTX was more likely to attain HAQ-DI scores similar to population norms (< 0.5) than ETA alone (P < 0.05). Combination group had greater improvement in mean HAQ scores (mean fall from 1.8 to 0.8 vs. 1.7 to 1.0; P < 0.001; mean improvement from baseline HAQ 1.0 vs. 0.7; P < 0.01) | ETA + MTX patients reported better quality of life than ETA-only patients (mean EQ 5-D VAS 72.7 vs. 66.8; P < 0.05) | Good
Weaver et al., 2006^53^ | Prospective cohort study 3,034 12 months | Population- based; patients with active RA who required change in therapy; mean disease duration 8.3 years | ETA (25 mg twice weekly) + MTX (dose NR) vs. ETA (25 mg twice weekly) | Patients treated with ETA + MTX had similar improvements in functional capacity to those treated with ETA only (mean percentage improvements in HAQ at 12 months: 17% vs. 17%; P = NR) | NR | Fair
Biologic DMARDs + Synthetic DMARDs vs. Synthetic DMARDs
Breedveld et al., 2006^57^ PREMIER study | RCT 799 2 years | Early, aggressive RA; MTX- naive; mean disease duration NR (< 3 years) | ADA (40 mg biweekly) + MTX (20 mg/week) vs. MTX (20 mg/week) | At 1 year, ADA + MTX had greater improve- ments in HAQ-DI than MTX alone (mean −1.1 units vs. −0.8; P < 0.001). After 2 years, ADA + MTX remained statistically greater (−1.0 vs. −0.9; P < 0.058) After 2 years, more ADA + MTX patients had improvement of ≥ 0.22 in HAQ-DI than MTX patients (72% vs. 63%; P < 0.05). Had greater percentage with HAQ-DI scores of 0 (33% vs. 19%; P < 0.001) | NR | Fair
St Clair et al., 2004;^68^ Smolen et al., 2006^69^ ASPIRE study | RCT 1,049 54 weeks | Early, aggressive RA; MTX- naive; mean disease duration 0.9 years | INF (3 mg/kg/8 weeks) + MTX (20 mg/week) vs. INF (6 mg/kg/8 weeks) + MTX (20 mg/week) vs. MTX (20 mg/week) | Greater mean decrease in HAQ from weeks 30 to 54 for combination groups than MTX group (INF 3 mg + MTX and INF 6 mg + MTX vs. MTX: 0.80 and 0.88 vs. 0.68; P = 0.03; P < 0.001). Combination therapy was more effective for improving HAQ by at least 0.22 units (76.0% and 75.5% vs. 65.2%; P = 0.003; P = 0.004) Patients on combination treatment had a higher probability of improvement in employability than those on MTX alone (P < 0.001) | Significantly greater improvement in SF- 36 physical component summary scores for INF 6 mg + MTX vs. MTX (13.2 vs. 10.1; P = 0.003) but not for INF 3 mg + MTX vs. MTX (11.7 vs. 10.1; P = 0.10) | Fair
Weaver et al., 2006^53^ | Prospective cohort study 3,034 12 months | Population- based; patients with active RA who required change in therapy; mean disease duration 8.3 years | ETA (25 mg twice weekly) + MTX (dose NR) vs. ETA (25 mg twice weekly) | Greater mean percentage improvements in HAQ at 12 months for ETA + MTX than MTX (17% vs. 7%; P < 0.01) Similar mean percentage improvements in HAQ at 12 months for INF + MTX and MTX (3% vs. 7%; P = NS) | NR | Fair

BUD, budesonide; combo, combination therapy; DAS, disease activity score; DMARD, disease modifying antirheumatic drug; ETA, etanercept; HAQ, Health Assessment Questionnaire; HAQ-DI, Health Assessment Questionnaire – Disability Index; HCQ, hydroxychloroquine; INF, infliximab; LEF, leflunomide; mg, milligram; MTX, methotrexate; NHS, National Health Service; NR, not reported; NS, not significant; PNL, prednisolone; PRED, prednisone; RCT, randomized controlled trial; SF-36, Medical Outcomes Test, Short Form 36; SOFI, Signals of Functional Impairment Scale; SSZ, sulfasalazine.

### Rheumatoid Arthritis: Key Points

#### Corticosteroids vs. corticosteroids

Only one head-to-head RCT compared two corticosteroids, budesonide and prednisolone.29 Prednisolone produced greater improvement in functional capacity and health-related quality of life than budesonide. The results are limited to one study. The strength of evidence is low.

#### Synthetic DMARDs vs. synthetic DMARDs

Two RCTs32,37 and one systematic review with meta-analysis34 compared leflunomide and MTX. Some results indicated greater improvement with leflunomide (mean improvement in the Health Assessment Questionnaire Disability Index (HAQ-DI) at 12 months and 24 months and in the SF-36 (Medical Outcomes Study Short Form 36 Health Survey) physical component at 12 months; others showed no differences in work productivity or the SF-36 mental component. The strength of the evidence is moderate.

One RCT35 with a 2-year followup123 compared leflunomide and sulfasalazine. Leflunomide yielded greater improvements in functional capacity measured by HAQ scores at 24 weeks, 6 months, and 24 months. The results were limited to one study. The strength of the evidence is low.

Three RCTs compared sulfasalazine and MTX.30,31,33 Results, consistent across the trials, did not support a difference in functional capacity between the medications. The strength of the evidence is moderate.

No fair or good evidence exists for comparing hydroxychloroquine to monotherapy with another synthetic DMARD.

#### Synthetic DMARD combinations

Three RCTs compared a combination of two synthetic DMARDs (sulfasalazine plus MTX) to monotherapy with either drug alone.30,31,33 Findings do not support a difference in functional capacity between combination therapy and monotherapy. The strength of the evidence is moderate.

Three RCTs compared various combination strategies using corticosteroids and one or more synthetic DMARDs with synthetic DMARD monotherapy.39,43,47 One open-label RCT compared the combination of a synthetic DMARD and prednisolone with synthetic DMARD monotherapy and found greater improvement in functional capacity for the combination group.47 The functional capacity outcomes were not statistically evaluated for the two groups, and the clinical relevance of these results is uncertain. In addition, the results should be interpreted cautiously, given the open-label design and potential for bias. Another RCT found that the combination of sulfasalazine, MTX, and prednisolone vs. sulfasalazine alone resulted in greater improvements in functional capacity at 28 weeks, but the difference was no longer statistically significant at 56 weeks.39 The third RCT compared a combination of three synthetic DMARDs (MTX, sulfasalazine, and hydroxychloroquine) plus prednisolone with synthetic DMARD monotherapy.43 The combination therapy group had significantly less work disability than patients in the monotherapy group at 5-year followup.124 Of note, the randomized treatments were carried out for 2 years and treatments were then at the discretion of the treating physician.

The data are limited to one study for each comparison. The strength of the evidence is low for each individual comparison. However, the strength of evidence is moderate favoring combination strategies using corticosteroids plus one or more synthetic DMARDs over synthetic DMARD monotherapy.

One RCT in patients with early RA found that patients treated with initial combination therapy of MTX, sulfasalazine, and tapered high-dose prednisone or initial combination therapy with infliximab and MTX had statistically significantly better functional ability than those treated with sequential DMARD therapy.42 However, the magnitude of difference was small, and the clinical significance of this result is uncertain. The strength of the evidence is low.

#### Biologic DMARDs vs. biologic DMARDs

We did not find any head-to-head RCTs that compared one biologic DMARD with another. The evidence was limited to one prospective cohort study that compared etanercept with infliximab.53 Patients treated with etanercept had better functional capacity at 12 months than did those treated with infliximab (mean percentage improvements in HAQ 17 percent vs. 1 percent; P = NR). However, direct statistical comparisons between etanercept and infliximab were not described. The strength of the evidence is low.

#### Biologic DMARDs vs. synthetic DMARDs

We found three RCTs54,57,63 and one prospective cohort study58 that included comparisons of monotherapy with a biologic DMARD to monotherapy with a synthetic DMARD. The evidence from these studies is mixed. Population-based, observational evidence from the cohort study indicated that biologic DMARDs as a class resulted in better functional capacity than synthetic DMARDs as a class.58 Two of the RCTs, however, found no differences when comparing either adalimumab57 or etanercept63 with MTX. The third RCT 54 found that etanercept resulted in better improvement of function and quality of life during the first 12 weeks of treatment, but it found no difference from week 16 to week 52. The study also reported that a greater percentage of patients treated with etanercept had significant improvements in functional capacity (≥0.5 unit HAQ-DI) at 24 months. All RCTs were funded by the makers of the biologic DMARDs. The strength of the evidence is moderate for biologics as a class compared to synthetics as a class.

No evidence exists on abatacept, anakinra, infliximab, and rituximab. No studies were available comparing biologics with synthetic DMARDs other than MTX.

#### Biologic DMARDS vs. corticosteroids

No studies meeting our quality criteria compared biologic DMARDs with corticosteroids.

#### Biologic DMARD combinations

Two RCTs suggested that a combination of adalimumab57 or etanercept63–65 with MTX led to statistically significantly greater improvements in functional capacity or health-related quality of life than monotherapy with biologic DMARDs. One other RCT found no difference between a combination of etanercept with sulfasalazine and etanercept monotherapy.60 One prospective cohort study found no differences in these outcomes when comparing etanercept plus MTX to etanercept alone or infliximab plus MTX to infliximab alone.53 The strength of the evidence is low for all comparisons.

For most individual medications in these comparisons, however, the evidence is limited to a single study. All RCTs were funded by the makers of the biologic DMARDs. No evidence (for biologic DMARD plus synthetic DMARD vs. biologic DMARD) was available on abatacept, anakinra, rituximab, and combinations with synthetic DMARDs other than MTX and sulfasalazine.

Two RCTs found that a combination of adalimumab plus MTX57 or infliximab plus MTX68 in MTX-naive patients with early, aggressive RA led to better functional capacity and quality of life than MTX monotherapy. Both RCTs were funded by the makers of the biologic DMARDs. One prospective cohort study found the etanercept-MTX combination to be greater than MTX monotherapy for functional capacity, but it found no difference between the infliximab-MTX combination and MTX alone.53 The strength of the evidence supporting a greater efficacy of combination treatment with a biologic DMARD plus MTX than with MTX monotherapy is moderate for the above comparisons.

### Rheumatoid Arthritis: Detailed Analysis

#### Corticosteroids

##### Corticosteroid vs. corticosteroid

One 12-week head-to-head RCT (N = 143) compared budesonide (3 mg/day or 9 mg/day; n = 37 and 36, respectively) and prednisolone (7.5 mg/day; n = 39).29 Mean disease duration of RA was 9 years. Overall, prednisolone produced greater improvement in functional capacity and health-related quality of life than either dose of budesonide. At 12 weeks, those treated with prednisolone had better improvement in mean HAQ scores than budesonide (0.393 units better than budesonide 3 mg, P < 0.001; 0.276 units better than budesonide 9 mg, P < 0.01). A change of 0.22 units is generally considered the minimum clinically important difference.126 Those treated with prednisolone also had better improvement in health-related quality of life as measured by the physical subscale of the SF-36 (difference in mean change of 5.4 units compared with budesonide 3 mg, P < 0.01; 3.7 compared with budesonide 9 mg, P < 0.05). Improvement on the mental subscale of the SF-36 was not statistically significantly different between groups. Of note, functional capacity and health-related quality of life were secondary outcome measures; the study had not been designed to compare differences in either the HAQ or the SF-36.

#### Synthetic DMARD vs. synthetic DMARD

##### Leflunomide vs. methotrexate

We found two RCTs32,37 comparing leflunomide (20 mg/day) with MTX (7.5 mg/week to 15 mg/week)32,37 and one good systematic review with a meta-analysis of leflunomide.34 The systematic review included only two trials comparing leflunomide with MTX and only one study for all but one of the functional capacity and quality-of-life outcomes. We describe the individual studies first.

The first trial randomized 482 patients to leflunomide (n = 182) or MTX (n = 182) over 12 months.37,127 It is described in more detail in the KQ 1 section entitled Synthetic DMARDs vs. synthetic DMARDs. Patients receiving leflunomide reported greater mean improvement in the HAQ-DI (−0.45 vs. −0.26; P ≤ 0.01), MHAQ (−0.29 vs. −0.15; P < 0.01), and the SF-36 physical component (7.6 vs. 4.6; P < 0.01) than those receiving MTX at 12 months. At 12 months, the two groups did not differ significantly in improvement in the SF-36 mental summary score (1.5 vs. 0.9; P = NS) or in work productivity. A 2-year followup of 235 patients (leflunomide, n = 98; MTX, n = 101) found greater mean improvement in the HAQ-DI (−0.60 vs. −0.37; P = 0.005) and MHAQ scores (−0.43 vs. −0.28; P ≤ 0.05) with leflunomide than with MTX.38 The groups did not differ significantly in mean improvement in the SF-36 physical or mental summary scores at 24 months. These 2-year results are limited by the high attrition rate (45 percent) from the initial study.

One multinational trial comparing leflunomide and MTX was a 1-year RCT of 999 subjects with an optional second year.32,128 Mean disease duration was 3.5 years to 3.8 years. At 12 months, a statistically significant but minimal quantitative difference (number not reported, shown in bar graph)32 for change in the HAQ (P < 0.05) was reported between the two groups; at 24 months, however, the groups did not differ significantly.

The systematic review with meta-analysis included six trials (N = 2,044) comparing leflunomide (10 to 20 mg/day) with other synthetic DMARDs in patients with active RA.34 It included two studies relevant to this section.32,37 MHAQ scores improved significantly more in patients treated with leflunomide than in those treated with MTX at 6, 12, and 24 months. The leflunomide group and the MTX group did not differ in improvement on the HAQ index at either 12 months or 24 months. Work productivity did not improve significantly in the leflunomide group when compared with the MTX group (weighted mean difference [WMD], −2.3 points; 95% CI, −6.37–1.77). When comparing leflunomide with MTX, changes in SF-36 scores showed better improvement in the physical summary score (WMD, −3.0 points; 95% CI, −5.41 - −0.59) but not the mental summary score (WMD, −0.6 points; 95% CI, −3.01–1.81). This systematic review was limited by the number of studies included for meta-analysis; only one study was available for each individual functional capacity or quality-of-life outcome measure except for change in HAQ scores, for which there were two studies.

##### Leflunomide vs. sulfasalazine

One RCT35 with a 2-year followup123 compared leflunomide (20 mg/day) with sulfasalazine (2 g/day); one systematic review included a meta-analysis of leflunomide.34 The RCT was a multinational, multicenter study of 358 patients (leflunomide, n = 133; sulfasalazine, n = 133).35 Baseline HAQ scores were similar for all groups. The leflunomide group had significantly greater improvement in HAQ scores at 24 weeks than the sulfasalazine group (−0.50 vs. −0.29; P < 0.03). The 2-year followup found that the leflunomide group had significantly greater improvements in HAQ scores than the sulfasalazine group at 6 and 24 months (−0.50 vs. −0.29 and −0.65 vs. −0.36; both P < 0.01).123 The study was limited by only including 146 (leflunomide, n = 60; sulfasalazine, n = 60) of the original 358 subjects and having a 21 percent attrition rate (116 completed the study).

One systematic review with meta-analysis compared leflunomide (10 to 20 mg/day) with other DMARDs in patients with active RA.34 For comparing leflunomide and sulfasalazine, the meta-analysis included one study (N = 229) with changes in HAQ at 6, 12, and 24 months.123 At 6 and 24 months, the leflunomide group had greater improvements in the HAQ-DI than the sulfasalazine group (WMD −0.25 point; 95% CI, −0.42 - −0.08; WMD −0.29 point; 95% CI, −0.57 - −0.01, respectively). This evidence is limited because the meta-analysis included only one study for this outcome; they did not pool data from multiple studies.

##### Sulfasalazine vs. MTX

Three RCTs compared sulfasalazine with MTX.30,31,33 Their findings are consistent and do not support a difference in functional capacity between the groups receiving these two pharmaceuticals. A multinational 52-week RCT of 209 DMARD-naive subjects found no statistically significant difference in change in the HAQ from baseline to 1 year (sulfasalazine −0.74; MTX −0.73; P = NS).31 A 52-week RCT of 105 DMARD-naive subjects in academic and peripheral clinics in the Netherlands reported a change in HAQ scores from baseline to 52 weeks of −0.32 (95% CI, −0.53 - −0.10) for sulfasalazine and a change of −0.46 (95% CI, −0.68 - −0.25; P = NR) for MTX.33 HAQ was a secondary outcome in this study; HAQ changes for the different groups were not compared statistically. An 18-month RCT of 165 subjects at eight sites in Scotland found no significant difference between the sulfasalazine and MTX groups on the HAQ between baseline and endpoint (−0.25 vs. −0.19; P = 0.99).30

#### Synthetic DMARD combinations

##### MTX plus sulfasalazine vs. monotherapy with MTX or sulfasalazine

Three RCTs (four publications) compared MTX plus sulfasalazine to either drug alone.30,31,33,41 Two of the RCTs included patients with disease duration of less than 1 year;31,33 the third included patients with RA of up to 10 years.30 Findings of these studies do not support a difference in functional capacity between combination therapy and either monotherapy.

A multinational RCT of 209 DMARD-naive subjects compared sulfasalazine (2 g/day to 3 g/day; n = 68), MTX (7.5 mg/week to 15 mg/week; n = 69), and the sulfasalazine-MTX combination (n = 68) for 52 weeks. No statistically significant difference in changes in HAQ scores occurred from baseline to 1 year (combination −0.70; sulfasalazine −0.74; MTX −0.73; P = NS).31 A long-term followup comparing the combination therapy to monotherapy (combining the two monotherapy groups) found no significant difference in mean HAQ scores at 5 years (combination 0.6; monotherapy 0.6; P = 0.9).41

A 52-week RCT of 105 DMARD-naive subjects in Dutch academic and peripheral clinics reported a change in HAQ scores between baseline and 52 weeks of −0.51 (95% CI, −0.76 - −0.26) for the MTX-sulfasalazine combination therapy, a change of −0.32 (95% CI, −0.53 - −0.10; P = NR) for sulfasalazine, and a change of −0.46 (95% CI, −0.68 - −0.25; P = NR) for MTX.33 The HAQ was a secondary outcome in this study; the authors did not attempt to explain these results or compare the values.

The third study was an 18-month RCT of 165 subjects at eight sites in Scotland. The investigators found no significant difference between the combination therapy and the monotherapy groups in changes from baseline HAQ scores (combination −0.50; sulfasalazine −0.25; MTX −0.19; combination vs. sulfasalazine, P = 0.51; combination vs. MTX, P = 0.57).30

#### Synthetic DMARD plus corticosteroid combinations vs. synthetic DMARDs

##### One synthetic DMARD plus corticosteroid vs. synthetic DMARD

The evidence is limited to one open-label RCT that compared synthetic DMARD use with and without prednisolone in patients with active RA for 1 year or less.47 This 2-year study compared prednisolone (7.5 mg/day) added to an initial DMARD (chosen by the treating physician) with a synthetic DMARD only in patients with early RA; it is described in greater detail in the Key Question 1 section entitled One synthetic DMARD plus corticosteroid vs. synthetic DMARD. The authors reported greater improvement in functional capacity for the prednisolone group than the nonprednisolone group. The DMARD plus prednisolone group had a decrease in HAQ scores from a mean of 1.0 at baseline to 0.4 at 1 year and 0.5 at 2 years. The corresponding values for the DMARD-only group were 1.0, 0.6, and 0.7 (P = NR). The DMARD plus prednisolone group also had greater improvement in the mean Signals of Functional Impairment (SOFI) index (mean decrease from 8 at baseline to 4 at 1 year and 4 after 2 years compared to values of 9, 6, and 7, respectively; P = NR). Scores on the HAQ and the SOFI index were not statistically compared for the two groups; the clinical relevance of these results is uncertain. In addition, the results should be interpreted cautiously, given the open-label design and potential for bias.

##### Two synthetic DMARDs plus corticosteroid vs. synthetic DMARD

The COBRA (Combinatietherapie Bij Reumatoide Artritis) study assessed differences in efficacy between a combination of sulfasalazine, MTX, and prednisolone and sulfasalazine only.39 This RCT evaluated 155 patients with early RA over 56 weeks. Combination therapy included sulfasalazine (2 g/day), MTX (7.5 mg/week stopped after 40 weeks), and prednisolone treatment (60 mg/day tapered over 28 weeks). Compared with patients treated with sulfasalazine alone, patients treated with combination therapy had greater improvements in functional capacity at 28 weeks (mean change in HAQ of −1.1 vs. −0.6; P < 0.0001). The difference was no longer statistically significant at 56 weeks (mean change in HAQ, −0.8 vs. −0.6; P < 0.06).

##### Three synthetic DMARDs plus corticosteroid vs. synthetic DMARD

The FIN-RACo (Finnish Rheumatoid Arthritis Combination Therapy) RCT assessed the efficacy of a combination of MTX, sulfasalazine, hydroxychloroquine, and prednisolone against monotherapy with a DMARD with or without prednisolone.43 This study randomized 199 patients with early RA to combination therapy or monotherapy. Combination therapy included sulfasalazine (2 g/day), MTX (7.5 mg/week to 10 mg/week), hydroxychloroquine (300 mg/day), and prednisolone (5 mg/day to 10 mg/day). Patients on monotherapy were initially started on sulfasalazine (2 g/day to 3 g/day), but they could be changed to MTX (7.5 mg/week to 15 mg/week) or to a third DMARD if needed. The study is described further in the KQ 1 section entitled Three synthetic DMARDs plus corticosteroid vs. synthetic DMARDs. The initial publication reported no functional capacity or quality-of-life outcomes at 2 years. A 5-year follow-up trial reported that patients in the combination therapy group had significantly less work disability than patients in the monotherapy group (median 12.4 days per patient-observation year vs. 32.2 days; P = 0.008, sex- and age-adjusted P = 0.009).124 After 2 years, the drug treatment strategy was no longer restricted.

Other combination strategies. The BeSt RCT (Dutch acronym for Behandel Strategieen, “treatment strategies”) examined four different treatment strategies over 12 months.42 Patients (N = 508) with early RA were randomized to one of four strategies: (1) sequential DMARD starting with MTX (15 mg/week); (2) step-up combination therapy of MTX (15 to 30 mg/week) followed by sulfasalazine (2 g/day), hydroxychloroquine, and prednisone; (3) initial combination therapy of MTX, and sulfasalazine with tapered high-dose prednisone (60 mg/day to 7.5 mg/day in 7 weeks); and (4) initial combination therapy with infliximab (3 mg/kg) and MTX (25 to 30 mg/week). Adjustments were made in each strategy when the DAS 44 (disease activity score in 44 joints) was greater than 2.4. All groups had similar D-HAQ (Dutch version of the HAQ) scores at baseline (1.4 ± 0.7 or 1.4 ± 0.6). Functional ability, measured by the D-HAQ, was a primary end point. After 12 months of treatment, patients treated with strategy 3 or 4 had statistically significantly better functional ability than those treated with strategy 1; (mean D-HAQ scores for strategies 1 through 4 were 0.7, 0.7, 0.5, and 0.5, respectively; P < 0.05 for group 1 vs. groups 3 and 4, NS for other comparisons).

#### Biologic DMARD vs. biologic DMARD

We did not identify any head-to-head RCTs. The head-to-head evidence was limited to a prospective cohort study based on the RADIUS (Rheumatoid Arthritis DMARD Intervention and Utilization Study) program that included etanercept and infliximab.53

##### Etanercept vs. infliximab

RADIUS was a primary care-based U.S. study that enrolled patients who were initiating any new DMARD at study entry. Mean disease duration was 9.3 years, indicating that most patients suffered from advanced RA. The percentage of patients with early RA was not reported. Patients treated with etanercept had greater mean percentage improvements on the HAQ at 12 months than patients treated with infliximab (17 percent vs. 1 percent; P = NR). Among patients older than 65 years, after adjusting for baseline covariates, the authors reported that the etanercept-treated patients had greater mean percentage improvements in the HAQ at 12 months than infliximab-treated patients (22 percent vs. 4 percent; P = NR). However, direct statistical comparisons between etanercept and infliximab were not described. The study was designed to compare combinations of etanercept or infliximab with MTX to monotherapy with etanercept, infliximab, or MTX.

#### Biologic DMARDs vs. synthetic DMARDs

We found three RCTs and one prospective cohort study that included comparisons of biologic DMARD monotherapy with synthetic DMARD monotherapy. The RCTs compared etanercept with MTX54,63 and adalimumab with MTX;57 the cohort study assessed differences in class effects.58 No head-to-head evidence exists on abatacept, anakinra, infliximab, and rituximab or on synthetic DMARDs other than MTX (although anakinra and infliximab were included in the prospective cohort study comparing biologics as a class to synthetic DMARDs as a class).

##### Biologic DMARDs as a class vs. synthetic DMARDs as a class

The prospective cohort study examined differences in clinical and functional remission between biologics as a class (adalimumab, anakinra, etanercept, infliximab; n = 818) and synthetic DMARDs as a class (n = 265) in patients who had failed two previous DMARD treatments.58 This study was population-based and part of the RABBIT study, a German long-term, prospective cohort study of RA patients who required a change in therapy in daily rheumatologic care. Patients on biologics were younger and had a significantly more active disease at baseline. Severely disabled patients receiving biologic therapies were more likely to achieve physical independence, defined as ≥67 percent of full function as measured by the Hanover Functional Status Questionnaire (FFbH, or Funktionsfragebogen Hannover), than controls on conventional synthetic DMARD therapy (OR, 3.88; 95% CI, 1.7–8.8). Functional remission (≥83 percent of full function) was more often achieved in patients receiving biologics than in controls (OR, 2.18; 95% CI, 1.04–4.6).

##### Adalimumab vs. MTX

The only data come from the PREMIER study, a multinational 2-year RCT of 799 patients with early, aggressive RA who had not previously received MTX.57 Two treatment arms of this 2-year study were adalimumab monotherapy (40 mg every other week) and MTX monotherapy (20 mg/week). Details of this study are reported in the KQ 1 section on Biologic DMARDs plus synthetic DMARDs vs. biologic DMARDs. After 1 year, the adalimumab and MTX monotherapy groups had similar improvements in functional status measured using the HAQ-DI (mean: −0.8; −0.8; P = NR). Improvements remained similar after 2 years (−0.9; −0.9; P = NR). After 2 years, 19 percent of patients in both monotherapy groups had HAQ-DI scores of zero. We report on results of the other comparisons of the PREMIER study for functional status outcomes in the respective KQ 2 sections on Biologic DMARDS plus synthetic DMARDs vs. biologic DMARDs and Biologic DMARDs plus synthetic DMARDs vs. synthetic DMARDs.

##### Etanercept vs. MTX

Two trials (seven publications) compared etanercept with MTX (20 mg/week) over 52 weeks.54–56,63–65,125 The ERA (Early Rheumatoid Arthritis) study (N = 632) was conducted in patients with early RA who were MTX-naive.54–56 The other study was the TEMPO trial (see KQ 1 section on Biologic DMARDs plus synthetic DMARDs vs. biologic DMARDs).63–65 Patients had active RA and had failed at least one DMARD other than MTX. About 60 percent of the study population was MTX-naive.

ERA was a 52-week multicenter RCT of 632 patients with early RA in the United States that compared etanercept (10 mg or 25 mg twice weekly) with MTX (20 mg/week).54–56,125 The treatment groups were similar at baseline. Most patients were female, white, and rheumatoid factor positive and had had RA for fewer than 18 months. Patients treated with etanercept had better early responses for functional status and health-related quality of life. Compared with patients treated with MTX, patients treated with etanercept showed better improvement early in treatment (during the first 12 weeks) on the HAQ (P < 0.0001), the SF-36 physical subscale (P < 0.0001), and the SF-36 arthritis-specific health index (ASHI) (P < 0.0001). From weeks 16 to 52, these measures did not differ significantly; both groups showed similar improvement. These results may be attributed to an earlier response to etanercept than to MTX and the fact that patients were increased to the maximum MTX dose over 2 months. After 12 months, approximately 55 percent of patients in both the MTX and the 25-mg etanercept groups had at least a 0.5 unit improvement in the HAQ-DI. At 24 months, 55 percent of the 25-mg etanercept group had this level of improvement, as did 37 percent of the MTX group (P < 0.001) and 43 percent of the 10-mg etanercept group (P = 0.021).

The 52-week TEMPO RCT of RA patients who had failed previous DMARD therapy compared patients treated with etanercept (25 mg twice weekly) with those treated with MTX (20 mg/week) and those given combination therapy with both drugs.63 Baseline HAQ scores were similar for all three groups. At 52 weeks, improvement of functional status did not differ significantly between the MTX group and the etanercept group (mean HAQ scores fell from 1.7 to 1.1 and from 1.7 to 1.0, respectively; P = 0.3751). We report on comparisons of etanercept with the combination group in the KQ 2 section below on Biologic DMARD plus synthetic DMARD vs. biologic DMARD.

#### Biologic combination strategies: biologic DMARD plus synthetic DMARD vs. biologic DMARD

We found four studies, three RCTs57,60,63 and one prospective cohort study,53 comparing the combination of a biologic DMARD plus a synthetic DMARD with biologic DMARD monotherapy. The majority of these studies compared a combination of a biologic DMARD and MTX with monotherapy of the same biologic DMARD.53,57,63 One trial used sulfasalazine as a synthetic DMARD in combination with a biologic DMARD.60 We found no evidence on combination treatments of abatacept and anakinra.

##### Adalimumab plus MTX vs. adalimumab

The PREMIER study was conducted in MTX-naive patients with early (< 3 years), aggressive RA.57 This 2-year multinational study randomized 799 patients to a combination of adalimumab (40 mg every other week) and MTX (20 mg/week), adalimumab monotherapy (40 mg every other week), or MTX monotherapy (20 mg/week). After 1 year, the combination group had greater improvements in HAQ-DI scores (mean: −1.1 units) than the adalimumab group (−0.8; P = 0.002). After 2 years, the combination group (−1.0) and the adalimumab-only group (−0.9) did not differ significantly (P = 0.058) for improvements in the HAQ-DI. More patients in the combination group (72 percent) had achieved improvement of ≥0.22 (considered the clinically relevant threshold) in HAQ-DI than the adalimumab group (58 percent; P < 0.05). In addition, 33 percent of patients in the combination group and 19 percent of those in the adalimumab group had HAQ-DI scores of zero (P < 0.001). For functional capacity outcomes, we report on results of the other comparisons of the PREMIER study in the KQ 2 sections on Biologic DMARDs vs. synthetic DMARDs and Biologic DMARDs plus synthetic DMARDs vs. synthetic DMARDs.

##### Etanercept plus MTX vs. etanercept

One good-quality RCT (three publications)63–65 and one prospective cohort study53 assessed differences in efficacy between a combination of etanercept and MTX and etanercept monotherapy in patients with active, DMARD-resistant RA. The RCT showed greater effectiveness for functional capacity and quality of life for combination therapy; the cohort study found no difference.

The 52-week TEMPO trial involved 696 patients with active RA who had failed previous DMARD therapy.63–65,91 We focus here on results of the etanercept-MTX combination and the etanercept monotherapy arms; their baseline HAQ scores were similar. The combination therapy group had better improvement in functional status than the etanercept monotherapy group. At 52 weeks, patients in the combination group were significantly more likely to attain HAQ-DI scores similar to population norms (< 0.5) than patients in the monotherapy group (P < 0.05). The combination group had greater improvement in functional capacity than the monotherapy group (mean HAQ changes from 1.8 to 0.8 vs. 1.7 to 1.0; P < 0.001; mean improvement from baseline HAQ 1.0 vs. 0.70; P < 0.01). In addition, those receiving combination therapy achieved better quality-of-life scores than etanercept monotherapy (mean European Quality of Life Health Status Visual Analogue Scale [EQ 5-D VAS] 72.7 vs. 66.8; P < 0.05).64

Results of year 2 of the TEMPO trial confirmed the long-term sustainability of these findings.65 Improvement in disability (based on HAQ) remained statistically significantly better in the combination group than in the etanercept monotherapy group (P < 0.01). However, attrition was 39 percent for year 2, which could compromise the validity of the long-term results.

The prospective cohort study was based on the RADIUS program53 (see Biologic DMARD vs. biologic DMARD above). Mean percentage improvements in HAQ at 12 months did not differ between patients treated with etanercept plus MTX and those treated with etanercept monotherapy (17 percent vs. 17 percent; P = NR).

##### Etanercept plus sulfasalazine vs. etanercept

A 24-week multicenter RCT in Europe assessed the comparative efficacy of etanercept monotherapy (25 mg twice weekly), sulfasalazine monotherapy (2, 2.5, or 3 g/day), and an etanercept-sulfasalazine combination (25 mg twice weekly plus 2, 2.5, or 3 g/day) in patients with active RA who had failed previous sulfasalazine treatment.60 This study is described in greater detail in the corresponding section for KQ 1. We focus on results of the etanercept monotherapy (n = 103) and the combination (n = 101) arms. Results on patient-reported measures of functional status and quality of life (HAQ, EuroQOL VAS) were similar at baseline for patients in the two groups. The mean percentage improvement for HAQ was similar for the combination group (40.2 percent) and the etanercept group (35.3 percent; P = NS). The mean percentage improvement for health-related quality of life measured by the EuroQOL VAS was also similar (67.6 percent vs. 64.6 percent; P = NS).

##### Infliximab plus MTX vs. infliximab

No RCT compared the infliximab-MTX combination to infliximab monotherapy. The only comparative evidence comes from a cohort study from the RADIUS program (see Etanercept plus MTX vs. etanercept).53 The mean percentage improvements in the HAQ at 12 months were similar for patients treated with the infliximab-MTX combination and those treated with infliximab monotherapy (3 percent vs. 1 percent; P = NR).

#### Biologic combination strategies: biologic DMARD plus synthetic DMARD vs. synthetic DMARD

We found two RCTs57,68 and one prospective cohort study53 comparing a combination regimen of adalimumab plus MTX,57 infliximab plus MTX,53,68 or etanercept plus MTX53 with MTX monotherapy. Both RCTs were conducted in patients with early, aggressive RA. The RCTs found greater improvement in functional capacity and quality of life with combination therapies than with MTX monotherapy. The prospective cohort study found the etanercept-MTX combination improved in functional capacity more than MTX monotherapy, but the infliximab-MTX group did not differ from the MTX-only group.53

##### Adalimumab plus MTX vs. MTX

The PREMIER study was a multinational 2-year RCT of 799 patients with early, aggressive RA who had not previously received MTX; it compared adalimumab monotherapy, MTX monotherapy, and the combination of adalimumab plus MTX57 (see KQ 1 section on Biologic DMARDs plus synthetic DMARDs vs. biologic DMARDs). After 1 year, the combination group had greater improvements in HAQ-DI scores (mean: −1.1) than the methotrexate group (−0.8; P < 0.001). After 2 years, the combination (−1.0) was superior to MTX (−0.9; P < 0.05). More patients in the combination group (72 percent) had achieved improvement of ≥0.22 (considered the clinically relevant threshold) in the HAQ-DI than the MTX group (63 percent; P < 0.05). In addition, 33 percent of patients in the combination group and 19 percent of those in the MTX group had HAQ-DI scores of zero (P < 0.001). We report on results of the other comparisons of the PREMIER study in the sections on Biologic DMARDs plus synthetic DMARDs vs. biologic DMARDs and Biologic DMARDs vs. synthetic DMARDs.

##### Infliximab plus MTX vs. MTX

The ASPIRE (Active-controlled Study of Patients Receiving Infliximab for the Treatment of Rheumatoid Arthritis of Early Onset) trial enrolled 1,049 patients with early RA (disease duration < 3 years) who were MTX-naive.68 This study compared the benefits of initiating treatment with MTX (20 mg/week) alone or with a combination of MTX and infliximab (3 mg/kg or 6 mg/kg) over 52 weeks. HAQ and SF-36 scores improved significantly more in the combination groups than in the MTX-only group. The mean decrease from baseline HAQ score from week 30 to week 54 was greater for the combination groups (0.80 for 3 mg/kg group and 0.88 for the 6 mg/kg group) than for the MTX-only group (0.68; P = 0.03 and P < 0.001, respectively). In addition, more patients in the combination groups (76.0 percent and 75.5 percent, respectively) improved their HAQ scores by at least 0.22 units than in the MTX-only group (65.2 percent; P = 0.003 and P = 0.004, respectively). The mean increases in SF-36 physical component summary scores were 11.7 and 13.2 for the combination groups and 10.1 for the MTX-only group (P = 0.10 and P = 0.003, respectively). Patients on the combination treatment also had a higher probability of maintaining their employability than did those on MTX alone.69

One prospective cohort study from the RADIUS program in the United States (described above in the Etanercept plus MTX vs. etanercept section) involved patients who were initiating any new DMARD.53 The mean percentage improvements in the HAQ at 12 months were not statistically significantly different between patients treated with the infliximab-MTX combination and those treated with MTX monotherapy (3 percent vs. 7 percent; P = NS).

##### Etanercept plus MTX vs. MTX

Another prospective cohort study from the RADIUS program showed that patients treated with the etanercept-MTX combination had greater mean percentage improvements in HAQ scores at 12 months than those treated with MTX alone (17 percent vs. 7 percent; P < 0.01).53

##### Abatacept plus synthetic DMARD vs. synthetic DMARD

One RCT,129 ATTAIN (Abatacept Trial in Treatment of Anti-TNF Inadequate Responders), that did not meet our inclusion criteria for KQ 2 deserves mention here because it provides some support that combination therapy with a biologic DMARD plus a synthetic DMARD may lead to greater improvement in quality of life and functional capacity than synthetic DMARD monotherapy. It was excluded for study design because all patients were on some background synthetic DMARD and were randomized to a biologic DMARD or placebo, rather than being randomized to abatacept plus a synthetic DMARD or placebo plus a synthetic DMARD. The study enrolled adults with RA for more than 1 year who had inadequate response to 3 months of anti-TNF therapy. Patients treated with abatacept had greater improvements in quality of life (mean change on SF-36 physical component: 6.5 vs. 1.0; P < 0.0001; SF-36 mental component: 5.4 vs. 1.7, P = 0.0025) and functional capacity (mean change on HAQ-DI: −0.5 vs. −0.1; P < 0.0001) than patients treated with placebo.

### Psoriatic Arthritis: Overview

A total of six RCTS examined functional capacity or quality of life in patients being treated for psoriatic arthritis. Details are found in Evidence Table 7 in Appendix E. Table 15 provides information on comparisons made, quality-of-life outcomes, and quality ratings. The main drug classes compared include corticosteroids, synthetic DMARDs, biologic DMARDs, and combined strategies.

Table 15

Interventions, functional capacity, health-related quality of life and quality ratings of studies in adults with psoriatic arthritis

Study | Study Design N Duration | Study Population | | Comparison (dose) | QOL outcomes (HAQ, SF-36) | Quality Rating
Synthetic DMARD vs. Placebo
Kaltwasser et al., 2004^112,113^ | RCT 190 24 weeks | Active PsA; failed at least one DMARD | | LEF (100 mg/day 3 days then 20 mg/day) vs. placebo | Change in HAQ LEF significantly greater than placebo (−0.19 vs. −0.05; P = 0.0267) | Fair
Biologic DMARDs vs. Placebo
Antoni et al., 2005^115,116^ IMPACT study | RCT 104 50 weeks (16 blinded, 34 open-label) | Active PsA; failed at least one DMARD | | INF (5 mg/kg at weeks 0, 2, 6, 14 then every 8 weeks) vs. placebo 71% received a concomitant DMARD | HAQ INF significantly better than placebo (49.8 vs. −1.6; P < 0.001) | Fair
Antoni et al., 2005^117,118, 130^ IMPACT2 study | RCT 200 14 to 24 weeks | Active PsA; failed at least one DMARD | | INF (5 mg/kg at weeks 0, 2, 6, 14, 22) vs. placebo 46% received concomitant MTX | INF significantly better than placebo in HAQ improvement, At week 14: −18.4% vs. 48.6% (P < 0.001) SF-36 change from baseline, at week 24: −19.4 vs. 46 (P < 0.001) SF-36 PCS; change from baseline: to week 14: vs. 9.1 (P < 0.001) to week 24: 1.3 vs. 7.7 (P < 0.001) SF36 MCS; change from baseline to week 14: −1.2 vs. 3.8 (P = 0.001) to week 24: 0.4 vs. 3.9 (P = 0.047) No significant difference in percentage of missed workdays in past 4 weeks at 14 weeks: 13% vs. 3.7% (P = 0.138) | Fair
Mease et al., 2005^39^ | RCT 313 24 weeks | Active PsA; failed at least one DMARD | ADA (40 mg every other week) vs. placebo 51% received concomitant MTX | | SF-36 PCS; change from baseline: to week 12 and week 24 ADA 9.3 vs. placebo 1.4 (P < 0.001) SF-36 MCS; change from baseline; to week 12: 1.2 vs. 1.6 (P = NS) to week 24: 0.6 vs. 1.8 (P = NS) HAQ-DI change from baseline; to week 12 and week 24 ADA −0.4 ± 0.5 vs. placebo −0.1 ± 0.4 (P < 0.001) | Fair
Mease et al., 2000^40^ | RCT 60 12 weeks | Active PsA; failed at least one DMARD | ETA (25 mg twice a week) vs. placebo 51% received concomitant MTX | | Improvement in HAQ from baseline ETA 83% vs. placebo 3% (P < 0.0001) | Fair
Mease et al., 2004^41,47^ | RCT 205 72 weeks (24 blinded, 48 open-label) | Active PsA; failed at least one DMARD | ETA (25 mg twice a week) vs. placebo 41% received concomitant MTX | | Improvement in HAQ from baseline ETA 54% vs. placebo 6% (P < 0.0001) | Fair

ADA, adalimumab; DMARD, disease-modifying antirheumatic drug; ETA, etanercept; HAQ, Health Assessment Questionnaire; INF, infliximab; LEF, leflunomide; MTX-methotrexate; PsA, psoriatic arthritis.

### Psoriatic Arthritis: Key Points

Conclusions are limited because no head-to-head comparisons have been done for any of the drugs used to treat PsA. The available studies are all placebo-controlled studies. Leflunomide patients had better quality-of-life outcomes than those in the placebo arm. The strength of evidence about leflunomide is low. The use of biologics—adalimumab, etanercept, and infliximab—led to better outcomes than did placebo. The strength of evidence about these three biologic DMARDs is moderate.

### Psoriatic Arthritis: Detailed Analysis

#### Leflunomide

One 24-week trial (two publications) evaluated the efficacy of leflunomide against placebo in PsA patients.112,113 The study included 190 patients; PsA was defined as having at least three swollen joints and three tender or painful joints and psoriasis over at least 3 percent of the body surface area. Almost 50 percent of the patients were DMARD naive. Those who were not were required to discontinue all synthetic DMARDs, biologic agents, and investigational drugs 28 days before baseline measures were done. At 24 weeks, quality of life was significantly improved in the leflunomide group as measured by the change in HAQ scores (−0.19 vs. −0.05; P = 0.0267).

#### Adalimumab

One adalimumab trial (40 mg every other week) included 313 patients suffering from moderate to severe PsA, which was defined as having at least three swollen joints and three tender or painful joints, who had had an inadequate response or intolerance to nonsteroidal anti-inflammatory drug (NSAID) therapy.114 Patients were allowed to continue current MTX therapy as long as the dose had been stable for 4 weeks. The double-blinded phase of the study was 24 weeks, but patients who failed to achieve at least a 20 percent decrease in both swollen and tender joint counts on two consecutive visits could receive rescue therapy with corticosteroids or DMARDs. Quality of life was significantly improved as measured by the greater change in HAQ scores in patients who took adalimumab than in those who received placebo (−0.4 vs. −0.1; P < 0.001).

#### Etanercept

Two studies that examined the efficacy of etanercept included 265 patients with active PsA who were not adequately responding to conventional DMARD therapies.119,120 In both studies patients were allowed to continue MTX therapy as long as it had been stable for 4 weeks prior to enrollment. One of these trials lasted 12 weeks (N = 60);119 the other was double-blinded for 24 weeks (N = 205).120 Both studies had the same dosing regimen of 25 mg of etanercept twice weekly by subcutaneous injections. Quality of life improved significantly as measured by the HAQ in both studies. Mean improvements were 83 percent in etanercept-treated patients and three percent in placebo-treated patients in the 12-week study (P < 0.0001). In the longer study, at 24 weeks the mean improvements were 54 percent in the etanercept group and 6 percent in the placebo group (P < 0.0001).

#### Infliximab

Two studies on the use of infliximab IMPACT involved 304 patients with active PsA who were not adequately responding to conventional DMARD therapies.115,117 Both studies permitted patients to continue MTX therapy as long as it had been stable for 4 weeks before enrollment. One trial was double-blinded for 16 weeks (N = 104);115 the other was double-blinded for 24 weeks (N = 200), with crossover allowed at week 16 for nonresponders on the primary outcomes measured at the 14-week evaluation (i.e., before crossover).117 Both studies had the same dosing regimen of 5 mg/kg of infliximab at weeks 0, 2, 6, and 14; the longer study had an additional injection at week 22. Quality of life improved significantly as measured on the HAQ in both studies. Mean percentages of patients improving on the HAQ were 49.8 percent in infliximab and −1.6 percent in placebo-treated patients in the smaller study (P < 0.001). In the bigger study, at 14 weeks the mean percentages of patients improving were 48.6 percent in the infliximab group and −18.4 percent in the placebo group (P < 0.001). Additionally, the larger study found that, in the 4 weeks before week 14, 13 percent of the placebo group and 3.7 percent of the infliximab group missed work (P = 0.138).130

## Key Question 3: Harms, Tolerability, Adverse Effects or Adherence

This key question examined overall harms for both diseases. Specifically, for patients with rheumatoid or psoriatic arthritis, do drug therapies differ in harms, tolerability, or adverse effects? We first address evidence on rheumatoid arthritis and then psoriatic arthritis. For each disease, we describe overall tolerability, then specific adverse events for each drug class, followed by studies reporting on adherence for each disease. Evidence Tables 8 and 9 in Appendix E describe details about these studies, some of which were described for efficacy in KQ 1, above (i.e., Tables 10 and 11).

### Rheumatoid Arthritis: Overview

A total of 28 randomized controlled trials (RCTs), one nonrandomized controlled trial, 48 observational studies, and four systematic reviews reported on tolerability, harms and adherence (see Evidence Tables 8 and 9 in Appendix E). Table 16 provides information on Food and Drug Administration (FDA) black box warnings and warnings in bold letters as well as toxicities requiring monitoring according to the American College of Rheumatology (ACR). A black box warning is a type of warning that the FDA requires on the labels of prescription drugs that may cause serious adverse effects, and it signifies that clinical studies have indicated that the drug carries a significant risk of serious or even life-threatening side effects. Its name comes from the black border that typically surrounds the text of the warning. A bold letter (or “bolded”) warning is text prominently displayed on the main panel of the drug label that warns users about possible side effects and other cautions. Adding a bold-text warning is a lesser step than a black box warning, even if it does relate to the possibility of serious adverse effects.

Table 16

Drug toxicities and Food and Drug Administration warnings

Drug | Toxicities^†^ | Warnings Black Box | Warnings Bold Letter
Corticosteroids | Hypertension, hyperglycemia, osteoporosis | No black box warnings131–135 | Dosage requirements are variable and must be individualized on basis of disease under treatment and response of the patient131–135
Synthetic DMARDs
Leflunomide | Diarrhea, alopecia, rash, headache, theoretical risk of immunosuppression infection | Pregnancy must be excluded before start of treatment; pregnancy must be avoided during treatment or prior to completion of treatment136 | Hepatotoxicity; rare cases of severe liver injury, including cases with fatal outcome, have been reported136
Hydroxychloroquine | Macular damage | Physicians should be completely familiar with complete contents of package insert before prescribing137 | No bold letter warnings137
Methotrexate | Myelosuppression, hepatic fibrosis, cirrhosis, pulmonary infiltrates or fibrosis | Bone marrow, liver, lung, and kidney toxicities; hepatotoxicity, fibrosis and cirrhosis; chronic interstitial pneumonitis; diarrhea and ulcerative stomatitis; malignant lymphomas; severe to fatal skin reactions; fatal opportunistic infections; fetal death and/or congenital anomalies138 | No bold letter warnings138
Sulfasalazine | Myelosuppression | No black box warning139 | No bold letter warnings139
Biologics DMARDs
Abatacept | No ACR recommendations about monitoring | No black box warning142 | No bold letter warnings142
Adalimumab | No ACR recommendations about monitoring | Risk of infections (TB, invasive fungal infections, other opportunistic infections); some infections have been fatal; patients should be evaluated for latent TB; patients should be monitored for signs of active TB during treatment143 | Should not be initiated in patients with active infections (chronic or localized); patients who develop new infections during treatment should be monitored closely; physicians should exercise caution when considering treating patients with history of recurrent infection or underlying conditions which may predispose them to infections; serious infections observed in clinical studies with concurrent use of anakinra; concurrent use of anakinra is not recommended143
Anakinra | No ACR recommendations about monitoring | No black box warning144 | Increased incidence of serious infections; discontinue if patient develops serious infection; should not be initiated in patients with active infections; safety and efficacy in immunosuppressed patients or patients with chronic infections have not been evaluated; concurrent therapy with etanercept is not recommended144
Etanercept | None recognized by ACR guidelines | No black box warning145 | Serious infections and sepsis, including fatalities; TB; should not be taken by patients with active infections; malignancies; neurologic events; should be discontinued if patient develops serious infection or sepsis; exercise caution when considering prescribing to patients with history of recurring infections or with underlying conditions which may predispose patient to infection, such as advanced or poorly controlled diabetes; concurrent therapy with anakinra is not recommended145
Infliximab | None recognized by ACR guidelines^‡^ | Increased risk for infections, including progression to serious infections leading to hospitalization or death; these infections include bacterial sepsis, TB, invasive fungal and other opportunistic infections; increased risk for TB; patients should be closely monitored for signs and symptoms of infection during and after treatment; patients should be evaluated for TB risk factors and tested for latent TB prior to treatment; fatal hepatosplenic T-cell lymphoma reported in adolescent and young adult patients with Crohn’s disease146 | Some serious infections resulted in patients on concomitant immunosuppressive therapy; some patients were hospitalized or had fatal outcome from infections while treated with infliximab alone; should not be given to patients with clinically important, active infection; new infections should be closely monitored; treatment should be discontinued if patient develops serious infection; TB, histoplasmosis, coccidioidomycosis, listeriosis, pneumocystosis, other bacterial, mycobacterial and fungal infections observed; monitor patients for signs and symptoms of TB146
Rituximab | No ACR recommendations about monitoring | Fatal infusion reactions; these fatal reactions followed an infusion reaction complex, which included hypoxia, pulmonary infiltrates, acute respiratory distress syndrome, myocardial infarction, ventricular fibrillation, or cardiogenic shock; TLS—acute renal failure requiring dialysis; severe mucocutaneous reactions; PML—JC virus infection resulting in PML and death has been reported147 | No bold label warnings147

† Toxicities requiring monitoring according to ACR guidelines, 2002.^140^

‡ ACR issued a warning for hepatosplenic T-cell lymphoma with infliximab use.141

ACR: American College of Rheumatology; PML: progressive multifocal leukoencephalopathy; TB: tuberculosis; TLS: tumor lysis syndrome.

As with earlier KQs, the main drug classes examined are corticosteroids, synthetic DMARDs, and biologic DMARDs.

Most studies that examined the comparative efficacy of our drugs of interest also determined their harms. Methods of adverse events assessment, however, differed greatly. Few studies used objective scales such as the UKU-SES (Utvalg for Kliniske Undersogelser Side Effect Scale) or the adverse reaction terminology from the World Health Organization (WHO). Most studies combined patient-reported adverse events with a regular clinical examination by an investigator. Often, determining whether assessment methods were unbiased and adequate was difficult. Rarely were adverse events pre-specified and defined. Short study durations and small sample sizes additionally limited the validity of adverse events assessment with respect to rare but serious adverse events.

Because few studies used the term serious adverse events as defined by the International Conference on Harmonisation of Technical Requirements for Registration of Pharmaceuticals for Human Use,148 we describe serious adverse events as the individual studies identified and reported them.

### Rheumatoid Arthritis: Key Points

#### Tolerability and adverse events

##### Corticosteroids

Comparative tolerability and overall adverse events between corticosteroids were similar but data were limited to one 3-month trial.29 The strength of evidence is low.

Corticosteroid use significantly predicted the risk of serious infections, as compared with methotrexate (MTX), sulfasalazine, hydroxychloroquine, leflunomide, and etanercept, in one long-term retrospective study (hazard ratio [HR] 1.56; 95% CI, 1.20–2.04).149 The strength of evidence is low.

#### Synthetic DMARDs and combinations

Three efficacy trials and one meta-analysis indicated similar tolerability and discontinuation rates of leflunomide, MTX, and sulfasalazine in data up to 2 years.32,34,35,37 The strength of evidence is moderate.

The proportion of patients who stayed on MTX was higher than the proportion remaining on sulfasalazine at 5 years in one meta-analysis of 71 RCTs and 88 observational studies (36 percent vs. 22 percent, P = NR).150 The strength of evidence is moderate.

Five studies involving combinations of two or three DMARDs, including sulfasalazine, MTX, hydroxychloroquine, and etanercept (a biologic DMARD), vs. one or two DMARDs have similar withdrawal rates attributable to adverse events.30,31,33,46,151 Although discontinuation rates were similar for these pharmaceuticals, the number of patients with adverse events (nausea, erythema, elevated transaminases) were higher in two studies of sulfasalazine plus MTX than in monotherapy with either drug.31,33 The level of evidence is moderate.

Three studies of combinations including prednisone with one or more DMARDs indicated similar discontinuation rates between groups.42,44,47 The level of evidence is moderate.

Hepatic events appeared to be similar among patients treated with MTX, leflunomide, hydroxychloroquine, sulfasalazine, infliximab, and etanercept in two retrospective studies over 2 years to 3 years.152,153 Longer term evidence is lacking. The level of evidence is low.

In one 5-year retrospective cohort, interstitial lung disease appeared to be significantly higher with leflunomide use than with use of other DMARDs (RR, 1.9; 95% CI, 1.1–3.6) but not significantly higher with use of either MTX (RR, 1.4; 95% CI, 0.8–2.3) or biologic DMARDs (RR, 0.8; 95% CI, 0.4–1.5).154 The level of evidence is low.

In three cohort studies, infection risk was elevated in patients receiving prednisone and possibly MTX and leflunomide compared with the risk in patients receiving other DMARDs.149,152,155 The level of evidence is low.

Estimates of cancer risk were limited to retrospective cohort studies. No risk of lymphoma was found for MTX or sulfasalazine in a 30-year retrospective cohort.156 Among RA patients, the development of nonmelanoma skin cancer was associated with use of prednisone (HR 1.28; P = 0.014).157

#### Biologic DMARDs

In efficacy studies, biologic DMARDs were generally well tolerated. Injection site reactions (adalimumab, anakinra, etanercept) and infusion reactions (abatacept, infliximab, rituximab) were the two most commonly and consistently reported adverse events. Some infusion reactions appeared to be more serious than injection site reactions. Overall, 0.5 percent of patients treated with infliximab had severe acute reactions that resembled acute anaphylactic conditions or led to convulsions.158 Fatal infusion reactions have also occurred with rituximab.147 The strength of evidence is moderate.

One nonrandomized, open-label 12-month trial directly compared the tolerability of two biologic DMARDs.159 It did not report any differences in harms between etanercept and infliximab. Evidence from placebo-controlled trials and observational studies is insufficient to draw conclusions about the comparative tolerability and safety of biologic DMARDs. The strength of the evidence is low.

In efficacy trials, injection site reactions were the most common reason for discontinuation because of adverse events.49 Incidence rates appeared to be significantly higher with anakinra than with anti-TNF drugs.49 In a large retrospective cohort study, anakinra led to statistically significantly higher discontinuation rates (41 percent) than etanercept (31 percent; P = 0.004) and infliximab (35 percent; P = 0.03).67 A prospective cohort study indicated that etanercept had statistically significantly lower discontinuation rates than infliximab during 60 months of follow-up (data NR; P < 0.001).52 The strength of the evidence is moderate.

Two trials indicated that a combination treatment of two biologic DMARDs can lead to substantially higher rates of severe adverse events than biologic DMARD monotherapy.59,160 The evidence, however, is limited to combinations of anakinra with etanercept and abatacept with anakinra, adalimumab, etanercept, or infliximab. The strength of the evidence is moderate.

Five long-term extension studies of adalimumab,83 anakinra,85 etanercept,161 and infliximab101,162 indicated that the rate of adverse events does not increase over time. The strength of the evidence is moderate. No evidence is available on the long-term tolerability of abatacept and rituximab.

The risk for long-term, rare but serious adverse events such as serious infections, malignancies, congestive heart failure, or autoimmunity is a cause of concern for all biologic DMARDs. We could not, however, reliably assess the comparative risk among biologic DMARDs for most serious adverse events because of insufficient evidence. One prospective cohort study suggested that risks do not differ for adalimumab, etanercept, and infliximab;163 it showed that, compared with synthetic DMARDs as a class, anti-TNF drugs as a class did not lead to a higher overall risk for serious infections (incidence rate ratio [IRR], 1.03; 95% CI, 0.68–1.57). The strength of the evidence is low.

Two studies indicated that the general risk of biologic DMARDs for serious infections is dose dependent. The evidence, however, is limited to adalimumab164 and infliximab.107 The strength of the evidence is moderate.

Three observational studies indicated that infliximab might have a higher risk of granulomatous infections than etanercept.165–167 The strength of the evidence is low.

Hepatotoxicity has been reported for infliximab but not for other biologic DMARDs. The strength of the evidence is low.146

#### Adherence

Few efficacy studies reported rates of adherence. Efficacy trials do not indicate any differences in adherence among drug therapies used to treat RA. However, the quality of reporting and assessment of adherence was limited.

Findings from highly controlled efficacy studies may have limited generalizability to “real world” practice, especially because of the overall short duration of these trials. The evidence is insufficient to draw any conclusions about adherence from effectiveness studies.

A review of a large, managed care database suggested that infliximab might have greater adherence than etanercept or MTX.168 In contrast, however, an observational study that suggested that etanercept had a better response rate than infliximab attributable to greater adherence.52 However, as noted below, measurements of adherence are different between these two studies. Strength of evidence is low for efficacy and effectiveness studies.

### Detailed Analysis

Tables 17, 18, and 19 provide information on harms for the three main categories of drugs covered in this review. We cover overall tolerability, then specific adverse events. When sufficient data are available, we break out specific events by type (e.g., hepatic or infection).

Table 17

Comparative harms in patients with rheumatoid arthritis treated with corticosteroids

Study | Study Design N Duration | Study Population | Drug | Results | Quality Rating
Corticosteroids Overall Tolerability
Kirwan et al., 2004^29^ | RCT 143 12 weeks | Active RA | BUD PNL | Similar in all groups | Fair
Corticosteroids Adverse Events
Doran, et al., 2002^149^ | Retrospective cohort 609 39 years | RA patients | Several synthetic DMARDs, corticosteroids | In patients hospitalized for infection, corticosteroid use increased risk (HR, 1.56; 95% CI, 1.20–2.04) | Fair
Saag et al., 1994^169^ | Retrospective cohort 224 ≥ 1 year | RA patients on low-dose PRED (15 mg/day or less) | PRED No PRED | PRED 10 mg to 15 mg/day most related to development of AE (OR, 32.3; 95% CI, 4.6–220) PRED 5 mg to 10 mg/day (OR, 4.5; 95% CI, 2.1–9.6) No increase in AE for PRED < 5 mg/day Fracture: OR, 3.9 (95% CI, 0.8–18.1; P < 0.09) First infection: OR, 8.0 (95% CI, 1.0–64.0; P < 0.05) First GI event: OR, 3.3 (95% CI, 0.9–12.1; P < 0.07) | Fair

AE, adverse event; BUD, budesonide; CI, confidence interval; DMARD, disease-modifying antirheumatic drugs; GI, gastrointestinal; mg, milligram; HR, hazard ratio; OR, odds ratio; PNL, prednisolone; PRED, prednisone; RA, rheumatoid arthritis; RCT, randomized controlled trial.

Table 18

Comparative harms in patients with rheumatoid arthritis treated with synthetic DMARDs

Study | Study Design N Duration | Study Population | Drug | Results | Quality Rating
Synthetic DMARDs Overall Tolerability
Cannon, et al., 2004^152^ | Retrospective cohort 40,594 2 years (claims database) | RA pts | LEF, MTX, other DMARD | AE rates in LEF, LEF + MTX were lower than or similar to AE rates for MTX and other DMARDS | Fair
Emery et al., 2000^32^ | RCT 999 1 year with optional 2nd year | RA 4 months to 10 years | LEF, MTX | Frequency of SAEs similar between groups | Fair
Maetzel, et al., 2000^150^ | Meta-analysis (RCT and observational) 159 studies MTX = 2,875 SSZ = 1,418 5 years | RA pt studies including withdrawal information | MTX SSZ HCQ (and gold) | Withdrawals due to toxicity for 5 years: MTX 35%, SSZ 52% Pts treated with SSZ were 1.68 times more likely to fail therapy due to toxicity than MTX (RR, 1.68; P < 0.0001) | Fair
Osiri et al., 2003^34^ | Systematic review and meta-analysis 1,732 2 years | Active RA | LEF, MTX LEF, SSZ | Discontinuation rates from AEs were similar for LEF, MTX and SSZ | Good
Smolen et al., 1999^35^ | RCT 358 24 weeks | Active RA | LEF, SSZ | Withdrawal due to AEs 14% vs. 19% | Fair
Strand, et al., 1999^37,38^ | RCT 482 12 months (1 year continuation) | RA for at least 6 months, MTX-naive | LEF, MTX | AEs constant over time LEF and MTX 12 months: Higher discontinuation rate for LEF (22% vs. 10.4%, P = NR) | Fair
Synthetic DMARD Combinations Overall Tolerability
Boer et al., 1997^39^ COBRA study | RCT 155 56 weeks | Early RA, DMARD naive | PNL taper + MTZ + SSZ vs. SSZ | Lower withdrawal rate due to AEs (2.6% vs. 7.6%, P = NR) | Fair
Capell et al., 2007^30^ | RCT 165 (Phase 1 run-in: 687) 6 months (18 months for those with DAS ≥2.4 at 6 months) | Active RA | SSZ + MTX vs. SSZ or MTX | Similar withdrawal rate due to AEs | Fair
Dougados et al., 1999^31^ | RCT 209 (146) 52 weeks (5 year followup) | DMARD naive, early RA | SSZ +MTX vs. SSZ or MTX | Discontinuation rate due to AEs similar among groups AEs higher in SSZ+MTX vs. SSZ vs. MTX (91% vs. 75% vs. 75%, P = 0.025) | Fair
Goekoop-Ruiterman et al., 2005^42^ BeSt study | RCT 508 12 months | Early RA | Sequential monotherapy (starting with MTX) vs. step-up combination therapy (MTX, then SSZ, then HCQ, then PRED) vs. combination (MTZ, SSZ, tapered high-dose PRED) vs. combination with INF (3 mg/kg – could be titrated to 10 mg/kg based on DAS) | No significant differences in serious AEs in all groups | Good
Haagsma et al., 1997^33^ | RCT 105 52 weeks | DMARD naive, early RA | SSZ + MTX vs. SSZ or MTX | No significant difference in number of withdrawals due to AEs | Fair
Korpela et al., 1999^44^ FIN-RACo study | RCT 199 24 months | Early RA | MTX + HCQ + SSZ + PNL vs. DMARD ± PNL | Frequency of serious AEs similar in both groups Discontinuation due to AEs similar in both groups | Fair
O’Dell et al., 2006^151^ | Prospective cohort 119 48 weeks | Active RA, previous use of DMARDs | ETA +SSZ vs. ETA + HCQ | Similar discontinuation rates due to AEs | Fair
O’Dell et al., 2002^45^ | RCT 171 2 years | RA pts not previously treated with combination drugs | MTX + SSZ + HCQ vs. MTX + HCQ vs. MTX + SSZ | Similar withdrawal rate due to AEs across groups | Good
O’Dell et al., 1996^46^ | RCT 102 2 years | RA and poor response to at least 1 DMARD | MTX + SSZ+ HCQ vs. MTX vs. SSZ + HCQ | Similar withdrawal rate due to AEs across groups | Good
Svensson et al., 2005^47^ | Open-label RCT 250 2 years | Early RA | DMARD + PNL vs. DMARD | Similar number of discontinuations between groups | Fair
Svensson et al., 2003^170^ | Open-label RCT 245 2 years | Early RA | MTX + PRED SSZ + PRED | Lower withdrawal rate due to AEs or inefficacy for PRED + MTX group vs. PRED + SSZ group (11.5% vs. 33.3%, P = 0.0005) | Fair
Synthetic DMARDs Adverse Events
Hepatic Event
Cannon et al., 2004^152^ | Retrospective cohort 40,594 2 years (claims database) | RA pts | LEF, MTX, other DMARD | Hepatic event: LEF 4.1/1,000PY, MTX 6.2/1,000PY, Other 4.2/1,000PY, LEF + MTX 4.6/1,000PY | Fair
Suissa et al., 2004^153^ | 2 retrospective cohorts (claims data) 41,885 3 years | RA diagnosis | LEF, biologics, traditional DMARDs, MTX | Serious hepatic events compared with MTX: LEF rate ratio: 0.9 (95% CI, 0.2–4.9), traditional DMARD: 2.3 (95% CI, 0.8–1.4), biologic DMARD: 5.5 (95% CI, 1.2–24.6) | Fair
Interstitial Lung Disease
Suissa et al., 2006^154^ | Retrospective cohort (claims data) 62,734 5 years | RA diagnosis, on DMARD | MTX, LEF, biologics, traditional DMARDs | Risk of interstitial lung disease in LEF compared to other DMARDs: OR, 1.9 (95% CI, 1.1–3.6). No elevation noted in LEF pts with no history of MTX or no history of interstitial lung disease | Fair
Infection
Cannon et al., 2004^152^ | Retrospective cohort< br> 40,594 2 years (claims database) | RA pts | LEF, MTX, other DMARD | Respiratory infection: LEF 20/1,000PY, MTX 38.9/1,000PY, Other 36.9/1,000PY | Fair
Doran et al., 2002^149^ | Retrospective cohort 609 39 years | RA pts | Several synthetic DMARDs, corticosteroids | Use of corticosteroids increased risk of hospitalization for infection (HR 1.56; 95% CI, 1.20–2.04) | Fair
Wolfe et al., 2006^155^ | Prospective cohort 16,788 3.5 years | RA diagnosis | PRED, LEF, SSZ, MTX, ETA, INF, ADA | Risk for hospitalization for pneumonia: PRED HR 1.7 (95% CI, 1.5–2.0), LEF HR 1.2 (95% CI, 1.0–1.5). No significant differences for SSZ, MTX | Fair
Malignancies
Baecklund et al., 2006^156^ | Retrospective cohort 756 30 years | RA pts with diagnosis of lymphoma | MTX, SSZ | No significant risk for lymphoma for MTX or SSZ | Good
Chakravarty et al., 2005^157^ | Retrospective cohort 15,789 (RA) 4 years | RA pts | PRED, LEF, MTX | PRED was associated with increased risk for non melanoma skin cancer PRED: HR 1.28 (95% CI, 1.05–1.55, P = 0.014) | Fair

3x, three times; ADA, adalimumab; AEs, adverse events; AERS, adverse events reporting system; AKA, anakinra; CHF, congestive heart failure; CI, confidence interval; DAS; DMARD, disease-modifying antirheumatic drug; ETA, etanercept; GI, gastrointestinal; HCQ, hydroxychloroquine; HR, hazard ratio; INF, infliximab; LEF, leflunomide; LFT, liver function test; mg/kg, milligram/kilogram; MTX, methotrexate; N/A, not applicable; NR, not reported; OR, odds ratio; PNL, prednisolone; PRED, prednisone; Pts, patients PY, person years; RA, rheumatoid arthritis; RCT, randomized controlled trial; RR, relative risk; SAEs, serious adverse events; SSZ, sulfasalazine; TB, tuberculosis; TNF, tumor necrosis factor; txt, treatment; vs., versus.

Table 19

Comparative harms in patients with rheumatoid arthritis and treated with biologic DMARDs

Study | Study Design N Duration | Study Population | Drug | Results | Quality Rating
Biologic DMARDs Overall Tolerability
Bathon et al., 2000^54–56^ ERA study | RCT 632 (512) 12 months (1 year open-label extension) | Early, aggressive RA; MTX-naive | ETA, MTX | Significantly more patients on MTX than on ETA had nausea (29% vs. 15%; P < 0.05) or mouth ulcers (14% vs. 5%; P < 0.05) | Fair
Breedveld et al., 2006^57^ PREMIER study | RCT 799 2 years | Early, aggressive RA; MTX-naive | ADA, MTX, ADA + MTX | No statistically significant differences in adverse events | Fair
Combe et al., 2006^60^ | RCT 260 24 weeks | Active RA despite SSZ treatment | ETA, SSZ, ETA+SSZ | Significantly more infections in ETA and ETA+SSZ than in SSZ group (47% vs. 31% vs. 13%; P < 0.05) | Fair
Edwards et al., 2004^61^ | RCT 161 24 weeks | Active RA despite MTX treatment | RIT, MTX, RIT+MTX, RIT+CYP | No significant differences in adverse events | Fair
Feltelius et al., 2005^161^ | Case series 1,073 2 years | Pts with RA initiating ETA therapy | ETA | Incidence of serious adverse events remained constant over time | Fair
Fleischmann et al., 2003^171^ | RCT 1,414 6 months | Pts with active RA despite MTX treatment | AKA | Higher rates of injection site reactions with AKA than placebo. Otherwise no statistically significant differences in adverse events | Fair
Fleischmann et al., 2006^172^ | Open-label extension of RCT 1,346 Up to 3 years | Pts with active RA despite MTX treatment | AKA | Incidence of serious adverse events remained constant over time | Fair
Flendrie et al., 2003^173^ | Retrospective cohort study 230 NR | Pts with RA initiating therapy with biologic DMARDs | ADA, ETA, INF | No significant differences in discontinuation rates among anti-TNF drugs | Fair
Furst et al., 2003^80^ STAR study | RCT 636 6 months | Pts with active RA despite MTX treatment | ADA | No statistically significant differences in adverse events | Fair
Gartlehner et al., 2006^49^ | Meta-analysis 5,248 NA | Patients who have failed MTX treatment; mean disease duration: varied | ADA, AKA, ETA, INF | Higher rates of injection site reactions for AKA than ADA and ETA (56% vs. 19% vs. 25%) | Good
Geborek et al., 2002^50^ | Nonrandomized, open-label trial 369 12 months | Population-based; active RA; had failed at least 2 DMARDs | ETA, LEF, INF | No statistically significant differences in adverse events | Fair
Genovese et al., 2002^55^ | Open-label extension of RCT 632 2 years | Pts with early, aggressive RA; MTX-naive | ETA | Incidence of serious adverse events remained constant over time | Fair
Genovese et al., 2004^59^ | RCT 242 24 weeks | Inadequate control of disease with MTX | ETA, ETA+AKA | Significantly higher rates of serious adverse events in combination group | Fair
Genovese et al., 2005^56^ | Uncontrolled extension of RCT 369 5 years | Pts with early, aggressive RA; MTX-naive | ETA | Rates of serious adverse events did not increase with long-term exposure | Fair
Klareskog et al., 2004^63–65^ TEMPO study | RCT 686 (503 for 2 year results) 52 weeks (2 years, 100 weeks) | Active RA; had failed at least 2 DMARDs | ETA, MTX, ETA+MTX | No statistically significant differences in adverse events | Good
Langer et al., 2003^174^ | Post marketing surveillance 454 6 months | Pts with RA, initiating AKA treatment | AKA | Rate of adverse events was generally similar to those reported in efficacy trials; lower rates of injection site reactions than in clinical trials | Fair
Maini et al., 2004^101^ | Open-label extension of RCT 259 2 years | Pts with active RA despite MTX treatment | INF | Incidence of serious adverse events remained constant over time | Fair
Moreland et al., 2006^162^ | Open-label extension of clinical trials 714 | Pts treated with ETA | ETA | Incidence of serious adverse events remained constant over time | Fair
Nuki et al., 2002^85^ | Uncontrolled extension of RCT 309 19 months | Pts with active RA despite MTX treatment | AKA | Incidence of serious adverse events remained constant over time | Fair
O’Dell et al., 2006^151^ | Nonrandomized, open-label trial 119 | Pts with active RA despite treatment with SSZ, HCQ, or gold | ETA + SSZ ETA + HCQ ETA + gold | No differences in adverse event rates among 3 treatment groups | Fair
Schaible et al., 2000^158^ | Retrospective data analysis of clinical trials 913 12 weeks to 3 years | Pts with RA or Crohn’s disease | INF | 17% of pts on INF in clinical trials had acute infusion reactions | Fair
Schiff et al., 2006^175^ | Retrospective data analysis of clinical trials; post marketing surveillance 10,050 12,506 pt years | Pts treated with ADA | ADA | Incidence of serious adverse events remained constant over time | Fair
St. Clair et al., 2004^68,69^ ASPIRE study | RCT 1,049 54 weeks | Early, aggressive RA; MTX-naive | MTX, INF, INF+ MTX | Significantly more patients in the INF than in the MTX group had more than one serious infection (5.3 vs. 2.1%; P < 0.05) | Fair
Van Riel et al., 2006^66^ | Open-label RCT 315 16 weeks | Inadequate control of disease with MTX | ETA, ETA+MTX | No statistically significant differences in adverse events | Fair
Wasserman et al., 2004^176^ | Prospective cohort study 113 15 months | Pts with RA starting INF treatment in a clinical care setting | INF | 53% of pts on INF experienced at least one infusion reaction | Fair
Weinblatt et al., 2006^160^ ASSURE study | RCT 1,456 1 year | Pts with active RA despite background biologic or synthetic DMARD treatment | ABA | Higher incidence of serious adverse events in pts on ABA and a biologic background DMARD | Fair
Weinblatt et al., 2006^83^ | Uncontrolled extension of RCT 162 3.4 years | Pts with active RA despite MTX treatment | ADA | Incidence of serious adverse events remained constant over time | Fair
Westhovens et al., 2006^107^ START study | RCT 1,084 22 weeks | Pts with active RA despite MTX treatment | INF + MTX, MTX | Risk of serious infections was similar between placebo and 3 mg/kg infliximab. 10 mg/kg infliximab led to increased risk of serious infections | Good
Zink et al., 2005^67^ | Retrospective cohort study 1,523 1 year | Pts with RA who had a change in treatment regimen | AKA, ETA, INF, LEF | Significantly higher overall discontinuation rates for AKA than ETA and INF after 12 months; no differences in discontinuation rates due to adverse events | Good
Biologic DMARDs Adverse Events
Infectious Diseases
Askling et al., 2005^177^ | Retrospective cohort study 62,321 467,770 person-years | Pts with RA in daily clinical care in Sweden | ETA, INF | 4-fold increase of risk for TB for ETA and INF compared with conventional DMARDs | Good
Bergstrom et al., 2004^178^ | Retrospective cohort study 985 3 years | Pts with inflammatory arthritis in daily clinical care, U.S. | ETA, INF | Pts treated with INF or ETA are more likely to develop symptomatic coccidioidmoycosis than pts on synthetic DMARDs | Fair
Bongartz et al., 2006^164^ | Meta-analysis 5,014 3 to 12 months | Pts with active RA despite MTX treatment | ADA, INF | Statistically significantly higher risk of serious infections for ADA and INF compared with placebo (OR, 2.0; 95% CI, 1.3–3.1) | Fair
Dixon et al., 2006^163^ | Prospective cohort study 8,973 11,220 pt-years | Pts with active RA despite MTX treatment | ADA, ETA, INF | No differences among anti-TNF drugs for risk of serious infections. Similar risk for serious infections between anti-TNF drugs and synthetic DMARDs | Fair
Gomez-Reino et al., 2003^179^ | Retrospective cohort study 1,540 1.1 years | Pts with RA in daily clinical care in Spain | ETA, INF | Higher risk of TB for ETA and INF than synthetic DMARDs | Fair
Keane et al., 2001^180^ | Database analysis 70 cases of TB NA, AERS data | Pts treated with INF | INF | TB may develop soon after initiation of INF treatment | Fair
Lee et al., 2002^166^ | Database analysis 10 cases of histoplasmosis NA, AERS data | Pts treated with ETA and INF | ETA, INF | Histoplasmosis infections may be a serious complication of treatment with anti-TNF agents; pts on INF had a higher rate of infections than pts on ETA | Fair
Listing et al., 2005^181^ | Prospective cohort study 1,529 Up to 12 months | Pts with RA in daily clinical care in Germany | AKA, ETA, INF | Higher risk of infections for AKA, ETA, INF compared with DMARDs | Fair
Mohan et al., 2004^182^ | Database analysis 25 cases of TB NA, AERS data | Pts treated with ETA | ETA | Median interval between first dose and diagnosis of TB was 11.5 months | Fair
Salliot et al., 2006^183^ | Case series 709 NR | Pts with different rheumatic diseases; primary care-based cohort | ADA, ETA, INF | Rates of serious infections in daily practice were higher than ones reported in efficacy trials | Fair
Slifman et al., 2003^167^ | Database analysis 15 cases of listeria infection NA, AERS data | Pts treated with ETA and INF | ETA, INF | Pts on INF had a higher rate of infections than pts on ETA | Fair
Wallis et al., 2004^165^ | Database analysis 649 cases of granulomatous infections NA, AERS data | Pts treated with ETA and INF | ETA, INF | Pts on INF had a higher rate of granulomatous infections than pts on ETA | Fair
Wolfe et al., 2004^184^ | Prospective cohort study with historic control 17,242 3 years | Pts with RA in daily clinical care in U.S. | INF, synthetic DMARDs | TB was more common in pts treated with INF than with synthetic DMARDs | Fair
Wolfe et al., 2006^155^ | Prospective cohort study 16,788 3.5 years | Pts with RA | ADA, ETA, INF | No increased risk for hospitalization for pneumonia for ADA, ETA, and INF compared to a historic control | Fair
Lymphoma and Other Malignancies
Askling et al., 2005^185^ | Retrospective cohort study 60,930 NR | Pts with RA in daily clinical care in Sweden | ADA, ETA, INF, synthetic DMARDs | No increase in solid cancers for pts treated with anti-TNF drugs | Fair
Askling et al., 2005^186^ | Retrospective cohort study 53,067 NR | Pts with RA in daily clinical care in Sweden | ADA, ETA, INF, synthetic DMARDs | No increase in lymphoma for pts treated with anti-TNF drugs | Fair
Bongartz et al., 2006^164^ | Meta-analysis 5,014 3 to 12 months | Pts with active RA despite MTX treatment | ADA, INF | Statistically significantly higher risk of malignancies for ADA and INF compared with placebo (OR, 3.3; 95% CI, 1.2–9.1) | Fair
Brown et al., 2002^187^ | Database analysis AERS 26 cases of lymphoma NA, AERS data | RA or CD pts treated with ETA and INF | INF, ETA | Median interval between initiation of therapy and lymphoma 8 weeks; some spontaneous remissions after discontinuation of therapy reported | Fair
Chakravarty et al., 2005^157^ | Retrospective cohort study 15,789 NR | RA or osteoarthritis pts treated with ETA or INF | ETA, INF | Statistically significant association between anti-TNF (HR 1.97; 95% CI, NR; P = 0.001) and corticosteroid (HR 1.28; 95% CI, NR; P = 0.014) use and nonmelanoma skin cancer | Fair
Geborek et al., 2005^159^ | Retrospective cohort study 1,557 5,551 pt-years | Pts with RA in daily clinical care in Sweden | ETA, INF | Higher risk of lymphoma for anti-TNF drugs than synthetic DMARDs | Fair
Lebwohl et al., 2005^188^ | Post marketing database review 1,442 3.7 years | Pts with RA treated with ETA | ETA | No increase in the incidence of cutaneous squamous cell carcinoma for ETA-treated pts | Fair
Setoguchi et al., 2006^189^ | Retrospective cohort study 8,458 33,240 pt-years | Pts with RA in daily clinical care in U.S. and Canada | ADA, ETA, INF | No increased risk of hematologic and overall malignancies for pts treated with anti-TNF drugs compared with those on synthetic DMARDs | Good
Wolfe et al., 2004^190^ | Prospective cohort study with external control 18,572 Up to 3 years | Pts with RA in daily clinical care in U.S. | INF, ETA | Pts with RA treated with INF or ETA are more likely to develop lymphoma than the general population | Fair
Congestive Heart Failure
Chung et al., 2003^191^ | RCT 150 28 weeks | Pts with CHF | INF | INF (10 mg)-treated pts were more likely to die than placebo-treated pts | Fair
Jacobsson et al., 2005^192^ | Retrospective cohort study 983 NR | Pts with RA in daily clinical care in Sweden | ETA, INF | Pts on anti-TNF treatment had a lower rate of cardiovascular events than pts on traditional RA therapy | Fair
Kwon et al., 2003^193^ | Database analysis AERS 47 cases of CHF NA, AERS data | Pts on ETA or INF therapy | ETA, INF | Most pts with CHF did not have preexisting conditions | Fair
Wolfe et al., 2004^194^ | Retrospective cohort study 13,171 2 years | Pts with RA in daily clinical care in U.S. | ADA, ETA, INF | Pts on anti-TNF treatment had a lower rate of CHF than pts on traditional RA therapy | Fair
Demyelination
Mohan et al., 2001^195^ | Database analysis AERS 19 cases of demyelination NA, AERS data | Pts on anti-TNF therapy | ETA, INF | Discontinuation of therapy led to partial or complete resolution of all cases | Fair
Other Adverse Events
De Bandt et al., 2005^196^ | Case series 22 cases with lupus syndrome | Pts with RA in daily clinical care in France | ETA, INF | Similar incidence of lupus syndrome between ETA and INF | Fair
Flendrie et al., 2005^197^ | Prospective cohort study with historic control 578 911 pt-years | Pts with RA starting anti-TNF therapy | ADA, ETA, INF | Higher rates of dermatological conditions in pts on anti-TNF drugs compared to DMARDs | Fair
Shin et al., 2006^198^ | Database analysis AERS 15 cases of Guillain-Barre and Miller Fisher syndromes NA, AERS data | Pts on anti-TNF therapy | ADA, ETA, INF | Demyelination is a potential adverse event of anti-TNF therapy | Fair

ABA, abatacept; ADA, adalimumab; AERS, adverse events reporting system; AKA, anakinra; CD, cardiovascular disease; CHF, congestive heart failure; CI, confidence interval; CYP, cyclophosphmide; DMARD, disease-modifying antirheumatic drug; ETA, etanercept; HCQ, hydroxychloroquine; HR, hazard ratio; INF, infliximab; LEF, leflunomide; mg/kg, milligram/kilogram; MTX, methotrexate; N/A, not applicable; NR, not reported; OR, odds ratio; Pts, patients; RA, rheumatoid arthritis; RCT, randomized controlled trial; RIT, rituximab; SSZ, sulfasalazine; TB, tuberculosis; TNF, tumor necrosis factor; US, United States.

#### Corticosteroids: overall tolerability

Corticosteroids are associated with several well-known side effects (noted already in Table 16). The prescription information for long-term use of corticosteroids highlights precautions including osteoporosis with secondary fractures, infection, glucose intolerance, peptic ulcer disease, gastrointestinal bleeding, cataracts and glaucoma.131–135 Table 17 describes relevant studies for harms from corticosteroids.

Comparatively, the tolerability for corticosteroids appears to be similar between groups, although the information is limited by short study duration and the fact that only one study is available. One head-to-head RCT, described more in detail for KQ 1, compared budesonide (3 mg/day), high-dose budesonide (9 mg/day), prednisolone (7.5 mg/day), and placebo over 12 weeks.29 Overall rates of adverse events were similar among groups (89 percent, 3 mg/day budesonide; 94 percent, 9 mg/day budesonide; 85 percent, prednisone; 90 percent, placebo; P = NR). Few adverse events caused patients to discontinue the drug; gastrointestinal symptoms, heart symptoms, and mood swings or insomnia were similar in all patient groups (P = NR).

#### Corticosteroids: specific adverse events

We found no comparative study of corticosteroids directly assessing specific serious adverse events. One study of a retrospective 39-year cohort of 609 RA patients in Rochester, Minnesota, examined the predictors of serious infections requiring hospitalization.149 Corticosteroids (intravenous [IV] or intramuscular [IM]), various synthetic DMARDS including MTX, sulfasalazine, hydroxychloroquine, and leflunomide, and etanercept (a biologic DMARD) were among the predictors examined. Of those patients requiring hospitalization for infection, only the use of corticosteroids was associated with an increased risk (HR 1.56; 95% CI, 1.20–2.04). Cumulative dose or duration of corticosteroids did not provide additional information beyond a history of corticosteroid use.

One retrospective cohort study of 224 RA patients directly assessed the toxicity of low-dose, long-term corticosteroid therapy (mean 4.9 years).169 In three outpatient rheumatology clinics, 112 patients on low-dose prednisone (< 15 mg/day) for more than 1 year were matched with 112 patients not using prednisone. Records were abstracted from the date of prednisone initiation to the date of a predetermined adverse event (fracture, avascular necrosis of bone, new onset diabetes or diabetes out of control, infection requiring hospital or surgical intervention, herpes zoster, myocardial infarction, cerebrovascular event, gastrointestinal (GI) bleeding or peptic ulcer disease, cataracts, glaucoma, and death). Low-dose and high-dose long-term prednisone use (>5 mg/day) was correlated with dose-dependent specific adverse events (adverse event at 10 to 15 mg/day: OR, 32.3; 95% CI, 4.6–220; P = 0.0004; adverse event at 5 to 10 mg/day: OR, 4.5; 95% CI, 2.1–9.6; P = 0.0001; and adverse event at 0 to 4 mg/day: OR, 1.9; 95% CI, 0.8–4.7; P = 0.15). Patients on long-term prednisone (any dose) were at higher risk for fracture (OR, 3.9; 95% CI, 0.8–18.1; P < 0.09), infection (OR, 8.0; 95% CI, 1.0–64; P < 0.09) and GI event (OR, 2.2; 95% CI, 0.9–12.1; P < 0.07).

#### Synthetic DMARDs: overall tolerability

MTX, sulfasalazine, hydroxychloroquine and leflunomide all can produce several well-known, and similar, reactions (Table 16). Frequently reported adverse reactions for these drugs found in package inserts include the following:

- MTX: ulcerative stomatitis, nausea and abdominal distress, fatigue, chills and fever, dizziness, leukopenia, and decreased resistance to infection;138
- Sulfasalazine: stomatitis, nausea, dyspepsia, rash, headache, abdominal pain or vomiting, fever, dizziness, pruritus, and abnormal liver function tests.139
- Hydroxychloroquine: dizziness, headache, abdominal pain/nausea/vomiting/diarrhea, pruritus, weight loss, hair bleaching, and alopecia;137 and
- Leflunomide: diarrhea, rash, elevated liver enzymes, and alopecia.136

Table 18 describes studies providing information on tolerability and various adverse events. Three trials32,35,37 and one meta-analysis with up to 2 years of data,34 all described in more detail for KQ 1, indicated similar levels of general tolerability among leflunomide, MTX, and sulfasalazine, including similar discontinuation rates and frequency of serious adverse events. However, another meta-analysis of withdrawal rates from 71 RCTs and 88 observational studies, which included data up to 5 years, found that patients with RA stayed on MTX significantly longer than on either sulfasalazine or hydroxychloroquine.150 At 5 years, 36 percent of patients had remained on MTX to continue their treatment; 22 percent had remained on sulfasalazine. Patients on sulphasalazine were more likely to have withdrawn from medication than those on MTX (RR, 1.68; P < 0.0001). Withdrawal rates did not differ between observational studies and RCTs.

For combination therapies, five studies of DMARD combinations (one up to 5 years31) included MTX, sulfasalazine, hydroxychloroquine, and etanercept (described in detail under KQ 1). They had similar withdrawal rates attributed to adverse events.30,31,33,45,46,151 Although discontinuation rates were similar, rates of adverse events were higher in two studies for sulfasalazine plus MTX vs. monotherapy (adverse events for combination therapy range from 53 percent to 91 percent; adverse events for monotherapy range from 50 percent to 75 percent).31,33 Side effects included nausea, erythema, and elevated transaminases. Three RCTs of combination therapy including prednisone with one or more DMARDs (described in detail in KQ 1) showed similar discontinuation rates between groups.42,44,47 One open-label RCT of 155 patients comparing a prednisolone taper plus MTX plus sulfasalazine actually had a lower withdrawal rate because of adverse events than sulfasalazine only (2.6 percent vs. 7.6 percent, P = NR).39 Another open-label RCT of 245 patients found the withdrawal rate for adverse events to be lower in the prednisone plus MTX group than in the prednisone plus sulfasalazine group (11.5 percent vs. 33.3 percent, P = 0.0005).170

#### Synthetic DMARDS: specific adverse events

Synthetic DMARDs can produce several serious adverse events (Table 16). The package inserts for MTX give several warnings.138 It has been reported to cause congenital abnormalities. Severe and sometimes fatal bone marrow suppression and gastrointestinal toxicity have been reported with concomitant administration of MTX and NSAIDS. MTX-induced lung disease can occur in doses as low as 7.5 mg per week. Malignant lymphoma may also occur in patients on low-dose MTX. Severe, occasionally fatal skin reactions have also been reported.

Less common but severe adverse and potentially fatal events for sulfasalazine include blood dyscrasias, hypersensitivity reactions including Stevens-Johnson syndrome, renal and liver damage, irreversible neuromuscular and central nervous system changes, and fibrosing alveolitis.139 The package insert for hydroxychloroquine describes irreversible retinal damage in some patients on long-term therapy or high dosage. Other serious reactions include blood dyscrasias, seizures, hypersensitivity reactions, and hepatotoxicity.137 Potentially severe adverse reactions for leflunomide include blood dyscrasias, hepatotoxicity, and hypersensitivity reactions including Stevens-Johnson syndrome.136

##### Hepatic events

Two retrospective cohorts examined hepatic events in patients with rheumatoid arthritis.152,153 Both studies found similar hepatic event rates for leflunomide and MTX.

A 2-year retrospective cohort from a U.S. insurance claims database (N = 40,594) examined the incidence rates of serious hepatic events in patients treated with leflunomide, MTX, and other DMARDs (including gold, D-penicillamine, hydroxychloroquine, sulfasalazine, infliximab, and etanercept).152 The hepatic event rate for leflunomide was similar to that for other DMARDs (leflunomide, 4.1/1,000 person-years [95% CI, 2.4–7.0], MTX, 6.2/1,000 person-years [95% CI, 5.1–9.3]; other DMARDs, 4.2/1,000 person-years [95% CI, 3.3, 5.3], P = NS, NR).

Another group examined data from claims databases for two retrospective cohorts of 41,885 patients over 3 years for serious hepatic events associated with treatment with leflunomide, MTX, traditional DMARDs (hydroxychloroquine, sulfasalazine, gold, minocycline, penicillamine, chlorambucil, cylcophosphamide and cyclosporine), or biologic DMARDs (infliximab, etanercept).153 Using MTX as the reference, they observed no higher rates in serious hepatic events for leflunomide (rate ratio 0.9; 95% CI, 0.2–4.9) or for traditional DMARDs (rate ratio 2.3; 95% CI, 0.8–6.5), but they did report higher rates for biologic DMARDs (rate ratio 5.5; 95% CI, 1.2–24.6).

##### Infection

Prednisone and possibly MTX and leflunomide increase the risk of infection compared with risks from other DMARDs. Two prospective cohort studies and one 39-year retrospective cohort study examined the risk of hospitalization for pneumonia infection.149,152,155 One study examined 16,788 patients from U.S. rheumatology practices and followed up semi-annually with questionnaires for 3.5 years.155 Both prednisone and leflunomide use increased the risk of hospitalization for pneumonia compared with RA patients not on these drugs (HR 1.7; 95% CI, 1.5–2.1; HR 1.3; 95% CI, 1.0–1.5); MTX, hydroxychloroquine, sulfasalazine, infliximab, etanercept, or adalimumab did not increase risks.

The 2-year retrospective database study examined RA patients to determine the incidence rates of adverse events during treatment with leflunomide, MTX, and other DMARDs (including gold, D-penicillamine, hydroxychloroquine, sulfasalazine, infliximab, and etanercept).152 Respiratory infection rates per person-year were highest in the MTX group (38.9/1,000 person-years), next highest in the other DMARD group (36.9/1,000 person-years), and lowest in the leflunomide group (20/1,000 person-years) (P < 0.0001).

The 39-year population-based study of the Rochester, Minnesota, cohort examined potential risk factors for hospitalization for infection in RA patients (N = 609).149 Outcomes were assessed by reviewing inpatient and outpatient community medical records. The use of corticosteroids increased hospitalization for infection (HR 1.56; 95% CI, 1.20–2.04). Compared with corticosteroids, other DMARDs including MTX, hydroxychloroquine, sulfasalazine, leflunomide, or etanercept had no increased risk of infection-related hospitalizations.

##### Interstitial Lung Disease

One 5-year retrospective cohort examined claims data from 62,734 patients with RA given a DMARD 1 year prior to the date of diagnosis of interstitial lung disease.154 Patients were divided into four categories: leflunomide, methotrexate, biologic agents (infliximab, etanercept, adalimumab, anakinra), and traditional DMARDs (antimalarials, sulfasalazine, gold salts, minocycline, penicillamine, azathioprine, cyclosporine, other cytotoxic agents). In patients diagnosed with interstitial lung disease, those prescribed leflunomide were at increased risk compared to patients prescribed other DMARDs (RR, 1.9; 95% CI, 1.1–3.6) but not significantly higher with use of either MTX (RR, 1.4; 95% CI, 0.8–2.3) or biologic DMARDs (RR, 0.8; 95% CI, 0.4–1.5).154

#### Malignancies

One retrospective study examined 756 patients with RA to determine the risk of lymphoma over a 30-year period.156 This was a matched case-control of consecutive Swedish RA patients in whom lymphoma was diagnosed. Controls were RA patients matched for sex, year of birth, year of RA diagnosis, and county of residence. The investigators found no association between lymphoma and use of DMARDs, including MTX (OR, 0.7; 95% CI, 0.3–1.6) or sulfasalazine (OR, 0.6; 95% CI, 0.3–1.1).

Another retrospective cohort study examined the risk of nonmelanoma skin cancer in 15,789 U.S. patients with RA who were participating in a registry and returned semi-annual questionnaires over a 4-year period in which they reported any current malignancies.157 Among RA patients, the development of nonmelanoma skin cancer was associated with use of prednisone (HR 1.28; P = 0.014). They found no association between this neoplasm and leflunomide plus MTX.

#### Biologic DMARDs: overall tolerability

Table 19 describes studies providing information on tolerability and various adverse events. Table 16 presented the basic information about toxicities and FDA or other warnings. The prescription information for abatacept highlights precautions for hypersensitivity reactions,142 and the prescription information of rituximab has a black box warning for fatal infusion reactions.147

In efficacy trials of biologic DMARDs, overall tolerability profiles appeared to be similar among biologic and synthetic DMARDs, or combinations of biologic and synthetic DMARDs. An exception was the combination of two biologic DMARDs. A 24-week RCT, described in more detail for KQ 1, assessed a combination treatment of etanercept (25 mg or 50 mg/week) and anakinra (100 mg/day) compared with etanercept monotherapy.59 The frequency of serious adverse events was substantially higher in the combination groups than the etanercept-only group (14.8 percent for 50 mg etanercept plus anakinra; 4.9 percent for 25 mg etanercept plus anakinra; 2.5 percent for etanercept only; P = NR). Furthermore, a study determining the efficacy of abatacept combined with different background treatments found substantially higher rates of serious adverse events in patients on abatacept combined with a biologic background treatment (22.3 percent) than in those not on a combination of two biologic DMARDs (12.5 percent).160

One nonrandomized open-label trial determined the comparative harms among combinations of biologic DMARDs and synthetic DMARDs other than MTX.151 No differences in adverse events could be detected between a combination of etanercept and either sulfasalazine or hydroxychloroquine.

The ERA (Early Rheumatoid Arthritis) study, described in more detail in KQ 1, had an open-label extension of up to 2 years,55 and an uncontrolled extension with etanercept (25 mg twice weekly) of up to 5 years.56 The rates of adverse events for etanercept did not rise during long-term treatment compared with rates reported from the short-term RCT. These results are consistent with findings from long-term extension studies of efficacy RCTs on adalimumab,83 anakinra,85,172 and infliximab.101,162 Likewise, safety analyses of post marketing surveillance data showed that the incidence of adverse events did not rise over time in patients treated with adalimumab175 and etanercept.161

In placebo-controlled efficacy trials of biologic DMARDs, injection site reactions, abdominal pain, nausea, headache, diarrhea, upper respiratory tract infections, and urinary tract infections were commonly reported adverse events.49 Injection site reactions (adalimumab, anakinra, etanercept) and infusion reactions (abatacept, infliximab, rituximab) were the more commonly and consistently reported adverse events. Most infusion reactions were nonspecific symptoms such as headache, dizziness, nausea, pruritus, chills, or fever.

In clinical trials of infliximab for the treatment of RA or Crohn’s disease, 17 percent of patients experienced infusion reactions; 0.5 percent were severe and resembled acute anaphylactic conditions or led to convulsions.158 In these trials, however, less than 2 percent of patients discontinued because of infusion reactions.158 A prospective cohort study of infliximab in a Canadian clinical care setting reported substantially higher rates of events than did the clinical trials.176 Specifically, in the community study (113 patients with 1,183 infusions), 53 percent of patients experienced at least one infusion reaction during the course of the therapy (mean 15 months).

Injection site reactions were mainly erythema, pruritus, rash, and pain of mild to moderate severity, and they were the most common reason for discontinuation blamed on adverse events. A systematic review reported that the mean, crude incidence rates of injection site reactions in RCTs and observational studies were 17.5 percent (95% CI, 7.1–27.9) for adalimumab, 22.4 percent (95% CI, 8.5–36.3) for etanercept, and 67.2 percent (95% CI, 38.7–95.7) for anakinra.49 The substantially higher incidence of injection site reactions for anakinra than for adalimumab and etanercept is consistent with rates reported in the respective package inserts.143–145 A German retrospective study based on post marketing surveillance data, however, reported a lower incidence of injection site reaction for anakinra than clinical trials (20 percent).174

The evidence on comparative discontinuation rates is limited to observational studies.52,67,173 A Swedish population-based, prospective cohort study reported statistically significantly higher rates of overall discontinuation (data NR; P < 0.001), discontinuation because of adverse events (data NR; P < 0.001), and discontinuation because of lack of efficacy (data NR; P < 0.018) for patients on infliximab than for those on etanercept over 60 months of followup.52 These findings are consistent with those from a German retrospective, population-based cohort study, based on the RABBIT (German acronym for Rheumatoid Arthritis – Observation of Biologic Therapy) database. This study reported that overall discontinuation rates among biologics were significantly higher for anakinra-treated patients (41 percent) than for patients on etanercept (31 percent; P = 0.004 for anakinra vs. etanercept) or those on infliximab (35 percent; P = 0.03 for anakinra vs. infliximab).67 Treatment discontinuations because of adverse events, after 12 months of treatment, were lowest for etanercept (13 percent for etanercept, 16 percent for anakinra, and 19 percent for infliximab; P = NR).

Four RCTs were designed to assess adverse events as primary outcomes.80,107,160,171 Overall, adverse event rates were similar for abatacept,160 adalimumab,80 anakinra,171 or infliximab107 and placebo. All four studies, however, reported a trend toward higher rates of severe infections in patients treated with biologic DMARDs than in those receiving placebo. In general, these studies were too short and did not have enough power to detect such rare but severe adverse events.

#### Specific adverse events

Because the evidence on the comparative risk for rare but severe adverse events is lacking for biologic DMARDs, we summarize the evidence on the risk of individual drugs below.

#### Serious infections

Because of the immunosuppressive nature of biologic DMARDs, serious infections including tuberculosis, pneumonia, osteomyelitis, progressive multifocal leucoencephalopathy (PML), and sepsis are of special concern. The FDA has issued black box warnings about an increased risk of infections for adalimumab and infliximab. The package inserts of anakinra and etanercept also contain bold letter warnings. Recently, the FDA issued an alert for health care professionals highlighting the death of two patients from PML who had been treated with rituximab for systemic lupus erythematosus.199 The available head-to-head evidence is insufficient to draw firm conclusions about the comparative risk of biologic DMARDs.

The best evidence stems from a prospective cohort study.163 This study enrolled 8,973 patients with severe RA from the British Society for Rheumatology Biologics Register. Patients were treated with adalimumab (n = 1,190), etanercept (n = 3,596), infliximab (n = 2,878), or synthetic DMARDs (n = 1,354). The overall followup included 11,220 patient-years. Results indicated no differences in risks among anti-TNF drugs. Compared with synthetic DMARDs, anti-TNF drugs did not lead to a higher overall risk for serious infections (IRR, 1.03; 95% CI, 0.68–1.57). The frequency of serious skin infections, however, was fourfold higher in patients treated with anti-TNF drugs than with synthetic DMARDs (IRR, 4.28; 95% CI, 1.06–17.17). What proportion of patients treated with anti-TNF drugs were also on a background synthetic DMARD regimen remains unclear. Although the statistical analysis controlled for multiple confounding factors, residual confounding in such a study design is likely. Results, therefore, must be interpreted cautiously. Event rates of serious infections in efficacy trials comparing anti-TNF drugs with synthetic DMARDs were generally too low to draw meaningful conclusions.

The following paragraphs summarize the evidence on the general risk of biologic DMARDs for serious infections (i.e., the risk of biologic DMARDs compared with that of placebo treatment).

Most studies defined serious infections as those that required antibiotic treatment or led to hospitalization or death. In placebo-controlled safety RCTs, the incidence of serious infections was consistently higher in biologic-treated than in placebo-treated patients. Although clinically significant, these differences rarely reached statistical significance because of low power. For example, in one large safety RCT (N = 1,414), a trend towards an increased risk of serious infections in anakinra-treated patients was apparent during the 6 months of treatment (2.1 percent vs. 0.4 percent; P = 0.068).171 The START (Trial for Rheumatoid Arthritis with Remicade) study, another safety RCT (N = 1,084) conducted to assess the risk of serious infections during infliximab treatment for RA, indicated a dose-dependent risk for patients on infliximab.107 After 22 weeks of treatment, patients on 3 mg/kg infliximab had similar rates of serious infections as patients on placebo (1.7 percent vs. 1.7 percent; RR: 1.0; 95% CI, 0.3–3.1). Patients treated with 10 mg/kg infliximab had a significantly higher rate of serious infections than patients on placebo (5.0 percent vs. 1.7 percent; RR: 3.1; 95% CI, 1.2–7.9). A fair meta-analysis of efficacy studies confirmed this finding and reported a similar dose-dependent risk for a combined population of adalimumab- and infliximab-treated patients.164

The higher risk of biologic DMARDs for serious infections was confirmed by a fair meta-analysis that pooled data of more than 5,000 RA patients from adalimumab and infliximab efficacy trials.164 The pooled odds ratio for serious infections was 2.0 (95% CI, 1.3–3.1) relative to placebo. The number needed to harm (NNH) was 59 (95% CI, 39–125) within a treatment period of 3 months to 12 months.

Most long-term observational studies support these findings.158,181,183,185 A large, French case series of 709 patients with various rheumatic diseases treated with adalimumab, etanercept, or infliximab in daily clinical practice reported a substantially higher rate of serious infections (10.5 per 100 patient-years) than rates reported in phase 3 efficacy trials (3 to 4 per 100 patient-years).183

The most common serious infections were cases of tuberculosis.180 In addition, observational studies reported infections with coccidiomycosis,178 histoplasmosis,166 pneumocystis carinii,200 and listeriosis167 and candida.180

Six retrospective cohort studies determined the risk of tuberculosis or granulomatous infections during treatment with infliximab or etanercept.165,177,179,180,182,184 All studies report a significant increase of risk attributable to anti-TNF therapy relative to placebo.

No evidence exists on the general risks of abatacept, adalimumab, anakinra, and rituximab. The best available evidence stems from three studies based on Spanish, Swedish, and U.S. databases that collected data on patients treated with biologic DMARDs.177,179,184 These data were collected systematically from participating physicians, regardless of the occurrence of adverse events. By contrast, the adverse events reporting system (AERS) database of the FDA includes post marketing adverse events spontaneously reported from U.S. sources, serious and unlabeled spontaneous reports from non-U.S. sources, and serious, unlabeled post marketing clinical trial reports from all sources. Therefore, the AERS lacks an adequate denominator to draw inferences about causation and the comparative risks of any drugs. In addition, underreporting is likely.201

The U.S. study, using data from the National Data Bank of Rheumatic Diseases (NBI), reported an eightfold higher rate of tuberculosis in patients treated with infliximab than in patients in a historic control group who had been treated with synthetic DMARDs.184 The analysis yielded rates of 6.2 cases per 100,000 patient-years in the control group and 52.5 cases per 100,000 patient-years in patients on infliximab. The other two studies were based on the Spanish BIOBADASER (Base de Datos de Productos Biologicos de la Sociedad Espanola de Reumatologia)179 and several Swedish databases.177 Both studies analyzed data on infliximab and etanercept and indicated a substantially higher risk for tuberculosis in patients treated with etanercept or infliximab than in those on synthetic RA therapy. The Swedish study reported a fourfold increased risk of tuberculosis (RR, 4.0; 95% CI, 1.3–12) for patients on anti-TNF treatment compared with the risk for RA patients not exposed to etanercept or infliximab.177 Three studies based on the AERS database provided similar results.165,180,182

One analysis of AERS data focused on granulomatous infections in general. It indicated a higher rate among patients treated with infliximab (239 cases per 100,000 patients) than with etanercept (74 cases per 100,000 patients).165 The rate of tuberculosis in this study was 144 cases per 100,000 patients for infliximab and 35 cases per 100,000 patients for etanercept. However, incidence rates must be compared cautiously because this study reported cases per treated patients and not per patient years.165

#### Lymphoma and other malignancies

The risk of lymphoma, both Hodgkin and non-Hodgkin lymphoma, is generally increased in patients with RA compared with the general population.202 Data from controlled trials do not provide sufficient evidence concerning a further increase in their risk of cancer attributable to the use of either biologic DMARDs or a combination of biologic and synthetic DMARDs. Findings from retrospective observational studies are mixed.

A large prospective cohort study followed 18,572 RA patients in a registry for up to 3 years.190 The risk of lymphomas was higher for patients on anti-TNF therapies than for those on synthetic DMARDs, although not statistically significantly so. Confidence intervals for treatment groups overlapped and the results were insufficient to establish a causal relationship between RA treatments and lymphoma or to delineate differences in risks among treatments. The standardized incidence rate (SIR) in the overall cohort was 1.9 cases per 100,000. The SIR for patients not receiving MTX or any biologic agents was 1.0. The SIRs for patients on specific drugs were as follows: MTX, 1.7 (95% CI, 0.9–3.2); infliximab, 2.6 (95% CI, 1.4–4.5); and etanercept, 3.8 (95% CI, 1.9–7.5).

Three community-based, retrospective cohort studies from Sweden, Canada, and the United States, however, did not detect any differences in the risks of lymphoma between patients on anti-TNF treatment and those on synthetic DMARDs.159,186,189 The largest study included 4,160 patients treated with anti-TNF drugs.186 Results yielded an adjusted relative risk of 1.1 (95% CI, 0.6–2.1) for anti-TNF patients relative to patients on synthetic DMARDs.

Results regarding an increased risk for overall malignancies in patients treated with biologic DMARDs relative to placebo are also mixed. The best evidence comes from a fair meta-analysis that pooled data of more than 5,000 RA patients from adalimumab and infliximab efficacy trials.164 The pooled odds ratio for malignancies was 3.3 (95% CI, 1.2–9.1). The NNH was 154 (95% CI, 91–500) within a treatment period of 3 months to 12 months. Two large retrospective cohort studies, however, do not support such findings.185,189 The larger of these two studies, based on data on more than 60,000 Swedish patients, found SIRs for solid cancers to be similar for RA patients treated with anti-TNF medications and those on conventional therapy using both a contemporary and a historic control group.

A clinical trial database review did not detect a higher incidence of squamous cell carcinoma in 1,442 RA patients (4,257 patient-years) treated with etanercept (crude rate: 2.8 cases/1,000 patients) than for those on placebo;188 the median follow-up time was only 3.7 years. A larger retrospective cohort study (N = 15,789), however, reported a statistically significant association of a combination of anti-TNF and MTX treatment and nonmelanoma skin cancer (hazard ratio [HR]: 1.28; 95% CI, NR; P = 0.014).157

#### Congestive heart failure

No direct evidence on the comparative risk of biologic DMARDs for congestive heart failure (CHF) exists. The evidence on the risk of CHF with anti-TNF therapy is mixed. Two observational studies reported lower rates of CHF194 and cardiovascular events192 for RA patients on anti-TNF therapy than for those on conventional RA therapies. A good-quality Swedish retrospective cohort study (N = 983), using data from population-based databases, reported a statistically significantly lower risk of cardiovascular events in patients treated with anti-TNF medications than in those on conventional therapy (age-sex adjusted rate ratio: 0.46/1,000 person-years; 95% CI, 0.25–0.85; P = 0.013). A large retrospective cohort study (N = 13,171) reported an absolute risk reduction for CHF of 1.2 percent (95% CI, −1.9 – −0.5; P = NR) for patients treated with anti-TNF therapy compared with those not treated with anti-TNF medications over a 2-year period.194 Confounding by indication, however, cannot entirely be ruled out with such study designs.

By contrast, an analysis of AERS data reported that half of the patients who developed new onset CHF under etanercept or infliximab treatment did not have any identifiable risk factors.193 Indirect evidence comes from three trials, two on etanercept203 and one on infliximab,191 that evaluated the efficacy of these drugs for the treatment of CHF. Study populations did not have any rheumatoid illnesses. One of the two etanercept trials was terminated early because interim analyses indicated higher mortality rates in patients treated with etanercept. Similarly, the infliximab study presented higher mortality rates in the 10 mg/kg arm than in the placebo and 5 mg/kg arm.191 The package insert of infliximab issues a contraindication regarding use in patients with CHF; the package inserts of etanercept and adalimumab emphasize precaution.

#### Other adverse events

Evidence from randomized trials and observational studies is insufficient to draw conclusions regarding the comparative risk of rare but serious adverse events such as demyelination, autoimmunity, pancytopenia, and hepatotoxicity. Reports based on data from the FDA’s AERS indicated that adalimumab, etanercept, and infliximab might be associated with demyelination.175,195 Similar cases have been seen in regulatory trials of adalimumab.143 All neurologic events partially or completely resolved after discontinuation of treatment.

Similarly, reports of autoimmunity have not been confirmed in controlled trials and observational studies. However, case reports suggest an association between infliximab and drug-induced lupus and other autoimmune diseases.146,158,196,204 Lupus-like syndromes have also been reported for adalimumab.175 Development of antinuclear, antidouble-stranded DNA, or antihistone antibodies have also been reported in regulatory trials of other anti-TNF-α drugs.143,145 The infliximab package insert reports that 34 percent of patients treated with infliximab and MTX experienced transient elevations of liver function parameters.146 Severe liver injury, including acute liver failure, has been reported. Owing to a lack of studies with the methodological strength to assess these rare events, conclusions should be drawn on other grounds, such as comorbidities, taking case reports into consideration.

A prospective cohort study (N = 578) indicated that patients on anti-TNF treatments developed dermatological conditions (skin infections, eczema, drug-related eruptions) statistically significantly more often than anti-TNF-naive patients over a median treatment time of 2.3 years (25 percent vs. 13 percent; P < 0.0005).197

#### Adherence

The published literature in this area frequently uses the terms compliance and adherence interchangeably. Compliance has traditionally been used to describe a patient’s ability to take medications as prescribed. Some authors argue, however, that adherence better represents the more complex relationship among patients, providers, and medications; it is meant to reflect the fact that following a medication regimen is not necessarily a simple choice.205 Given the lack of a clear definition, we use the term adherence. Table 20 summarizes included studies for adherence.

Table 20

Studies assessing adherence in patients with rheumatoid arthritis

Author, Year | Study Type and Interventions | N | Results
Boers et al., 1997^39^ | RCT MTX + SSZ + prednisolone vs. SSZ | 155 | Compliance satisfactory in 85%
Emery et al., 2000^32^ | RCT LEF vs. MTX | 999 | Reason for withdrawal: noncompliance in the 1st year: LEF 11 (2%) vs. MTX 14 (3%) noncompliance in the 2nd year: LEF 6 (2%) vs. MTX 6 (2%)
Fleischmann et al., 2003^171^ | RCT AKA vs. Placebo | 1,414 | AKA vs. placebo: 100% adherent with use of study drug: 43.8% vs. 47.8% <70% adherent with use of study drug: 0.8% vs. 1.7% >40% missed no injections >90% received at least 90% of intended doses
Goekoop-Ruiterman et al., 2005^42^ | RCT Four treatment strategies | 508 | 24 (5%) were nonadherent
Haagsma et al., 1997^33^ | RCT SSZ + MTX vs. SSZ or MTX | 105 | Percentage of tablets taken > 90% (pill count)
Harley et al., 2003^168^ | Retrospective database analysis INF vs. ETA vs. MTX | 2,662 | INF more adherent than ETA or MTX (P < 0.05)
Hyearich et al., 2006^62^ | Prospective observational study | 2,711 | Adherence at 6 months: ETA 80% vs. INF 79% ETA subgroups (22% monotherapy, 16% MTX co-therapy, 19% DMARD co-therapy) INF subgroups (30% vs. 21% MTX co-therapy, vs. 22% DMARD co-therapy)
Kremer et al., 2002^126^ | RCT LEF + MTX vs. placebo + MTX | 263 | Overall, 98% adherent Adherence rates 80%–120% LEF, 87.7% placebo 90.2%
Kristensen et al., 2006^52^ | Prospective observational study INF vs. ETA | 949 | ETA had better drug survival than INF (P = 0.001)
Strand et al., 1999^37^ | RCT LEF vs. MTX vs. placebo | 402 | Nonadherence as the reason for withdrawal: LEF (1) MTX (1)

AKA, anakinra; DMARD, disease-modifying antirheumatic drug; ETA, etanercept; INF, infliximab; LEF, leflunomide; MTX, methotrexate; RCT, randomized controlled trial; SSZ, sulfasalazine.

The majority of RCTs that reported adherence stated a rate between 85 percent and 100 percent. Six published studies reported levels of adherence in RCTs.32,33,39,42,126,171 Most, however, contained only minimal information, and many did not stratify by treatment. Furthermore, they provided little or no information on the methods of assessment. For example, one study reported that adherence was satisfactory in 85 percent of patients, but the investigators did not describe their method of determining adherence.39 Only three of the six RCTs reported adherence rates for different treatment arms.32,126,171 None of these studies noted a significant difference in adherence. To what extent results from these highly controlled efficacy trials can be extrapolated to effectiveness settings remains unclear.

A retrospective database analysis used a large U.S. health plan, which included commercial and Medicare insurance, to examine adherence levels in 2,662 patients being treated with infliximab, etanercept, or MTX from November 1999 to December 31, 2001.^168^ The primary outcome measured was the number of drug administrations or prescriptions filled, divided by the expected number during a 365-day period. Their primary finding was that patients on infliximab were significantly more adherent than patients on etanercept or MTX. After controlling for baseline covariates (age, sex, baseline cost, insurance type, health plan region, history of therapy of RA, comorbidities, type of physician), 81 percent of the patients receiving infliximab were adherent at least 80 percent vs. 68 percent of the etanercept and 64 percent of the MTX patients (P < 0.05 for infliximab vs. both other drugs) over 1 year.

A 5-year observational study from March 1999 to January 2004 with 949 patients in Sweden prospectively evaluated the long-term efficacy and tolerability of treatment with infliximab and etanercept in adults with RA using the LUNDEX.52 The LUNDEX, a new index combining the proportion of responders with the proportion of patients adhering to treatment, was designed to compare the efficacy of the different therapies based on continued adherence and continuation of treatment. The study found that the etanercept group had a greater LUNDEX value, attributable primarily to better treatment adherence or survival time in the active treatment group, than did the infliximab group (P = NR).

### Psoriatic Arthritis: Overview

A total of six RCTS compared tolerability, harms, and adherence. Details are found in Evidence Table 10 in Appendix E. Table 14 provides information on common adverse events of included drugs and black box warnings. Table 21 provides information on studies primarily examining comparative efficacy and safety. The drugs examined in patients with active disease included one synthetic DMARD (leflunomide) and the three biologic DMARDs (adalimumab, etanercept, or infliximab), all in comparison with placebo.

Table 21

Studies assessing adverse events and discontinuation rates during blinded portion of studies of psoriatic arthritis

Study | Study Design Duration | Study Population | Drug | Results | Quality Rating
Synthetic DMARDs
Kaltwasser et al., 2004^112^ | RCT 190 24 weeks | Patients with active PsA | LEF | Differences in rates of withdrawals because of adverse events, diarrhea, and clinically significant increases in ALT (for all, P = NR) | Fair
Biologic DMARDs
Mease et al., 2005^114^ | RCT 313 24 weeks | Patients with active PsA despite background biologic or synthetic DMARD treatment | ADA | No statistically significant differences in adverse events except for ISRs. ADA 6.6% vs. placebo 3.1% (P = NR) | Fair
Mease et al., 2000^119^ | RCT 60 12 weeks | Patients with active PsA despite background biologic or synthetic DMARD treatment | ETA | No statistically significant differences in adverse events except for ISRs. ETA 20% vs. placebo 3% (P = NS) | Fair
Mease et al., 2006^122^ | RCT 205 72 weeks (24 blinded, 48 open-label) | Patients with active PsA despite background biologic or synthetic DMARD treatment | ETA | No statistically significant differences in adverse events except for ISRs. ETA 20% vs. placebo 9% (P ≤ 0.001) | Fair
Antoni et al., 2005^115^ IMPACT study | RCT 104 16 weeks | Patients with active PsA despite background biologic or synthetic DMARD treatment | INF | No statistically significant differences in adverse events | Fair
Antoni et al., 2005^117^ IMPACT2 study | RCT 200 24 weeks | Patients with active PsA despite background biologic or synthetic DMARD treatment | INF | No statistically significant differences in adverse events | Fair

ADA, adalimumab; ALT, alanine aminotransferase; DMARD, disease-modifying antirheumatic drug; ETA, etanercept; INF, infliximab; ISR, injection site reaction; LEF, leflunomide; NR, not reported; NS, not significant; PsA, psoriatic arthritis; RCT, randomized controlled trial.

### Psoriatic Arthritis: Key Points

Very limited information is available for harms, tolerability, adverse events, and adherence for patients with psoriatic arthritis. The available studies include only placebo-controlled studies; there are no head-to-head studies. The strength of evidence is low.

#### Synthetic DMARDs

The use of leflunomide vs. placebo can increase the likelihood of diarrhea and clinically significant increases in alanine aminotransferase. The rates of adherence are similar for leflunomide and placebo. The strength of evidence is low.

#### Biologic DMARDs

Five placebo-controlled studies of biologics, including one in adalimumab and two each in etanercept and infliximab, provide indirect evidence on harms. When the individual drugs are compared with placebo, the authors reported no differences in the rate of adverse events with the exception of increased rates of injection site reactions with the use of adalimumab and etanercept. No study reported adherence rates. The strength of evidence is low.

### Psoriatic Arthritis: Detailed Analysis

#### Synthetic DMARDs

##### Overall tolerability

One 24-week trial in 190 patients examined adverse events in the treatment of PsA using leflunomide vs. placebo. The overall rates of adverse events were the same in each group: 85.4 percent of both trial arms experienced an adverse event.112

#### Specific adverse events

This same trial showed some differences in specific adverse events, in particular diarrhea (leflunomide, 24 percent; placebo, 13 percent; P = NR) and increases in alanine aminotransferase (leflunomide, 13 percent; placebo, 13 percent; P = NR).112

#### Biologic DMARDs

##### Overall tolerability

In efficacy trials for patients with PsA, overall tolerability profiles appeared to be similar for biologic DMARDs (adalimumab, etanercept, infliximab) and placebo.112,114,115,117,119,122 Injection site reactions, dizziness, headaches, and upper respiratory tract infections were the most commonly reported individual adverse events. Of these, injection site reactions appear to occur more often in the active group than in the control group.

##### Specific adverse events

Adalimumab and etanercept used to treat PsA show some differences in injection-site reactions. In a 24-week RCT examining adalimumab vs. placebo, the adalimumab group experienced more injection site reactions (6.6 percent) than the placebo group (3.1 percent; P = NR).114 Two other studies comparing etanercept to placebo also showed higher rates of injection site reactions in the active arms.119,122 A 12-week RCT reported injection site reaction rates of 20 percent in the etanercept group and 3 percent in the placebo group; these results were not significant, probably owing to the small sample size (N = 60).119 In an RCT with 205 patients, however, the difference between these two groups was statistically different.122 In the 24-week blinded portion of this study, injection site reactions occurred in 36 percent of the etanercept patients and 9 percent of the placebo patients (P < 0.001).

##### Adherence

Only one study reported adherence in the treatment of PsA (Table 22).112 This 24-week study found that treatment adherence of ≥ 80 percent to < 110 percent was reported by 85 percent of leflunomide patients and 78 percent of placebo patients and (P = NR). Additionally, one patient was withdrawn by the investigator from the placebo group because of poor adherence.

Table 22

Adherence in patients with psoriatic arthritis

Author, Year | Study Type and Interventions | N | Results
Kaltwasser et al., 2004^112^ | RCT LEF vs. placebo | 190 | Compliance of ≥80% to <110%: LEF, 85%; placebo, 78%. One patient was withdrawn from placebo arm because of poor adherence

LEF, leflunomide; RCT, randomized controlled trial.

## Key Question 4: Benefits and Harms for Selected Populations

This key question concerned two main topics. Specifically, what are the comparative benefits and harms of drug therapies for rheumatoid arthritis in subgroups of patients based on stage of disease, history of prior therapy, demographics, concomitant therapies, or comorbidities? Stage of disease and history of prior therapy were addressed under KQ 1. We did not find any interventions that grouped subjects by early RA vs. more advanced RA, or those that compared MTX-naive RA groups with those with RA who were MTX-experienced.

We found no studies of adults with PsA that compared efficacy, effectiveness, or harms of drug therapies between subgroups and the general population. No studies conducted subgroup analyses or used subgroups as the study population.

### Rheumatoid Arthritis: Overview

We did not find any studies directly comparing efficacy, effectiveness, and harms of drug therapies between subgroups and the general population for treating RA patients. Our findings are limited to results from subgroup analyses, a weaker form of evidence. Overall, we included 11 studies in addressing this key question: one RCT, four subgroup analyses of multiple RCTs, one database analysis, four observational studies, and one systematic review.

We focused on groups defined by demographics (age, sex, race or ethnicity), concomitant therapies, comorbidities (any comorbidity, cardiovascular disease, osteoporosis, and renal disease) and pregnancy. Strength of evidence is low for comparative efficacy and effectiveness for age, concomitant therapies, comorbidities, and pregnancy.

We present key points and detailed analyses below for the population groups noted above. Details about included studies are presented by subgroup analysis in Tables 23 to 28 (listed alphabetically by drug comparison).

Table 23

Study characteristics, outcomes, and quality ratings of adult subpopulations with rheumatoid arthritis: by age

Study | Study Design N Duration | Study Population | Comparison and Dose (mg/day) | Outcomes | Quality Rating
Bathon et al., 2006^207^ | Subgroup analysis within 4 RCTs 1,353 12 months to 6 years | Adults with early DMARD resistance or late-stage RA Subgroups: elderly (≥ 65 years of age) and younger adults (< 65 years of age) | ETA 25 mg twice weekly + MTX vs. ETA 25 mg twice weekly | No significant difference found for improved efficacy or function between groups; elderly subjects had similar or less treatment response than younger subjects | Poor
Fleischmann et al., 2003^208^ | Pooled data from RCTs 1,128 Varies | Adults with RA taking ETA continuously for 1 year Subgroups: elderly (≥65 years of age) and younger adults (< 65 years of age) | ETA twice weekly Dosage not reported | No significant difference between elderly and younger groups at 1 year | Poor
Rheumatoid Arthritis Clinical Trial Archive Group 1995^206^ | Systematic review 496 ≥12 weeks | Adults with RA Subgroups: Under 60 years of age; 60 to 64 years; 65 to 69 years; and 70 years or above | MTX Dosages not reported | Adjusted analysis demonstrated that as age increases, the odds ratio for major clinical improvement decreases; no effect found on toxicity | Fair
Schiff et al., 2006^209^ | Pooled data from RCTs 1,049 ≤4 years | Adults with RA Subgroups: elderly (≥ 65 years of age) and younger adults (<65 years of age) | ETA (25 mg twice weekly) | No significant difference found between groups in functional status; both groups exhibited similar improvements | Fair

ETA, etanercept; MTX, methotrexate; RA, rheumatoid arthritis; RCT, randomized controlled trial.

Table 24

Study characteristics, outcomes, and quality ratings of adult subpopulations with rheumatoid arthritis and other conditions

Study | Study Design N Duration | Study Population | Comparison and Dose (mg/day) | Outcomes | Quality Rating
Schiff et al., 2004^211^ | RCT 951 6 months | RA patients with high-risk comorbid conditions | AKA 100 mg vs. placebo | In patients with comorbid conditions, no differences were found between treatment groups in regard to incidence of serious adverse events or overall infectious events | Fair
Jacobsson et al., 2005^192^ | Case and comparison cohort study 983 7 years | RA patients treated with TNF blockers in a Swedish Arthritis Treatment Register compared to a non-exposed anti-TNF RA population from the same geographic area | TNF inhibitors | Treatment group had significantly lower incidence and RR for development of first time cardiovascular events (myocardial infarctions) than the community cohort not treated with anti-TNFs. | Fair
Kwon et al., 2003^193^ | Database analysis AERS 47 cases of CHF NA | RA or other rheumatoid illness patients treated with ETA or INF | ETA, INF | Half of the patients who developed new onset CHF did not have any identifiable risk factors | Poor
Wolfe et al., 2004^194^ | Retrospective cohort study 13,171 2 years | Patients with RA in daily clinical care in U.S. | ADA, ETA, INF | Absolute risk reduction for CHF of 1.2 percent (95% CI, −1.9 – −0.5; P = NR) for patients treated with anti-TNF medications compared with those not treated with anti-TNF medications over a 2-year period | Fair
Rheumatoid Arthritis Clinical Trial Archive Group, 1995^206^ | Systematic review of 11 RCTs 496 NA | Adults with RA treated with MTX and having age and renal function data available | MTX | Severe toxicity (severe upper abdominal pain, renal failure, proteinurea, cytopenias and liver toxicity) and respiratory toxicity (cough, pneumonitis, dyspnea, wheezing) worse with greater renal impairment | Fair

ADA, adalimumab; AERS, adverse events reporting system; AKA, anakinra; CHF, congestive heart failure; ETA, etanercept; INF, infliximab; MTX, methotrexate; NA, not applicable; RA, rheumatoid arthritis; RCT, randomized controlled trial; TNF, tumor necrosis factor.

Table 25

Study characteristics, outcomes, and quality ratings of studies of pregnant women

Study | Study Design N Duration | Study Population | Comparison and Dose (mg/day) | Outcomes | Quality Rating
Chakravarty et al., 2003^213^ | Case reports from mailed survey 65 NA | Women of childbearing age seen by responding rheumatologists | MTX, LEF, ETA, INF (no dose specified) | Rate of congenital abnormalities in women on MTX was 10% | Poor
Katz et al., 2004^212^ | Retrospective analysis of drug safety database 146 NA | Pregnant women who either before or after conception were treated with INF or whose partners were treated with INF before conception | INF: 1 to 9 infusions vs. General population | No statistical differences in live births, miscarriages, or therapeutic terminations relative to rates in U.S. population of pregnant women | Fair

ETA, etanercept; INF, infliximab; LEF, leflunomide; MTX, methotrexate; US, United States.

### Key Points

#### Demographics

We found no studies that conducted comparisons by sex, race, or ethnicity, but we did include one trial that addressed age;206 two other studies, both rated poor quality, also addressed age, and we discuss them here because of the sparseness of this part of the evidence base.207,208 One study directly compared the efficacy of DMARDs in elderly RA patients (65 years of age or older) with younger RA patients (under 64 years of age and older than 18); however, the analysis was focused on outcomes within age groups, not the specific effects of age.209 Comparisons were available for only two DMARDs: one synthetic (MTX) and one biologic (etanercept).

Table 23 presents the studies of adults with RA that conducted comparisons by age groups. One systematic review by the Rheumatoid Arthritis Clinical Trial Archive Group found an inverse relationship between age and major clinical improvement.206 Of the three trials reviewed, the differences between the odds ratios was small.206 Two meta-analyses (pooled analyses of original data), both rated poor quality, provided mixed evidence on differences in efficacy in the elderly compared with a younger population treated with MTX and etanercept.207,208 In one, the investigators determined that patients in the elderly age groups had a lower response to treatment than those in the younger age groups,207 but both meta-analyses reported no difference in efficacy or function.207,208 Given that two of the studies are of poor quality, the level of evidence is low.

#### Concomitant Therapies

We found no evidence from head-to-head comparisons, placebo-controlled trials, or observational studies on other treatment therapies and the various RA treatments addressed in this report. An analysis of data from a placebo-controlled trial involving RA patients receiving anakinra determined that the safety profiles did not differ in subjects receiving antihypertensive, antidiabetic, or statin medication treatments.210 The level of evidence is low.

#### Comorbidities

Table 24 presents the studies found that addressed outcomes of RA patients with comorbidities. For RA patients with various high-risk conditions, one large placebo-controlled RCT of anakinra reported that there was no difference in serious adverse events or infections between the treated and placebo groups.211 Lower rates of either myocardial infarction192 or CHF194 in RA patients on anti-TNF therapy compared with those on other RA therapies were reported by two observational studies. Another retrospective cohort study of RA patients on anti-TNF medications found that half of those who developed new onset CHF had no identifiable risk factors for CHF.193 A systematic review of 11 MTX trials of RA patients determined that greater renal impairment was associated with greater toxicity.206 The level of evidence is low.

#### Pregnancy

The effects of DMARDs on pregnancy or neonatal outcomes are mixed. Table 25 presents the studies found that addressed neonatal or pregnancy outcomes for women with RA. Two observational studies212,213 are presented. We included one poor-quality study due to the sparseness of evidence on pregnancy outcomes for women with RA. The level of evidence is low.

### Detailed Analysis

#### Demographics

We identified three studies analyzing etanercept use in the elderly and two of MTX. The Rheumatoid Arthritis Clinical Trial Archive Group 1995 review of 11 MTX trials for adults with RA evaluated the effects of age or renal impairment on adverse events or treatment efficacy.206 Although the authors reported that the odds for major clinical improvement dropped slightly as age increases, among all clinical trial patients, age did not affect MTX efficacy or the rate of side effects. Using the group under age 60 as the referent, the odds of major clinical improvement for those 60 to 64 years of age was 1.4 (95% CI, 0.7–2.6), 1.0 (95% CI, 0.5–2.2) for those 65 to 69 years of age, and 0.7 (95% CI, 0.3–1.7) for those 70 years of age or older (P = NR). As renal functioning declines, the odds for toxicity increased as much as four fold. Baseline renal function was found to be a significant predictor of toxicity, with the lower creatinine clearances ending up with greater toxicity (P = 0.027).206

In a post-hoc analysis of three controlled and open-label extension studies of RA patients treated with etanercept; outcomes for elderly and younger adult age groups were compared for all those treated with etanercept for at least 4 years.209 Though the elderly group exhibited greater mean HAQ-DI improvements than those in the younger group (0.39 to 0.92 vs. 0.57 to 1.00), at baseline the elderly group was more disabled than the younger adults. Also, the proportion of elderly in each study was much smaller than the younger adult group, usually about 20 percent vs. 80 percent.209 Both groups demonstrated similar rapid improvements in disability and pain during the first few months of the controlled phase of the trials, then stabilized, and improvements were maintained through the open-label portions of the trials.209

Another post-hoc analysis (poor quality) of original data from four RCTs evaluated treatment comparisons of etanercept, both in combination with MTX and as a monotherapy in adults with early DMARD resistance or late-stage RA.207 Within each of the four trials, subset analysis was conducted comparing elderly subjects to younger adults (under 65 years of age). Each trial and extension exhibited similar or lower ACR responses for the elderly in comparison to the younger adult group in regard to functioning and progression (P = NR).

Another pooled analysis (poor quality) of nine RCTs found similar or less etanercept treatment response in elderly subjects than younger adults, although the difference was not significant for function and improved efficacy.208

#### Concomitant Therapies

One placebo-controlled trial of 1,399 adults with active RA disease examined safety profiles of those treated with 100 mg/day anakinra. No differences were found in the adverse event profiles of the subjects taking or not taking concomitant antihypertensive, antidiabetic, or statin pharmacotherapies. Even when the analysis was done comparing those treated with anakinra with those on placebo, no differences emerged (P = NR).210

#### Comorbidities

##### Any comorbidity

We did not identify any study specifically designed to assess the comparative efficacy and risk of biologic DMARDs (abatacept, adalimumab, anakinra, etanercept, infliximab, or rituximab) in RA patients with common comorbidities. A post-hoc subgroup analysis of a large safety trial determined the safety profile of anakinra in patients with various comorbidities (cardiovascular events, pulmonary events, diabetes, infections, malignancies, renal impairment, central nervous system-related events).211 Overall, the incidence rates of adverse events were similar regardless of comorbidity status.

##### Cardiovascular morbidity

No direct evidence exists on the comparative risk of biologic DMARDs in patients with both RA and cardiovascular disease. The evidence on the risk of cardiovascular disease with anti-TNF therapy is mixed. A Swedish retrospective cohort study (N = 983), using data from population-based databases, reported a statistically significantly lower risk of cardiovascular events for patients treated with anti-TNF medications than for those on conventional therapy (age-sex adjusted rate ratio: 0.46/1,000 person-years; 95% CI, 0.25–0.85; P = 0.013).192 A large retrospective cohort study (N = 13,171) based on the National Databank for Rheumatic Diseases reported an absolute risk reduction for CHF of 1.2 percent (95% CI, −1.9 – −0.5; P = NR) for patients treated with anti-TNF therapy relative to the risk for those not treated with anti-TNF medications over a 2-year period.194

A MedWatch analysis of data from the AERS found that half of the patients who developed new onset CHF while being treated with etanercept or infliximab for RA or other rheumatoid illnesses did not have any identifiable risk factors.193 These findings support the possible association between new onset cardiovascular harms for RA patients treated with etanercept or infliximab. However, package inserts for infliximab, etanercept, and adalimumab warn about a contraindication for patients already diagnosed with CHF. For infliximab that package insert warns about a contraindication regarding its use in patients with CHF;147 the package inserts of etanercept and adalimumab express precautions in use of these agents in patients with CHF.143,145

##### Renal function

A systematic review of 11 RCTs of MTX use in 496 adults with RA concluded that toxicity worsened with greater renal impairment. Patients with high renal impairment had a fourfold risk (OR, 4.5; 95% CI, 0.9–22.6) for severe toxicity (severe upper abdominal pain, renal failure, proteinurea, cytopenias, and liver toxicity) than those with no renal impairment. Slightly more (4 percent vs. 1 percent) had respiratory toxicity (cough, pneumonitis, dyspnea, wheezing). No effect was found between renal impairment and increased liver toxicity.206

#### Pregnancy

Two observational studies addressed pregnancy in women with RA.212,213 A retrospective analysis of data from a U.S. and European drug safety database found no statistical differences in live births, miscarriages, or therapeutic terminations in the subpopulation studied. The focus was on pregnant RA patients who had been treated with between one to nine infliximab infusions either before or after conception and male patients treated with up to nine infusions before their partners’ conception. The authors also reported no increase in adverse events from infliximab exposure during pregnancy relative to the rate in the U.S. population of pregnant women.212

One poor-quality study, using case reports from survey responses from 175 rheumatologists, found 10.3 percent (4/39) of women exposed to MTX during their pregnancies resulted in congenital malformations.213 This is a much higher rate than the 2 percent to 3 percent average reported in a California cohort of 1.6 million infants.213 In all, 23 physicians (rheumatologists) reported on 65 pregnancies with their patients treated with DMARDs (MTX, 38 patients; leflunomide, 10; etanercept, 14; infliximab, 2; and MTX plus etanercept, 1). A majority of the survey respondents agreed that pregnancy was contraindicated for women being treated with DMARDs, especially with patients being treated with MTX (95 percent agreement) and leflunomide (92.7 percent agreement). For patients treated with etanercept, the percentage agreement dropped to 38.6 percent, and for infliximab to 46.5 percent. Two observational studies addressed pregnancy in women with RA.212,213

A retrospective cohort study using data from a U.S. and European drug safety database found no statistical differences in live births, miscarriages, or therapeutic terminations in the subpopulation studied. The focus was on pregnant RA patients who had been treated with between one to nine infliximab infusions either before or after conception and male patients treated with up to nine infusions before their partners’ conception. The authors also reported no increase in adverse events from infliximab exposure during pregnancy vs. those in the U.S. population of pregnant women.212