# 1 Introduction

## Background

Arthritis and other rheumatic conditions constitute the leading cause of disability among U.S. adults,1 affecting more than 7 million persons. Noninflammatory arthritic conditions (e.g., osteoarthritis) are most common, but inflammatory arthritides such as spondyloarthropathies (e.g., ankylosing spondylitis, psoriatic arthritis [PsA]), and reactive arthritis) and rheumatoid arthritis (RA) can be equally or more disabling.

Among RA and PsA—the focus of this review—the burden of disease is evidenced by decreased quality of life,2–4 decreased employment rates,5 and increased direct and indirect costs.6–9 Annually, approximately 9 million physician office visits and more than 250,000 hospitalizations occur as the result of RA. The mean total annual direct cost to patients with RA is estimated to be $9,519 per person,6 and most studies have reported indirect costs to be roughly twofold greater than direct costs.10 Costs associated with PsA are not as well studied, although they are believed to be just slightly lower than those in RA.8 Indirect costs are believed to increase over time; as the disease progresses so does the loss of function and inability to work.

Clinically, RA and PsA may present similarly. The most notable distinctions are the presence of serum rheumatoid factor in RA and accompanying skin presentations in PsA. Still, the two inflammatory conditions are unique, and they warrant independent descriptions.

## Causes and Diagnosis

### Rheumatoid Arthritis (RA)

RA is an autoimmune disease that affects 2.1 million adults in the United States. Disease onset generally occurs between ages 30 and 50 years, and incidence is higher in women and older adults. RA presentations range from mild to severe. Some people are affected for as little as a few months, whereas others are affected for a lifetime and suffer severe joint damage and disability.

The hallmarks of the disease are inflammation of the synovium (a membrane that lines the joint capsule and produces lubricating fluid in the joint) with progressive erosion of bone leading to malalignment of the joint. As the inflamed synovium destroys the joint, the surrounding muscles and tendons become weak, leading to disability in most cases. Unlike osteoarthritis, RA can affect areas in addition to joints. Most patients develop anemia. Some patients have dry eyes and mouth (sicca syndrome). Rarely, patients develop inflammation in the lining of the lung (pulmonary fibrosis), various layers of the eye wall (episcleritis and scleritis), small vessels (vasculitis), and the outer covering of the heart (pericarditis).

The exact etiology of RA is not completely understood, but genetic susceptibility has been described in certain populations.11,12 Studies have shown the importance of T cells, B cells, and cytokines in the pathogenesis of RA.13,14 Cytokines of particular interest are tumor necrosis factor (TNF), interleukin (IL)-1, and IL-6.

TNF plays a central role in the pathobiology of RA. It is an important regulator of other proinflammatory molecules and stimulates the secretion of matrix metalloproteinases. It also exerts a direct effect on the multiple tissues inside the joint including chondrocytes, macrophages, synovial fibroblasts, and osteoclasts. Together, its action leads to inflammation and the formation of pannus, a mass of tissue that causes localized joint destruction.14

The diagnosis of RA is primarily a clinical one, based on multiple patient symptoms. No single laboratory test confirms RA. Constitutional symptoms including low-grade fever, fatigue, or malaise are common before the onset of joint swelling and pain. Joint stiffness is almost always present and is frequently most severe after periods of prolonged rest. The disease tends to affect the small joints of the hands and feet first in a symmetric pattern, but other joint patterns are often seen. A serum rheumatoid factor is present in up to 75 percent of patients with RA but is frequently negative in early disease. A more specific marker, anticyclic citrullinated peptide (CCP) antibody, has recently been described and may be a useful marker in patients with early disease.15 Table 1 presents the diagnostic criteria for RA proposed by the American College of Rheumatology (ACR).16 Patients are said to have RA if they meet four of the seven criteria in the table.16

Table 1

ACR criteria for the diagnosis of rheumatoid arthritis

Criteria
1. Morning stiffness lasting greater than 1 hour
2. Arthritis in 3 or more joint areas
3. Arthritis of the hand joints (metacarpophalangeal [MCP], proximal interphalangeal [PIP], wrists)
4. Symmetric arthritis
5. Rheumatoid nodules
6. Serum rheumatoid factor
7. Radiographic changes: erosions or unequivocal periarticular osteopenia

Source: Arnett et al., The American Rheumatism Association 1987 revised criteria for the classification of rheumatoid arthritis. Arthritis Rheum. 1988 Mar; 31(3):315–24.

### Psoriatic Arthritis (PsA)

Psoriasis, a skin disease, affects 2.2 percent of U.S. adults; approximately 10 percent to 30 percent of patients with psoriasis develop PsA. Approximately 55,000 adults in the United States have PsA. PsA can develop at any age but most often appears between 30 and 50 years old. Unlike RA, PsA appears to affect men slightly more often than women.

The presentation is highly variable. In most cases, the psoriasis predates the onset of the PsA, although arthritis has been described as the initial manifestation of psoriatic disease. Common presentations include a symmetric small-joint polyarthritis (RA-like) and an axial arthritis with involvement of the sacroiliac joints, axial skeleton (spine), and large joints. In all cases, symptoms include pain and stiffness in the affected joint, enthesial areas (where tendons insert into bone) with joint line tenderness, swelling, and often loss of range of motion. Pitting of the fingernails often correlates with the extent and severity of the disease. Dactylitis—swelling of a whole digit—is a characteristic clinical finding, and inflammatory eye disease (iritis, uveitis) may occur. More than one-third of patients with PsA will develop dactylitis and enthesopathy (a disease process at the site where muscle tendons or ligaments insert into bones or joints).

The etiology and pathogenesis of psoriasis and PsA are not completely understood, but genetic, immunologic, and environmental factors are all likely to play a role.17 Several classification systems have been proposed for the diagnosis of PsA,18 but which one best represents true PsA remains unclear. Table 2 presents the CASPAR (ClASsification of Psoriatic ARthritis) as an example of one classification.19

Table 2

CASPAR criteria for the diagnosis of psoriatic arthritis

Inflammatory articular disease (joint, spine, or enthesial areas) with ≥ 3 points from the following
1. Evidence of current psoriasis, a personal history of psoriasis, or a family history of psoriasis
2. Typical psoriatic nail dystrophy including onycholysis, pitting, or hyperkeratosis
3. Negative test result for the presence of rheumatoid factor
4. Current dactylitis or history of dactylitis
5. Radiographic evidence of juxtaarticular new bone formation

Source: Taylor W, Gladman D, Helliwell P, Marchesoni A, Mease P, Mielants H. Classification criteria for psoriatic arthritis: development of new criteria from a large international study. Arthritis Rheum. 2006 Aug;54(8):2665-73.^19^

## Treatment of Rheumatoid Arthritis and Psoriatic Arthritis

### Overview

Treatment of patients with RA or PsA is aimed primarily at controlling pain and inflammation and, ultimately, at slowing or arresting the progression of joint destruction.

#### Corticosteroids

Corticosteroids—sometimes referred to as glucocorticoids or steroids—are used for many inflammatory and autoimmune conditions. As a class, corticosteroids have been used since the discovery of cortisone in the 1940s. Commonly used corticosteroids include betamethasone, budesonide, cortisone, dexamethasone, hydrocortisone, methylprednisolone, prednisone, prednisolone, and triamcinolone. The drugs differ in their relative potency and available modes of administration. Betamethasone and dexamethasone are the most potent of the corticosteroids, whereas cortisone and hydrocortisone are the least potent. Frequently used agents for oral administration are prednisone and methylprednisolone. Methylprednisolone, betamethasone, and triamcinolone are used for intra-articular therapy.

Corticosteroids are a synthetic form of cortisol, a hormone produced by the adrenal glands. They produce their anti-inflammatory and immunosuppressive response by interacting with steroid-specific receptors in the cytoplasm of cells, thereby inhibiting the movement of inflammatory cells into the site of inflammation, inhibiting neutrophil function, and inhibiting prostaglandin production. They are widely prescribed as an oral treatment for RA because of their ability to reduce inflammation and subsequent joint pain and swelling. When used in PsA, corticosteroids are most often given as a joint injection rather than orally.

#### Synthetic disease-modifying antirheumatic drugs (DMARDs)

Synthetic DMARDs such as methotrexate (MTX), sulfasalazine, hydroxychloroquine, and leflunomide modify the course of inflammatory conditions, presumably through their effects on the immune system. Most of the synthetic DMARDs have been used in clinical practice for more than 20 years. MTX was developed in the 1940s as a treatment for leukemia but was not approved for the treatment of arthritis until 1988. Sulfasalazine also has been available since the 1940s; it is a combination salicylate (acetylsalicylic acid) and antibiotic (sulfapyearidine) that originally was used to treat patients with inflammatory bowel disease. Hydroxychloroquine, approved in the 1950s for the treatment of malaria, is believed to work in arthritis by interfering with antigen presentation and the activation of immune response by increasing the pH within macrophage phagolysosomes. Additionally, hydroxychloroquine possibly inhibits toll-like receptors that mediate proinflammatory cytokine production. Only leflunomide, an isoxazole immunomodulatory agent, was specifically developed for treating inflammatory arthritis; the U.S. Food and Drug Administration (FDA) approved its use in 1998.

Synthetic DMARDs are not members of a single drug family. They are classified together, however, because they all are slow acting with the aim of improving symptoms, reducing or preventing joint damage, and preserving structure and function in patients with inflammatory disease. All the synthetic DMARDs covered in this review can be given orally, although methotrexate can also be injected.

#### Biologic DMARDs

Biologic DMARDs—commonly referred to as biological response modifiers or simply biologics—are a relatively new category of DMARDs that differ from synthetic DMARDs in that they target specific components of the immune system. The FDA approved the first of the biologics (infliximab) in 1998; this report covers five additional agents approved since that time: etanercept (1998), anakinra (2001), adalimumab (2002), abatacept (2005), and rituximab (2006). Of the six agents, all are currently FDA approved for treating RA, but only adalimumab, etanercept, and infliximab are approved for treating PsA.

The biologic DMARDs work by selectively blocking mechanisms involved in the inflammatory and immune response. Adalimumab, etanercept, and infliximab are known as TNF inhibitors (i.e., drugs that block specific proinflammatory mediators known as cytokines). They produce their primary effect by blocking TNF from interacting with cell surface TNF receptors. Adalimumab and infliximab are monoclonal antibodies. Adalimumab is a fully human monoclonal antibody that binds specifically to TNF, blocking its interaction with both the p55 and p75 cell surface TNF receptor. Infliximab is a chimeric (i.e., made from human and mouse proteins) monoclonal antibody that binds specifically to human TNF. Etanercept is not a monoclonal antibody, but rather a TNF-soluble receptor protein. More specifically, it is a soluble dimeric form of the p75 TNF receptor linked to the Fc portion of human immunoglobulin G1 (IgG1). Etanercept exerts its action by binding circulating TNF and preventing it from interacting with a cell surface receptor.

IL-1, another naturally occurring cytokine, has both immune and proinflammatory actions. Anakinra is a human recombinant protein that competitively blocks the IL-1 receptor, thus blocking various inflammatory and immunological responses.

The immunosuppressant agent abatacept produces its immune response by interfering with T lymphocyte activation. Abatacept is a soluble fusion protein that consists of the extracellular domain of human cytotoxic T lymphocyte-associated antigen (CTLA-4) and the modified Fc portion of IgG1.

Rituximab, a chimeric murine/human monoclonal antibody, works by binding to the CD20 antigen found on the surface of B lymphocytes. Thus, it in effect removes circulating B cells from the pre-B cell stage through the activated B cells. B cells are believed to play a role in autoimmune and inflammatory processes, such as those involved in RA.

Tables 3 and 4 provide detailed information on agents used in the treatment of RA and PsA that we have included in this review. Table 3 documents names, manufacturers, and available dosage forms. Table 4 shows routes of administration, labeled uses, and usual (recommended) adult doses and frequency for RA and PsA.

Table 3

Pharmaceutical treatments for rheumatoid arthritis and psoriatic arthritis

Class | Generic Name | U.S. Trade Name(s)^*^ | Manufacturer | How Supplied
Corticosteroids
| Betamethasone | Celestone®, Soluspan® | Multiple | Injectable—3 mg/ml and 6 mg/ml Syrup—0.6 mg/5 ml Topical—cream, lotion, ointment (multiple strengths)
| Budesonide | Entocort® EC | AstraZeneca | Tabs—3 mg
| Cortisone | Cortone® | Multiple | Tabs—5 and 25 mg
| Dexamethasone | Decadron®, Maxidex® | Multiple | Injectable—4 and 10 mg/ml Solution—0.5 mg/5 ml, 1 mg/ml Tabs—0.5, 1.5, 2, and 4 mg
| Hydrocortisone | Cortef®, Solu-Cortef® | Multiple | Injectable—100, 250, 500, and 1,000 mg vials Tabs—5, 10, and 20 mg Topical—cream, foam, gel, lotion, ointment, solution (multiple strengths)
| Methylprednisolone | Medrol®, Depo-Medrol®, Solu-Medrol® | Multiple | Injectable (acetate)—20, 40, and 80 mg/ml Injectable (sodium succinate)—40, 125, and 500 mg, 1 and 2 g vials Tabs—2, 4, 8, 16, and 32 mg
| Prednisone | Deltasone®, Sterapred®, LiquiPred | Multiple | Solution—1 and 5 mg/ml Tabs—1, 2.5, 5, 10, 20, and 50 mg
| Prednisolone | Orapred®, Pediapred®, Prelone®, Delta-Cortef®, Econopred® | Multiple | Solution/Syrup—5, 6.7, 15, and 20 mg/5 ml Tabs—5 and 15 mg
| Triamcinolone | Aristospan®, Kenacort® Kenalog® | Multiple | Injectable (acetonide)—10 and 40 mg/ml Injectable (hexacetonide)—5 and 20 mg/ml Tabs—4 mg Topical—aerosol, cream, lotion, ointment, paste
Synthetic DMARDs
| Hydroxychloroquine | Plaquenil® | Multiple | Tabs—200 mg
| Leflunomide | Arava® | Multiple | Tabs—10 and 20 mg
| Methotrexate | Trexall®, Folex®, Rheumatrex® | Multiple | Injectable—25 mg/ml, 20 mg and 1 g vials Tabs—2.5, 5, 7.5, 10, and 15 mg
| Sulfasalazine | Azulfidine®, EN-tabs®, Sulfazine® | Multiple | Suspension—250 mg/5 ml Tabs—500 mg
Biologic DMARDs
| Abatacept | Orencia® | Bristol Myers Squibb | Injectable—250 mg vial
| Adalimumab | Humira® | Abbott | Injectable—40 mg/0.8 ml syringe
| Anakinra | Kineret® | Amgen | Injectable—100 mg/0.67 ml syringe
| Etanercept | Enbrel® | Amgen Wyeth Immunex | Injectable—50 mg/ml, 25 mg vial
| Infliximab | Remicade® | Centocor | Injectable—100 mg vial
| Rituximab | Rituxan® | Genentech IDEC | Injectable—10 mg/ml vial

DMARD, disease-modifying antirheumatic drug.

* Listed trade names are limited to commonly prescribed U.S. products when multiple are available.

Table 4

Route, labeled use, and usual dose of treatments for rheumatoid arthritis and psoriatic arthritis

Class | Generic Name | Route | Labeled Use* | Usual Adult Dose
Corticosteroids
| Betamethasone | Injectable Oral Topical | NSA | IM—0.6 to 9 mg/day in 1 or 2 divided doses Intrabursal, intra-articular, intradermal, intralesional—0.25 to 2 ml Oral—2.4 to 4.8 mg/day in 2 to 4 divided doses Topical—1 to 2 times daily as needed
| Budesonide | Oral | Crohn’s | Oral—9 mg once daily for up to 8 weeks
| Cortisone | Oral | NSA | Oral—25 to 300 mg/day in 1 or 2 divided doses
| Dexamethasone | Injectable Oral | NSA | IM, IV, oral—0.75 to 9 mg/day in 2 to 4 divided doses
| Hydrocortisone | Injectable Oral Topical | NSA | IM, IV, oral—15 to 240 mg/day in 2 divided doses Intralesional, intra-articular, soft tissue injection—10 to 37.5 mg Topical—2 to 4 times daily as needed
| Methylprednisolone | Injectable Oral | NSA | IM (acetate)—10 to 80 mg every 1 to 2 weeks IM (sodium succinate)—10 to 80 mg daily Intra-articular, intralesional (acetate)—4 to 80 mg every 1 to 5 weeks IV (sodium succinate)—10 to 40 mg every 4 to 6 hours; up to 30 mg/kg every 4 to 6 hours Oral—2 to 60 mg in 1 to 4 divided doses to start, followed by gradual reduction
| Prednisone | Oral | NSA | Oral—Use lowest effective dose (≤7.5 mg/day)
| Prednisolone | Oral | NSA | Oral—Use lowest effective dose (5 to 7.5 mg/day)
| Triamcinolone | Injectable Oral Topical | NSA | IM—2.5 to 60 mg Intra-articular, intralesional, intradermal, intrasynovial—1 to 40 mg Oral—8 to 16 mg/day Topical—2 to 4 times daily as needed
Synthetic DMARDs
| Hydroxychloroquine | Oral | RA | Oral—200 to 400^†^ mg/day in 1 or 2 divided doses
| Leflunomide | Oral | RA | Oral—10 to 20 mg/day in a single dose
| Methotrexate | Injectable Oral | RA | IM, IV, oral—7.5 to 25 mg/week in a single dose
| Sulfasalazine | Oral | RA | Oral—500 to 3,000 mg/day in 2 to 4 divided doses
Biologic DMARDs
| Abatacept | Injectable | RA | IV—Dosed according to body weight (< 60 kg = 500 mg; 60–100 kg = 750 mg; > 100 kg = 1,000 mg); dose repeated at 2 weeks and 4 weeks after initial dose, and every 4 weeks thereafter
| Adalimumab | Injectable | PsA | SQ—40 mg every other week
| Adalimumab | Injectable | RA | SQ—40 mg every other week; may increase to 40 mg per week in patients not taking concomitant methotrexate
| Anakinra | Injectable | RA | SQ—100 mg/day; dose should be decreased to 100 mg every other day in renal insufficiency
| Etanercept | Injectable | PsA, RA | SQ—25 mg twice weekly or 50 mg once weekly
| Infliximab | Injectable | PsA | IV—5 mg/kg, with or without methotrexate, at 0, 2, and 6 weeks followed by maintenance every 8 weeks thereafter
| Infliximab | Injectable | RA | IV—3 mg/kg in combination with methotrexate at 0, 2, and 6 weeks followed by maintenance every 8 weeks thereafter; may increase to maximum of 10 mg/kg or treat as often as every 4 weeks
| Rituximab | Injectable | RA | IV—1,000 mg on days 1 and 15 in combination with methotrexate

DMARD, disease-modifying antirheumatic drug; IM, intramuscular; IV, intravenous; NSA, nonspecific anti-inflammatory (or immunosuppressant) indication; PsA, psoriatic arthritis; SQ, subcutaneous; RA, rheumatoid arthritis.

* Labeled use limited to RA and PsA unless otherwise indicated.

† Initial dose is 400–600 mg/day for 4 to 12 weeks

### Disease-Specific Treatments

#### Rheumatoid arthritis

In RA, nonsteroidal anti-inflammatory drugs (NSAIDs) are frequently used in early or mild disease, but they do not have any disease-modifying properties. For RA, the synthetic DMARD MTX is the cornerstone of treatment, as it has demonstrated good disease control. However, MTX toxicity may limit its use, and many patients do not adequately respond to MTX monotherapy.

Combination therapies serve an important role because treatment with a single DMARD often does not adequately control symptoms. Low-dose systemic corticosteroids (prednisone 7.5–10 mg/day) or intra-articular corticosteroids are used as an adjunct to DMARDs. In patients with persistent disease despite aggressive management with standard agents, biologic agents, often in combination with MTX, are now considered the standard of care.

There is debate as to which types of combination therapy are preferred and how early in the disease process to initiate this intervention. No settled opinion exists as to whether treatment should proceed in a sequential “step-up” approach (progressing from single therapy to combination therapy) or in a “step-down” approach (beginning with combination therapy and stepping down treatment when symptoms are under control). Additionally, uncertainty remains regarding risks and benefits of therapies in patient subgroups.

Two recent reports examined some of the biologic DMARDs in the treatment of RA. The first included a meta-analysis of the benefits and harms of three biologics (adalimumab, etanercept, and infliximab).20 It found that these three drugs were more efficacious than placebo for RA patients who are not well controlled by conventional DMARDs, specifically for improving control of symptoms, increasing physical function, and slowing radiographic changes in the joints. The second report used meta-regression techniques and found that anakinra was less effective than infliximab, etanercept, or adalimumab;21 when the researchers accounted for disease duration and baseline quality-of-life scores, the three biologics appeared better than anakinra. These studies support the overall efficacy of biologics. Nonetheless, examining comparative efficacy and effectiveness with synthetic DMARDs and corticosteroids, as well as long-term outcomes and subpopulations, is warranted.

#### Psoriatic arthritis

Historically, few PsA trials have been conducted, and management has been adapted from RA trial data. With the introduction of biologic therapy, however, dedicated PsA trials have demonstrated efficacy in this distinct disease. The first line of treatment of PsA is NSAIDs, although in most cases DMARDs are necessary. MTX is particularly useful because it treats the psoriasis in addition to the arthropathy. Corticosteroids may be used to control inflammation, but they do not have much of a role in chronic disease management in psoriatic disease. The tapering or withdrawal of steroids in PsA has been associated with severe flares of skin disease. When chronic disease continues to be active despite the use of MTX, biologics are indicated. Biologics most often are given in combination with synthetic DMARDs (e.g., MTX).

## Scope and Key Questions

The purpose of this review is to compare the efficacy, effectiveness, and harms of corticosteroids, synthetic DMARDS, and biologic DMARDs in the treatment of patients with RA and PsA. We address the following four key questions (KQs):

- KQ 1. For patients with rheumatoid or psoriatic arthritis, do drug therapies differ in their ability to reduce patient-reported symptoms, to slow or limit progression of radiographic joint damage, or to maintain remission?
- KQ 2. For patients with rheumatoid or psoriatic arthritis, do drug therapies differ in their ability to improve functional capacity or quality of life?
- KQ 3. For patients with rheumatoid arthritis or psoriatic arthritis, do drug therapies differ in harms, tolerability, adherence, or adverse effects?
- KQ 4. What are the comparative benefits and harms of drug therapies for rheumatoid arthritis and psoriatic arthritis in subgroups of patients based on stage of disease, history of prior therapy, demographics, concomitant therapies, or comorbidities?

For each key question, we evaluated specific outcome measures as reported in Table 5. For efficacy and effectiveness, we focused on head-to-head trials and prospective observational studies comparing one drug to another. For biologic DMARDs, we also included placebo-controlled, double-blinded randomized controlled trials (RCTs). For safety and tolerability, as well as for efficacy and effectiveness in subgroups, we included head-to-head trials, high-quality systematic reviews, and prospective and retrospective observational studies.

Table 5

Outcome measures and study eligibility criteria

Key Questions, Outcomes of Interest, and Specific Measures | Study Eligibility Criteria
KQ 1/KQ 2: Efficacy/effectiveness KQ 1:; - Patient symptoms; - Radiographic joint damage; - Remission; KQ 2:; - Functional capacity; - Quality of life | Study Design; - Head-to-head double-blind RCTs; - High-quality systematic reviews; - Prospective, controlled observational studies; Minimum Study Duration; - RCT—3 months; - Observational—3 months; Study Population; - Age 19 and older; - Patients with RA or PsA; Sample Size; - RCT N ≥ 100; - Observational N ≥ 100
KQ 3: Harms, tolerability, adherence, adverse effects | Study Design; - Head-to-head double-blind RCTs; - High-quality systematic reviews; - Observational studies, prospective and retrospective; Minimum Study Duration; - RCT—3 months; - Observational—3 months; Study Population; - Age 19 and older; - Patients with RA or PsA; Sample Size; - RCT N ≥ 100; - Observational N ≥ 100
KQ 4 Benefits and harms in subgroups based on stage, history of prior therapy, demographics, concomitant therapies, comorbidities | Study Design; - Head-to-head double-blind RCTs; - High-quality systematic reviews; - Observational studies; Minimum Study Duration; - RCT—3 months; - Observational—3 months; Study Population; - Age 19 and older; - Patients with RA or PsA; Sample Size; - RCT N ≥ 100; - Observational N ≥ 100

KQ, key question; PsA, psoriatic arthritis; RA, rheumatoid arthritis; RCT, randomized controlled trial.

Because equipotency among the reviewed drugs is not well established, we assume that comparisons made within the recommended dosing ranges in Table 4 are appropriate. Dose comparisons made outside the recommended daily dosing range are not in our report.

## Organization of the Report

The remainder of this comparative effectiveness review describes our methods to review and synthesize this literature, presents our results by key question (RA followed by PsA), and discusses the implications of those results for clinical applications and future research. Appendix A lists our peer reviewers; Appendix B describes our search strategy; Appendix C contains studies included in meta-analyses; Appendix D lists excluded studies; Appendix E presents evidence tables; Appendix F contains abstract-only studies; Appendix G presents the criteria for assessing the quality of individual studies; Appendix H provides characteristics of studies with poor internal validity; and Appendix I describes clinical assessment scales commonly used in arthritis trials.