# 4 Discussion

This report provides a comprehensive review of the comparative efficacy, effectiveness, and harms of members of three main classes of drugs used to treat adult patients with rheumatoid arthritis (RA) or psoriatic arthritis (PsA). These include corticosteroids, synthetic disease-modifying antirheumatic drugs (DMARDs), and biologic DMARDs. The objective of our report was to evaluate the comparative efficacy, effectiveness, and harms of monotherapies, combination therapies, and different treatment strategies.

Table 26 and Table 27 (for RA and PsA, respectively) summarize our findings and the strength of evidence for the four key questions (KQs) addressed by this report. In brief, the KQs involved benefits of these drugs, alone or in combination, in terms of reducing patient-reported symptoms, slowing or limiting the progression of radiographic joint damage, and maintaining remission (KQ 1); improving functional capacity and quality of life (KQ 2); harms and risks of these drugs (KQ 3); and the benefits or harms in various patient subpopulations defined by sociodemographic characteristics or health states (KQ 4). Most of the evidence meeting inclusion criteria focuses on comparative efficacy. We highlight comparative effectiveness studies when available.

Most of the trials were conducted in RA patients, and we can draw some conclusions regarding the comparative efficacy of drugs for RA. Data are quite limited for PsA patients, and the evidence is insufficient to draw firm conclusions on comparative efficacy, effectiveness, and harms of either synthetic or biologic DMARDs in this condition.

## Key Findings

### Rheumatoid Arthritis

Over the past few years, treatment strategies for RA have changed considerably. Early use of DMARDs is now considered crucial to avoid persistent and erosive arthritis. Clinicians frequently start treatment regimens with DMARD monotherapies and adjust dosages as appropriate to achieve a low disease activity.

Existing comparative evidence permits us to draw some conclusions for monotherapies of synthetic and biologic DMARDs. Overall, the evidence supports similar efficacy and effectiveness for methotrexate (MTX) and sulfasalazine, but it is insufficient to draw conclusions about efficacy and effectiveness for sulfasalazine and leflunomide relative to each other.30,31,33 All three drugs have similar discontinuation rates attributed to adverse events in short-term efficacy trials up to 2 years.32,34,35,37

Although the evidence is insufficient to draw firm conclusions on the comparative efficacy, effectiveness, and harms of biologic DMARDs, adjusted indirect comparisons of placebo-controlled studies suggest that no differences exist among the set of anti-tumor necrosis factor (anti-TNF) drugs (namely, etanercept, infliximab, and adalimumab).21,48,49,51 Results of adjusted indirect comparisons indicate, however, that anakinra is less efficacious than anti-TNF drugs for patients with RA.48,49 Adjusted indirect comparisons, in general, have to be interpreted cautiously because the validity of results is based on assumptions that cannot be verified, particularly the similarity of study populations.

The evidence comparing monotherapy using a biologic DMARD with monotherapy using a synthetic DMARD is mixed. Monotherapies of adalimumab57 and etanercept54,63 generally did not reveal a benefit relative to MTX monotherapy; the exception was for radiographic outcomes, which were statistically significantly better in patients on biologic DMARDs than on MTX. Whether such differences are clinically relevant and can alter the long-term progression of the disease remains unclear. Other biologic DMARDs have not been directly compared with MTX.

By contrast, population-based, observational evidence suggests that biologic DMARDs as a class resulted in better functional capacity than synthetic DMARDs as a class.58 No evidence exists on abatacept, anakinra, infliximab, and rituximab. No studies were available comparing biologics with synthetic DMARDs other than MTX. All randomized controlled trials (RCTs) were funded by the makers of the biologic DMARDs.

Although a substantial percentage of patients responds well to DMARD monotherapy,34,54,57,63–65 some patients do not achieve an acceptable treatment response. As the BeSt study (Dutch acronym for Behandel Strategieen, “treatment strategies”), a Dutch effectiveness trial assessing different treatment strategies for RA, has indicated, tight disease control and an individualized treatment approach are paramount in achieving a satisfactory treatment response or remission.42 Therefore, if dose escalation of a monotherapy does not achieve low levels of disease activity, combination therapies have to be taken into consideration. This is supported by multiple efficacy studies that indicate that combinations of biologic and synthetic DMARDs appear to be more efficacious than monotherapy of either drug.

The existing evidence supports combination strategies of up to three synthetic DMARDs, including corticosteroids, compared with strategies using one or two drugs. The data are limited, however, by the number of supporting studies for each drug combination. Moderate strength evidence from two efficacy trials reported higher proportions of patients meeting American College of Rheumatology (ACR) 20 criteria at 2 years for the combination of MTX plus sulfasalazine and hydroxychloroquine than for one or two drugs.45,46

Similarly, combination therapy of biologic DMARDs (adalimumab and etanercept) with MTX achieved better results in clinical outcomes, functional capacity, and quality of life than monotherapy with biologic DMARDs.57,63–66 Whether these results can be extrapolated to combinations of biologic DMARDs with other synthetic DMARDs is uncertain. In clinical practice, patients often receive biologic DMARDs as an add-on therapy to an existing regimen of various synthetic DMARDs.

Combinations of two biologic DMARDs did not yield an additional treatment benefit but rather led to substantially higher rates of serious adverse events than monotherapies (14.8 percent vs. 2.5 percent; P = NR).59,160 Current evidence also suggests improved functional capacity39,43,47,124 and less radiographic progression39,40,43,44,47 for combination strategies with corticosteroids and one or more synthetic DMARDs compared with synthetic DMARD monotherapy. For most of these comparisons, the evidence is limited to a single study.

The evidence is insufficient to draw firm conclusions about whether one combination strategy is better than another. Data are limited to one effectiveness trial for patients with early RA; it reported less radiographic progression over 12 months with either (1) MTX, sulfasalazine, and high-dose tapered prednisone or (2) MTX and infliximab versus (3) sequential DMARD therapy or (4) step-up combination therapy.42 Of note, after the report was in peer review, the 2-year followup was published.214 Results of this study reinforced the conclusion that patients on initial combination therapy of MTX, sulfasalazine, and tapered high-dose prednisone or initial combination therapy with MTX and infliximab had less radiographic progression. However, all arms had similar functional ability by Health Assessment Questionnaire scores (HAQ), and similar disease activity by Disease Activity Score (DAS) values regardless of which initial therapy they received.

The therapeutic advantage of combination therapy compared with monotherapy does not seem to be outweighed by an increase in harms. Evidence of moderate strength suggests that combination studies of two or three DMARDs, including MTX, sulfasalazine, hydroxychloroquine, and etanercept versus one or two DMARDs had similar withdrawal rates attributable to adverse events. Combination studies including prednisone with one or more DMARDs had similar discontinuation rates between groups.

Similarly, combinations of biologic and synthetic DMARDs had similar rates of adverse events than monotherapies of either drugs. However, because biologic DMARDs are relatively new medications, solid long-term data on safety are generally still missing. Especially rare but severe adverse events such as serious infections, lymphoma, autoimmunity, or congestive heart failure are of concern. The evidence is particularly sparse on abatacept and rituximab. Furthermore, the pharmaceutical industry funded a large percentage of these studies, and selective reporting is conceivable, although we had no way to account for missing information.

The most obvious differences among biologic DMARDs that might be clinically decisive for choosing a particular drug involve dosing and administration. Abatacept, infliximab, and rituximab require intravenous administration at different intervals and present the danger of rare but severe infusion reactions. Adalimumab, anakinra, and etanercept can be administered subcutaneously by the patient. Administration intervals differ substantially: adalimumab requires an injection once a week or once every other week, anakinra has to be administered daily, and etanercept once or twice per week. The route of administration is also the cause of the main differences in short-term tolerability. Anakinra appears to have a substantially higher rate of injection site reactions than anti-TNF drugs. Abatacept, infliximab, and rituximab carry the risk of severe infusion reactions that cannot occur in drugs administered subcutaneously. Fatal infusion reactions have been reported for infliximab and rituximab.146,147

The existing evidence remains insufficient to draw firm conclusions on the best treatment regimen for patients with early RA. Studies conducted in patients with early RA suggested that an early start of a biologic DMARD can prevent joint erosions and beneficially influence the clinical course of the disease. Because the studies were of limited duration, however, they do not allow conclusions on whether early initiation of a biologic regimen can improve the long-term prognosis of RA. Currently, clinical practice guidelines recommend that clinicians start biologic DMARDs if patients have suboptimal response to synthetic DMARDs.140,215

A considerable limitation of our conclusions is that we have had to derive them primarily from efficacy trials. The direction and effect sizes of findings from effectiveness trials and observational studies were generally consistent with those from efficacy trials. Nonetheless, differences in the incidence of reported adverse events and discontinuation rates were obvious between clinical trials and population-based observational studies.

For example, clinical efficacy trials of infliximab reported infusion reaction in, on average, 17 percent of patients.158 A prospective cohort study in a Canadian clinical care setting, however, reported substantially higher percentages.176 In this study (113 patients with 1,183 infusions), 53 percent of patients experienced at least one infusion reaction during their therapy (mean, 15 months).

Patients who were enrolled in efficacy trials usually suffered from more severe disease than the average patient in clinical practice.216 For example, a recent study found that only small proportions of consecutive patients with RA who were under the care of a private practice rheumatologist in Nashville, Tennessee, would have met eligibility criteria of the ERA (Early Rheumatoid Arthritis) trial;54 only 31 percent of patients with early RA who had not taken MTX would have met the ERA criteria. The same pattern was true for the ATTRACT (anti-TNF trial in RA with concomitant therapy) study trials;100,216 only 5 percent of patients in a long-term RA database would have been eligible for this trial. Therefore, the applicability of results from efficacy trials to the average patient in community practice appears to be limited.

Furthermore, with RA we did not find any studies directly comparing efficacy, effectiveness, and harms of drug therapies between subgroups and the general population. Several studies conducted subgroup analyses or used subgroups as the study population. Age subgroup analyses suggested no differences in adverse events, infections, or malignances in patients treated with MTX or etanercept.207,208 For MTX, the odds for major clinical improvement dropped slightly as age increases in all clinical trial patients; age did not affect MTX efficacy or the rate of side effects.206 The strength of this evidence is weak, and results have to be interpreted cautiously.

Table 26

Summary of findings with strength of evidence: rheumatoid arthritis

Key Question and Drug Comparison | Findings^*^ | Strength of Evidence^†^
Key Question 1: Comparative Efficacy and Effectiveness of Drug Therapies
Corticosteroids vs. corticosteroids | Comparative efficacy: One RCT indicated no differences in efficacy between prednisolone and budesonide. No other head-to-head evidence was available. | Low
Synthetic DMARD vs. synthetic DMARD | Comparative efficacy: Two trials and a good-quality meta-analysis (of these two RCTs) reported no differences in efficacy at 2 years for leflunomide and MTX. | Moderate
Synthetic DMARD vs. synthetic DMARD | One RCT reported higher efficacy for leflunomide than for sulfasalazine at 2 years. | Low
Synthetic DMARD vs. synthetic DMARD | Six trials and one meta-analysis found no differences in radiographic changes up to 2 years for MTX, leflunomide, and sulfasalazine. | Moderate
Synthetic DMARD vs. synthetic DMARD | No evidence exists for hydroxychloroquine. | NA
Synthetic DMARD combinations | Comparative efficacy: One RCT supported higher efficacy for sulfasalazine + MTX vs. monotherapy. Two studies reporting no difference focused on patients with early RA. | Low
Synthetic DMARD combinations | Two trials supported higher efficacy at 2 years for triple combination MTX + sulfasalazine + hydroxychloroquine than for 1 or 2 drugs. | Moderate
Synthetic DMARD combinations | Three trials including prednisone with 1, 2 or 3 synthetic DMARDs (respectively (MTX + sulfasalazine + hydroxychloroquine) showed less radiographic progression than 1 synthetic DMARD alone. | Moderate
Synthetic DMARD combinations | Comparative effectiveness: One fair trial of early RA patients found that combination therapy with MTX + sulfasalazine + tapered high-dose prednisone or infliximab + MTX showed less radiographic change than sequential DMARD or step-up combination therapy. | Low
Biologic DMARDs vs. placebo | Comparative efficacy: Head-to-head trials are not available. Adjusted indirect comparisons indicated no differences in efficacy among adalimumab, etanercept, and infliximab. Anakinra appeared to be less efficacious than anti-TNF drugs. No adjusted indirect comparisons are available on abatacept or rituximab. | Moderate
Biologic DMARD combinations vs. monotherapy | Comparative efficacy: Combination of biologic DMARDs did not yield additional treatment effects compared with monotherapy of the same drugs. | Low
Biologic DMARD combinations vs. monotherapy | Comparative effectiveness: A nonrandomized effectiveness study and two prospective observational studies indicated a faster onset of response for etanercept than for infliximab during the first months of therapy but no differences in effectiveness thereafter. | Low
Biologic DMARDs vs. MTX (class effects) | Comparative efficacy: Three RCTs (two with early RA patients) indicated no significant differences in clinical outcomes between either adalimumab or etanercept and MTX. Adalimumab and etanercept led to statistically significantly better radiographic outcomes than MTX. | Moderate
Biologic DMARDs vs. synthetic DMARDs | Comparative effectiveness: One retrospective cohort study indicated significantly higher rates of remission for biologic DMARDs as a class than synthetic DMARDs. | Low
Biologic DMARDs + MTX vs. biologic DMARDs | Comparative efficacy: Multiple good (or fair) RCTs supported a higher efficacy of a combination treatment of adalimumab, etanercept, infliximab, or rituximab and MTX compared with a monotherapy of the respective biologic DMARD. Some comparisons are limited to single studies. | High for etanercept Moderate for adalimumab, infliximab, and rituximab
Biologic DMARDs + synthetic DMARD other than MTX vs. biologic DMARDs | Comparative efficacy: One RCT found no difference between a combination of etanercept with sulfasalazine and etanercept monotherapy. | Low
Biologic DMARD + MTX vs. MTX | Comparative efficacy: Two RCTs indicated a greater efficacy of combinations of adalimumab or infliximab and MTX compared with MTX monotherapy in patients with early RA. | Moderate
Key Question 2: Functional Capacity or Health-related Quality of Life
Corticosteroids vs. corticosteroids | Comparative efficacy: In one head-to-head RCT, prednisolone improved functional capacity and health-related quality of life more than budesonide. | Low
Synthetic DMARDs vs. synthetic DMARDs | Comparative efficacy: Seven studies compared synthetic DMARDs head-to-head: leflunomide with MTX, leflunomide with sulfasalazine, and sulfasalazine with MTX. Three RCTs and one systematic review suggested that leflunomide led to greater improvement in functional status and/or health-related quality of life than either MTX or sulfasalazine. | Moderate
Synthetic DMARDs vs. synthetic DMARDs | Three RCTs did not support a difference in functional capacity between sulfasalazine and MTX. | Moderate
Two synthetic DMARDs vs. synthetic DMARD monotherapy | Comparative efficacy: Three RCTs compared a combination of MTX and sulfasalazine to monotherapy with either drug alone. These studies did not support a difference in functional capacity between combination therapy and monotherapy. | Moderate
Synthetic DMARD combinations vs. synthetic DMARD monotherapy | Comparative efficacy: Three RCTs examined combination strategies with corticosteroids and one or more synthetic DMARDs compared to synthetic DMARD monotherapy. Some suggested better outcomes with the combination strategies. | Low
Biologic DMARDs vs. biologic DMARDs | Comparative effectiveness: Head-to-head evidence was limited to a prospective cohort study that compared etanercept and infliximab. Etanercept patients had greater improvements in functional capacity, but the groups were not compared statistically. | Low
Biologic DMARDs vs. MTX | Comparative efficacy: Three RCTs (one good quality) found no difference in endpoint outcomes comparing either adalimumab or etanercept with MTX. Two of the RCTs found no difference between groups; one found greater improvement during the first 12 weeks in functional capacity and health-related quality of life with etanercept than with MTX but no difference from weeks 16 to 52. | Moderate
Biologic DMARDs vs. other synthetic DMARDs (as class effects) | Comparative effectiveness: No head-to-head evidence is available. One prospective cohort study indicated that biologic DMARDs as a class resulted in better functional capacity than synthetic DMARDs as a class. | NA
Biologic DMARDs + MTX vs. biologic DMARDs | Comparative efficacy: Evidence is mixed. Two RCTs found that a combination of adalimumab or etanercept with MTX led to statistically significantly greater improvements in functional capacity or health-related quality of life than monotherapy with the same biologic DMARDs. One prospective cohort study found no difference when comparing etanercept plus MTX with etanercept alone or infliximab plus MTX with infliximab alone. For most of these comparisons, the evidence is limited to a single study. | Low
Biologic DMARDs + synthetic DMARD other than MTX vs. biologic DMARDs | Comparative efficacy: One RCT found no difference between a combination of etanercept with sulfasalazine and etanercept monotherapy. | Low
Biologic DMARD + MTX vs. MTX | Comparative efficacy: Two RCTs found greater improvement in functional capacity and quality of life with combination therapies (adalimumab + MTX or infliximab + MTX) than with MTX alone. One prospective cohort study found, for functional capacity, the etanercept-MTX combination, but not the infliximab-MTX combination, to be better than MTX alone. | Moderate
Key Question 3: Comparative Tolerability and Safety of Drug Therapy
General Tolerability
Corticosteroids | Overall adverse events in one efficacy trial of prednisolone and budesonide were not different. | Low
Synthetic DMARDs | Three efficacy trials and one meta-analysis indicate no differences in tolerability for leflunomide, MTX, and sulfasalazine. | Moderate
Biologic DMARDs | Overall adverse event profiles: In efficacy trials, overall profiles did not differ among biologic DMARDs. Two fair RCTs suggested that the risk of serious adverse events is dose-dependent. | Moderate
Biologic DMARDs | Injection site reactions: In efficacy trials, anakinra had substantially higher rates of injection site reactions than either adalimumab or etanercept. | Moderate
Biologic DMARDs | Infusion reactions: The existing evidence is insufficient to draw conclusions about the comparative risk of abatacept, infliximab, and rituximab with respect to severe or fatal infusion reactions. | Low
Combination of two biologic DMARDs | Two RCTs indicated that the combination of two biologic DMARDs led to statistically significantly higher rates of serious adverse events than monotherapy. | Moderate
Discontinuation Rates
Synthetic DMARDs | Three trials and one meta-analysis indicate no differences in discontinuation rates for leflunomide, MTX, and sulfasalazine. However, one meta-analysis of studies up to 5 years indicated that the proportion of patients who discontinue MTX is lower than the proportion who discontinue sulfasalazine. | Moderate
Synthetic DMARD combinations | Five studies of two or three DMARDs, including MTX, sulfasalazine, hydroxychloroquine, and etanercept versus one or two DMARDs had no differences in withdrawal rates attributed to adverse events. Three studies combining prednisone with one or more DMARDs reported no differences in discontinuation rates between groups. | Moderate
Biologic DMARDs | Two cohort studies indicated that infliximab has statistically significantly higher rates of discontinuation than etanercept. | Moderate
Biologic DMARDs | One cohort study reported that anakinra had higher rates of discontinuation than etanercept and infliximab. | Low
Serious Infections
Corticosteroids and synthetic DMARDs | Three cohort studies indicated elevated infection risk for prednisone and possibly MTX and leflunomide compared with other DMARDs. | Low
Biologic DMARDs | The existing evidence is insufficient to draw conclusions about the comparative risk of biologic DMARDs. | NA
Biologic DMARDs and synthetic DMARDs | One cohort study indicated that anti-TNF drugs as a class (adalimumab, etanercept, and infliximab) did not lead to a higher overall risk for serious infections compared with synthetic DMARDs as a class. | Low
Malignancies
Synthetic DMARDs | The existing evidence is limited to retrospective cohort studies. No risk of lymphoma was found for MTX or sulfasalazine. | Low
Biologic DMARDs | The existing evidence is insufficient to draw conclusions about the comparative risk of biologic DMARDs with respect to lymphoma or other malignancies. | NA
Combinations | One study of prednisone and a biologic DMARD-MTX combination was associated with nonmelanoma skin cancer. | Low
Other Serious Adverse Events
Synthetic or biologic DMARDs | The existing evidence is insufficient to draw conclusions about the comparative risk of synthetic or biologic DMARDs with respect to serious adverse events such as demyelinations, drug-induced lupus, hepatotoxicity, interstitial lung disease, or congestive heart failure. | Low
Key Question 4: Differences by Subgroups
Demographics: Age
Various drug comparisons | The evidence base is sparse and mixed. One pooled analysis found similar responses in patients ages 65 years and older versus patients under 65 treated with a biologic (etanercept). Two poor-quality studies of one synthetic (MTX) and one biologic (etanercept) found no difference between these groups in adverse events, infections, or malignancies. A systematic review of MTX also found an inverse relationship between age and major clinical improvement, and no difference in toxicity. | Low
Concomitant Therapies: Chronic Disease
Various drug comparisons | No evidence is available from head-to-head comparisons, or observational studies for these concomitant treatment therapies. One subgroup analysis from a placebo-controlled trial involving anakinra found that safety profiles did not differ in subjects receiving antidiabetic, antihypertensive, or statin medication treatments. | NA
Comorbidities
Various drug comparisons | High-risk comorbidities: One placebo-controlled RCT of anakinra found no difference between groups in serious adverse events or infections for adults with RA and various high-risk conditions. | Low
Various drug comparisons | Cardiovascular: Evidence is limited for subpopulations with cardiovascular disease. Two observational studies reported lower rates of either myocardial infarction or congestive heart failure on anti-TNF therapy than on other RA therapies. One database analysis found that only half of those with new onset congestive heart failure had no identifiable risk factors for congestive heart failure. | Low
Various drug comparisons | Renal impairment: One systematic review reported that greater renal impairment was associated with worse toxicity. | Low
Pregnancy and Neonatal Outcomes
Various drug comparisons | Fetal abnormalities: Evidence is very limited and mixed. One poor-quality study using case reports calculated a higher incidence of congenital abnormalities in pregnancies of women taking DMARDs than in the general population, but a fair-quality database analysis found no statistical difference in live births, miscarriages, or therapeutic terminations in mothers or fathers treated with infliximab and the general population of pregnant women. | Low

DMARD, disease-modifying antirheumatic drug; MTX, methotrexate; NA, not applicable; PSA, psoriatic arthritis; RA, rheumatoid arthritis; RCT, randomized controlled trial; TNF, tumor necrosis factor; vs., versus.

* Studies are of fair quality (see Methods) unless otherwise noted.

† Strength of evidence assessed according to a modified GRADE approach.27

Table 27

Summary of findings with strength of evidence: psoriatic arthritis

Key Question and Drug Comparison | Findings^*^ | Strength of Evidence^†^
Key Question 1: Comparative Efficacy and Effectiveness of Drug Therapies
Synthetic DMARDs | Comparative efficacy: No head-to-head evidence met inclusion criteria. Current evidence is limited to placebo-controlled trials. Compared with placebo in one fair study, leflunomide produced greater response rates. | NA
Biologic DMARDs | Comparative efficacy: No head-to-head evidence met inclusion criteria. The current evidence is limited to placebo-controlled trials. Compared with placebo, adalimumab, etanercept, and infliximab produced greater response rates. | NA
Key Question 2: Functional Capacity or Health-related Quality of Life
Synthetic DMARDs | Comparative efficacy: No head-to-head evidence met inclusion criteria. Current evidence is limited to placebo-controlled trials. Compared with placebo in one study, leflunomide provided better improvement in functional capacity and health-related quality of life. | NA
Biologic DMARDs | Comparative efficacy: No head-to-head evidence met inclusion criteria. Current evidence is limited to placebo-controlled trials. Compared with placebo, adalimumab, etanercept, and infliximab led to greater improvement in functional capacity and health-related quality of life. | NA
Key Question 3: Comparative Tolerability and Safety of Drug Therapy
Synthetic DMARDs | No head-to-head evidence met inclusion criteria. Current evidence is limited to placebo-controlled trials. Compared with placebo, leflunomide led to higher rates of withdrawals because of adverse events, diarrhea, and clinically significant increases in alanine aminotransferase. | NA
Biologic DMARDs | No head-to-head evidence met inclusion criteria. Current evidence is limited to placebo-controlled efficacy trials. In these, overall adverse event profiles appeared to be similar for biologic DMARDs and placebo. Injection site reactions: adalimumab and etanercept had more injection site reactions than placebo. | NA
Key Question 4: Differences by Subgroups: No Evidence

DMARD; disease-modifying antirheumatic drug; NA, not applicable.

* Findings are limited to placebo-controlled studies.

† No head-to-head studies that evaluated comparative effectiveness in psoriatic arthritis met the inclusion criteria.

### Psoriatic Arthritis

No head-to-head comparative evidence meeting inclusion criteria exists for any drugs in this review for treating patients with PsA. Parenteral high-dose MTX and sulfasalazine improved patient outcomes compared with placebo.111 Additionally, patients taking leflunomide had higher response rates and quality of life outcomes than those taking placebo.112,113

Evidence supports the general efficacy of adalimumab, etanercept, and infliximab for the treatment of PsA.114–122 However, evidence is insufficient to draw firm conclusions about the comparative efficacy, effectiveness, functional status, health-related quality of life, or tolerability of abatacept, adalimumab, anakinra, etanercept, infliximab, and rituximab for the treatment of PsA.

Information is insufficient for the harms, tolerability, adverse events, and adherence for patients with psoriatic arthritis. The available studies include only placebo-controlled studies; no head-to-head studies meeting inclusion criteria have been published.

## Future Research

We have identified several areas needing further research to help clinicians and researchers arrive at stronger conclusions on the comparative efficacy, effectiveness, quality of life, and harms of medications for both RA and PsA.

### Rheumatoid Arthritis

Important areas that will influence clinical decisionmaking include three critical topics: (1) timing of initiation of therapies, (2) applicability of combination strategies and biologic DMARD therapy in community practice, and (3) specific head-to-head comparisons focusing on different combination strategies and different biologic DMARDs. Analyses involving subpopulations, specifically those defined by age and coexisting conditions, will be beneficial, given that RA disease onset generally occurs in middle age, when the risk of comorbidities increases.

Timing of initiation of therapies needs to be addressed, including whether aggressive early treatment in RA influences the course and prognosis beneficially. Adequately powered, long-term RCTs must examine different treatment strategies with and without corticosteroids, synthetic DMARDs, and biologic DMARDs to determine the best therapy to prevent or minimize debilitating joint damage in this population. These trials should be conducted over multiple years to guarantee that results provide a relevant assessment of the long-term prognosis of RA under different treatment strategies. Such trials would also provide insight about whether the long-term benefits of any combination of drugs outweigh the adverse effects.

Given that available long-term data indicate high discontinuation rates for drugs used to treat RA, having backup regimens is crucial. Additional well-conducted research is needed to assess the comparative efficacy and safety of synthetic DMARDs in patients who currently do not qualify for a treatment with a biologic DMARD. Also still unclear is whether newer synthetic DMARDs such as leflunomide have a better, long-term adverse events profile than older synthetic DMARDs such as MTX. Additionally, although combination strategies with synthetic DMARDs with or without corticosteroids appear more effective, further research examining which combination strategy is more effective would be beneficial for medical treatment decisionmaking.

Moreover, head-to-head RCTs need to establish the comparative effectiveness and safety of biologic DMARDs. Currently, evidence from systematic reviews, placebo-controlled trials, and observational studies is insufficient to draw any firm conclusions. Biologic DMARDs differ substantially in the route and frequency of administration, which can influence the choice of a biologic agent by patients and physicians. Establishing the comparative effectiveness and safety of biologic DMARDs, therefore, is helpful for balanced, informed decisionmaking.

The risk of rare but serious adverse events such as malignancies, serious infections, demyelinations, severe infusion reactions, or congestive heart failure must be established in well- conducted observational studies, such as large cohort or case-control studies. The balance of risks and benefits of biologic DMARDs can be determined reliably only if good long-term data on such harms are available.

In general, all future studies have to ensure a high rate of applicability to patients seen in community practices. Future research has to establish the comparative effectiveness, health-related quality of life, and safety of all therapies, but especially biologic DMARDs, in settings that reflect daily clinical care and take into account factors such as varying adherence because of administration schedules, costs, and adverse events. The current evidence indicates that severity of disease and population characteristics may differ substantially between the highly selected populations enrolled in efficacy trials and those treated in daily clinical practice. Future trials must plan subgroup analyses in older patients or patients with comorbidities a priori.

### Psoriatic Arthritis

For this condition, the available evidence is limited to placebo-controlled trials (six studies and two systematic reviews). The quality of studies on synthetic DMARDs is sparse and fraught with methodological issues.

Areas of future research are similar to the ones on RA outlined above. Head-to-head RCTs have to establish the comparative efficacy and safety of different treatment strategies with and without corticosteroids, synthetic DMARDs, and biologic DMARDs to determine the best therapy to prevent or minimize debilitating joint damage.

Furthermore, head-to-head RCTs have to determine the comparative effectiveness and safety of biologic DMARDs for the treatment of PsA.

More generally, the issues of effectiveness, subgroups, and use in ordinary clinical settings highlighted for RA warrant attention for PsA as well.