# Appendix H Characteristics of Studies With Poor Internal Validity

Study | Design | Sample Size | Intervention | Reason for Exclusion
† Bathon et al., 2006^1^ | Pooled data analysis | 2,402 | Etanercept | Selection bias
de Nijs et al., 2001^2^ | Cross-sectional | 410 | Corticosteroids | Selection bias
Faarvang et al., 1993^3^ | RCT | 91 | Hydroxychloroquine Sulfasalazine | No ITT analysis; high LTF
†Fleischmann et al., 2003^4^ | Pooled data analysis | 1128 | Etanercept | Selection bias
‡ Flendrie et al, 2003^5^ | Retrospective cohort study | 230 | Adalimumab Etanercept Infliximab | High differential LTF; no ITT analysis
Flendrie et al., 2005^6^ | Observational | 162 | Leflunomide infliximab | High LTF; selection bias
Hansen et al., 1999^7^ | RCT | 102 | DMARDs Prednisolone | High attrition; no ITT analysis
‡ Langer et al., 2003^8^ | Post-marketing surveillance | 454 | Anakinra | No comparison group; no ITT analysis
‡ Moreland et al., 2006^9^ | Pooled retrospective analysis | 714 | Etanercept | High LTF; completers analysis only
‡ O’Dell et al., 2006^10^ | Prospective open-label study | 119 | Etanercept Hydroxychloroquine Sulfasalazine | Bias due to poor ITT design
‡ Svensson et al, 2003^11^ | Open-label RCT | 245 | Methotrexate Prednisolone Sulfasalazine | High post-randomization exclusions; high differential LTF

ITT, intention to treat; LTF, loss to followup; RCT, randomized controlled trial.

† Included for subgroups

‡ Rated fair for adverse events

## References

1 Bathon JM, Fleischmann RM, Van der Heijde D, Tesser JR, Peloso PM, Chon Y, et al. (2006). Safety and efficacy of etanercept treatment in elderly subjects with rheumatoid arthritis. J Rheumatol.
2 de Nijs RN, Jacobs JW, Bijlsma JW, Lems WF, Laan RF, Houben HH, et al. (2001). Prevalence of vertebral deformities and symptomatic vertebral fractures in corticosteroid treated patients with rheumatoid arthritis. Rheumatology (Oxford).
3 Faarvang K, Egsmose C, Kryger P, Podenphant J, Ingeman Nielsen M, Hansen TM. (1993). Hydroxychloroquine and Sulphasalazine Alone and in Combination in Rheumatoid Arthritis: a Randomised Double Blind Trial. Annals of the rheumatic diseases.
4 Fleischmann RM, Baumgartner SW, Tindall EA, Weaver AL, Moreland LW, Schiff MH, et al. (2003). Response to etanercept (Enbrel) in elderly patients with rheumatoid arthritis: a retrospective analysis of clinical trial results. J Rheumatol.
5 Flendrie M, Creemers MC, Welsing PM, den Broeder AA, van Riel PL. (2003). Survival during treatment with tumour necrosis factor blocking agents in rheumatoid arthritis. Ann Rheum Dis.
6 Flendrie M, Creemers MC, Welsing PM, van Riel PL. (2005). The influence of previous and concomitant leflunomide on the efficacy and safety of infliximab therapy in patients with rheumatoid arthritis; a longitudinal observational study. Rheumatology (Oxford).
7 Hansen M, Podenphant J, Florescu A, Stoltenberg M, Borch A, Kluger E, et al. (1999). A Randomised Trial of Differentiated Prednisolone Treatment in Active Rheumatoid Arthritis. Clinical Benefits and Skeletal Side Effects. Annals of the rheumatic diseases.
8 Langer HE, Missler-Karger B. (2003). Kineret: efficacy and safety in daily clinical practice: an interim analysis of the Kineret response assessment initiative (kreative) protocol. Int J Clin Pharmacol Res.
9 Moreland LW, Weinblatt ME, Keystone EC, Kremer JM, Martin RW, Schiff MH, et al. (2006). Etanercept treatment in adults with established rheumatoid arthritis: 7 years of clinical experience. J Rheumatol.
10 O’Dell JR, Petersen K, Leff R, Palmer W, Schned E, Blakely K, et al. (2006). Etanercept in combination with sulfasalazine, hydroxychloroquine, or gold in the treatment of rheumatoid arthritis. J Rheumatol.
11 Svensson B, Ahlmen M, Forslind K. (2003). Treatment of early RA in clinical practice: a comparative study of two different DMARD/corticosteroid options. Clin Exp Rheumatol.