# Appendix F Abstract-Only Studies

1. Cassell S, Tutuncu Z, Kremer J, Lee SJ, Reed G, Pugliese D, et al. Psoriatic arthritis patients have different rates of adverse events than rheumatoid arthritis patients when treated with TNF inhibitors: analysis from CORRONA Database [Abstract 491]. Arthritis Rheum 2005;52(Suppl 9):S211–S212.
2. Emery P, Breedveld FC, Jubb RW, Sorensen H, Oed C, Loew-Friedrich I. Efficacy and safety of leflunomide vs. methotrexate in rheumatoid arthritis (RA): results of a double-blind, randomized, 2-year trial. Arthritis and Rheumatism 1999;42(9 (Suppl)):S271.
3. Furst D, Luggen M, Thompson A, Coleman J. Adding leflunomide to patients with active rheumatoid arthritis patients while receiving methotrexate improves physical function and health related quality of life. Arthritis and Rheumatism 2000;43(Suppl):S344.
4. Keystone E, Haraoui B, Bykerk V. Role of Adalimumab in the Treatment of Early Rheumatoid Arthritis. Clinical and experimental rheumatology. 2003;21(5 Suppl 31):S198–9.
5. Kievit W, Fransen J, Kupper HH, Van de Laar MAFJ, De Rooij DJRA, De Gendt CM, et al. The drug survival of adalimumab compared to etanercept and infliximab in the treatment of patients with rheumatoid arthritis in daily clinical practice. Ann Rheum Dis 2006;65(Suppl 2):325.
6. Kremer JM, Caldwell JR, Cannon GW, Genovese M, Cush JJ, Bathon J. The combination of leflunomide and methotrexate in patients with active rheumatoid arthritis who are failing on methotrexate treatment alone: a double-blind placebo-controlled study. Arthritis Rheum 2000;43(Suppl 9):S224.
7. Manadan AM, Mohan AK. Tuberculosis and etanercept treatment. Arthritis Rheum 2002;46:S166.
8. Moreland LW, Cohen SB, Baumgartner S, Schiff M, Tindall EA, Burge DJ. Long-term use of etanercept in patients with DMARD-refractory arthritis. Arthritis Rheum 1992;42(Suppl 9):S401.
9. O’Dell J, Leff R, Paulsen G, Haire C, Mallek J, Eckhoff PJ. Methotrexate (M)-Hydroxychloroquine (H)-Sulfasalazine (S) versus M-H or M-S for rheumatoid arthritis (RA): results of a double-blind study. Arthritis Rheum 1999;42(Suppl 9):S117.
10. Ruderman EM, Markenson J. Granulomatous infections and tumor necrosis factor antagonists therapy: update through June 2002. Arthritis Rheum 2003;48(9):S241.