# Appendix E Evidence Tables

Abbreviations used in the evidence tables
ACR | American College of Rheumatology
ADA | adalimumab
AEs | adverse events
AIDS | acquired immunodeficiency syndrome
AIMS | Arthritis Impact Measurement Scales
ANA | anakinra
ARA | American Rheumatism Association criteria (pre-1987)
AS | ankylosing spondylitis
ASHI | Arthritis-Specific Health Index (Medical Outcomes Study Short Form SF- 36 Arthritis-specific Health Index)
AUC | area under the curve
BUD | budesonide
Ccs | corticosteroids
CFS | chronic fatigue syndrome
CHF | coronary heart failure
Cm | centimeters
Combo | combination therapy
CI | confidence interval
CHD | coronary heart disease
COPD | Chronic Obstructive Pulmonary Disease
CRP | C-reactive protein
CVD | cardiovascular disease
CXT | cyclophosamide
CYP | cyclosporine
Ds | days
DM | diabetes mellitus
DAS | Disease Activity Score
DMARD | disease modifying antirheumatic drug
D-HAQ | Dutch version of the Health Assessment Questionnaire (HAQ)
EQ-5D– | Quality of Life Questionnaire
ESR | erythrocyte sedimentation rate
ETA | etanercept
EULAR | European League against Rheumatism
EuroQol EQ-5D | European Quality of Life Questionnaire
EuroQOL VAS | European Quality of Life Visual Analogue Scale
GI | gastrointestinal
HAQ | Health Assessment Questionnaire
HAQ-DI | Disability Index of the Heath Assessment Questionnaire (HAQ)
HIV | Human immunodeficiency virus
HLA-DR4 | Human immune-response, D-related antigen encoded by the D locus on chromosome 6
HR | hazard ratio
HRQOL | health related quality of life
ICD | International Classification of Diseases
INF | infliximab
ISRs | injection site reactions
ITT | intention to treat
JRA | juvenile rheumatoid arthritis
HCQ | hydroxychloroquine
JSN | joint space narrowing
LEF | leflunomide
MTX | methotrexate
Mg | milligrams
mSharp Scale | Modified Sharp Method for Scoring Radiographs
mos | months
MHAQ | Modified Health Assessment Questionnaire
NSAIDs | non-steroidal anti-inflammatory drugs
NSFHS | National Survey of Functional Health Status
NA | not applicable
NMSC | non-melanoma skin cancer
NR | not reported
NS | not significant
NYHA | New York Heart Association
OA | osteoarthritis
OR | odds ratio
OMERACT | Outcome Measures in Rheumatology Clinical Trials
PASI | Psoriasis Area and Severity Index
PNL | prednisolone
PRED | prednisone
PsA | psoriatic arthritis
PsARC | Psoriatic Arthritis Response Scale
Pt | patient
PY | person-year
QOL | quality of life
RCT | randomized controlled trial
RAI | Ritchie Articular Index
RA | rheumatoid arthritis
RDS | radiological damage score
RF | rheumatoid factor
RIT | rituximab
RR | risk ratio
SAEs | serious adverse events
SAARDs | slow-acting anti-rheumatic drugs
SCC | squamous cell carcinoma
SD | standard deviation
SF-36 | Medical Outcomes Study Short Form 36 Health Survey
SJC | swollen joint count
SHS | Sharp/van der Heijde Method (SHS) for Scoring Radiographs
SIR | standardized incidence ratio
SLE | Systemic Lupus Erythematosus
SMR | standardized morbidity ratio
SSZ | sulfasalazine
SSTG | South Swedish Arthritis Treatment Group
TB | Tuberculosis
TIM | targeted immune modulator
TJC | tender joint count
TNF | tumor necrosis factor
Txt | treatment
URTI | upper respiratory tract infection
UTI | urinary tract infection
vs. | versus
yrs | years
w/ | with
w/in | with in
w/o | with out

Evidence Table 1

KQ 1. Rheumatoid arthritis trials: treatment response, disease progression, and remission

Study Characteristics | Inclusion and Exclusion Criteria | Characteristics and Interventions | Baseline Disease and Txt Characteristics | Health Outcomes | Adverse Events, % | Analysis and Quality Rating
Author, yr: Bathon, 2000; Genovese 2002; Kosinski et al., 2002; Genovese, 2005 ERA study Country, Setting: US, clinics Funding: Immunex Research Objective: To compare ETA and MTX in pts with early RA Study Design: RCT Overall N: 632 (468 extension) Study Duration: 12 mos (1 year open label extension; 2 more years, total of 5 yrs) | Inclusion Criteria: • Age: 18+ • Diagnosed with RA according to ACR criteria • Duration of condition: < 3 yrs • Positive serum test for RF or at least 3 bone erosions evident on radiographs of hands, wrists, or feet • At least 10 swollen joints and at least 12 tender or painful joints • ESR ≥ 28 mm per hour • Serum CRP concentration of at least 2.0 mg per deciliter • Morning stiffness that lasted at least 45 minutes • Stable doses of NSAIDS and PRE allowed Exclusion Criteria: • Prior txt with MTX • No other important concurrent illnesses | Interventions, dose: D1: MTX (19 mg/wk) D2: ETA (10 mg twice wkly) D3: ETA (25 mg twice wkly) N: D1: 49 D2: 50 D3: 51 Mean age, yrs: D1: 49 D2: 50 D3: 51 Sex, % female: D1: 75 D2: 75 D3: 74 Race, % white: D1: 88 D2: 84 D3: 86 | Mean disease duration, yrs: D1: 12 mos D2: 11 mos D3: 12 mos TJC, mean: D1: 30 (16.1) D2: 31 (15.5) D3: 31 (15.8) SJC, mean: D1: 24 (11.9) D2: 24 (11.7) D3: 24 (11.9) DMARD use, %: NR Corticosteroid use, % D1: 41 D2: 42 D3: 39 MTX naive, %: D1: 100 D2: 100 D3: 100 Txt resistant, %: NR Pts with Early RA (≤3 yrs): D1: 100 D2: 100 D3: 100 Baseline DAS, mean: NR | First 12 weeks Mean changes in SF-36, HAQ, and ASHI significantly better in with ETA vs. MTX (P < 0.0001) 16 to 52 weeks No significant difference in SF-36, HAQ, and ASHI scores between groups At 6 months Significantly more pts on ETA (25 mg) than on MTX achieved ACR50 and ACR70 responses (data NR, P < 0.05) At 12 months ACR 20 response rates, %: D1: 65 D3: 72 (P = 0.16) Mean increase in Sharp score D1: 1.00 D3: 1.59 (P = 0.11) Erosion score change D1: 1.03 D3: 0.47 (P = 0.002) Despite improvement, QoL measures remained below general population (P < 0.0001); at start QoL measures were significantly below that of general population (P < 0.0001) 24 month open-label extension: ACR20,% D1: 59 D3: 72 (P = 0.005); ACR50, % D1: 49 D3: 42 ACR 70,% D1: 29 D2: 24 HAQ improvement of at least 0.5 units, %: D1: 55 D2: 37 (P < 0.001) Total modified Sharp score change D1: 1.3 D3: 3.2 (P = 0.001) Erosion score change D1: 0.7 D3: 1.9 (P = 0.001) | At year 2 SAEs: 20.6 Cardiovascular Events: 1.8 MI Malignancies: 3% overall Total events: 18 Breast: 3 Prostate: 3 Colon: 3 Lung: 12 Malignant melanoma: l2 Leukemia: 1 Kidney: 1 Hodgkins: 1 Adenocarcinoma: 1 URTI: Pnuemonia 2 Overall SAE rate of 0.093 events per pt- year comparable to rate observed in first year of efficacy study, events per pt- year MTX: 0.109 ETA: 0.091 | Overall Attrition Rate, %: 19 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Boers et al., 1997; Landewe et al., 2002 COBRA study Country, Setting: Netherlands and Belgium, multicenter Funding: Netherland Research Objective: Comparing efficacy and radiographic outcomes of combination of SSZ, MTX and PNL with SSZ alone Study Design: RCT Overall N: 155 (148) Study Duration: 56 wks; (5 yr followup) | Inclusion Criteria: • Age: 18 to 69 • Diagnosed with RA according to ACR criteria • Duration of condition < 2 yrs • NSAID txt at least 3 mos, 6 or more active inflamed joints AND presence of 2 or more (9 or more tender joints, morning stiffness 45 min or more, EST of 28 or more in first hour Exclusion Criteria: • Pregnant or lactating: adequate contraception • Prior txt with: DMARDS except HCQ or steroids • Past TB • Impaired renal or hepatic system serious comorbidity surgery in past 3 mos • Unable to comply with protocol • • Allergy to study med • Alcohol or substance abuse | Interventions, dose: D1: Combined txt (SSZ, MTX, PNL) D2: SSZ Only SSZ: 2g/d MTX: 7.5 mg/wk, weaned after 40 wks PNL: 60 mg/d wk 1 40 mg/d wk 2 25 mg/d wk 3 20 mg/d wk 4 15 mg/d wk 5 10 mg/d wk 6 then 7.5 mg/d until wk 28 then weaned off N: D1: 76 D2: 79 Mean age, yrs: NR Sex, % female: D1: 66% D2: 52% Race, % white: NR | Mean disease duration, yrs: D1: 4 mos D2: 4 mos TJC, mean: NR SJC, mean: NR Antimalarial use (%): D1: 21 D2: 24 Corticosteroid use, % NR MTX naive, %: NR Txt resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR Erosions on hand or foot xrays, %: D1: 74 D2: 79 | At week 28 Mean pooled index D1: − 1.4 (95% CI, 1.2–1.6) D2: − 0.8 (95% CI, 0.6–1.0) (P < 0.0001) ACR20, %: D1: 72 D2: 49 (P = 0.006) ACR50, %: D1: 49 D2: 27 (P = 0.007) DAS median change: D1: −2.1 (SD 1.2) D2: −1.3 (SD 1.2) (P < 0.0001) HAQ mean change: D1: −1.1 (SD 0.8) D2: −0.6 (SD 0.6) (P < 0.0001) Sharp mean change: D1: 1 D2: 4 (P < 0.001) At week 56 Mean pooled index: D1: 1.1 (SD 0.8) D2: 0.9 (SD 0.8) (P =0.20) DAS median change: D1: 1.4 (SD 1.2) D2: 1.3 (SD 1.4) (P = 0.78) HAQ mean change: D1: 0.8 (SD 0.8) D2: 0.6 (SD 0.7) (P < 0.06) Sharp mean change: D1: 2 D2: 6 (P < 0.004) At week 80 Sharp mean change: D1: 4 D2: 12 (P < 0.01) Five yr follow up Sharp score mean change: D1: 5.6 (95% CI, 4.3, 7.1) (P = 0.001) D2: 8.6 (95%CI, 6.2–11) (P = 0.001) Time averaged DAS28, points/yr: D1: −0.07 D2: −0.17 | Overall: D1: 72.3 D2: 62.0 SAEs: D1: 2.6 D2: 7.6 Infections: D1: 15.8 D2: 7.6 Cardiovascular Events: D1: 7.9 D2: 5.1 Hepatotoxicity: D1: 2.6 D2: 0 | Overall Attrition Rate, %: 3.2 ITT Analysis: Yes Quality Rating: Good
Author, yr: Breedveld et al., 2006 PREMIER study Country, Setting: Multinational (Europe, North America, Australia), multicenter (133) Funding: Abbott Laboratories Research Objective: To compare efficacy and safety of ADA + MTX vs. MTX or ADA in pts with early, aggressive RA (RA) who had not previously received MTX txt Study Design: RCT Overall N: 799 Study Duration: 2 yrs | Inclusion Criteria: • Age: 18+ • Diagnosed with RA according to ACR criteria • Duration of condition: 3 yrs or less • MTX naive pts • > 8 swollen joints, > 10 tender joints, and an erythrocyte sedimentation rate of > 28 • Folic acid only other med allowed Exclusion Criteria: • Prior txt with: MTX, cyclophosphamide, cyclosporine, azathioprine | Interventions, dose: D1: MTX (20 mg/wk) D2: ADA (40 mg/biwkly) D3: ADA (40 mg/biwkly) + MTX (20 mg/wk) N: D1: 257 D2: 274 D3: 268 Mean age, yrs: D1: 52 D2: 52.1 D3: 51.9 Sex, % female: D1: 73.9 D2: 77.4 D3: 72 Race, % white: NR | Mean disease duration, yrs: D1: .8 D2: .7 D3: .7 TJC, mean: D1: 32.3 D2: 31.8 D3: 30.7 SJC, mean: D1: 22.1 D2: 21.8 D3: 21.1 DMARD use, %: NR Corticosteroid use, % D1: 35.4 D2: 36.5 D3: 35.8 MTX naive, %: NR Txt resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 6.3 D2: 6.4 D3: 6.3 HAQ: D1: 1.5 D2: 1.6 D3: 1.5 Erosion score: D1: 13.6 D2: 11.3 D3: 11.0 | At 6 months Radiographic progression; change in Sharp scores: D1: 3.5 D2: 2.1 (P < 0.001) At 1 yr Radiographic progression; change in Sharp scores: D1: 5.7 D2: 3.0 (P < 0.001) HAQ DI improvement, mean units +/− sd: D1: −0.8 +/− 0.7 D2: −0.8 +/− 0.6 D3: −1.1 +/− 0.6 D2 vs. D1, P = NR D3 vs. D1: P < 0.001 D3 vs. D2: P = 0.002) At 2 yrs ACR50 response, %: D1: 43 D2: 37 D3: 59 D3 vs. D2 or D1: P < 0.001 D1 vs. D2: P= NS Clinical remission, %: D1: 25 D2: 25 D3: 49 (both P < 0.001) Radiographic progression; change in Sharp scores: D1: 10.4 D2: 5.5 (P < 0.001) Withdrawal because of lack of efficacy, %: D1: 18 D2: 19 D3: 4.9 HAQ DI improvement, mean units +/− sd: D1: −0.9 +/− 0.6 D2: −0.9 +/− 0.7 D3: −1.0 +/− 0.7 D2 vs. D1, P = NR D3 vs. D1; P < 0.05 D3 vs. D2; P = 0.058 % with HAQ DI score of zero: D1: 19 D2: 19 D3: 33 D3 vs. D2, P < 0.001 D3 vs. D1: P < 0.001 % with HAQ DI improvement of ≥0.22 units from baseline: D1: 63 D2: 58 D3: 72 D3 vs. D2, P < 0.05 D3 vs. D1: P < 0.05 | SAEs: D1: 18.5 D2: 21.1 D3: 15.9 Infections: D1: 123 D2: 110 D3: 119 Serious Infections: D1: 2.9 D2: 0.7 D3: 1.6 Malignancies: D1: 0.4 D2: 0.9 D3: 0.9 Withdrawal because of adverse events: D1: 7% D2: 10% D3: 12% | Overall Attrition Rate, %: 32% ITT Analysis: Yes Quality Rating: Fair
Author, yr: Capell, 2006 Country, Setting: Scotland, 8 NHS sites Funding: Wyeth and Pharmacia - drugs Arthritis Research Campaign Research Objective: If a combination of SSZ and MTX is superior to either alone in RA pts with supoptimal response to 6 mos of SSZ Study Design: RCT Overall N: 165 Study Duration: Phase I: 6 mos; Phase 2: 12 additional mos for those with DAS > 2.4 after 6 mos | Inclusion Criteria: • Age: 18 to 80 • Duration of condition: < 10 yrs • Active disease defined by DAS > 2.4 after 6 mos SSZ txt were eligble for phase II • NSAIDs and other medications were continued • Intra-articular or intramuscular corticosteroid was permitted but not within 1 mo of 6, 12, & 18 mo assessments Exclusion Criteria: • Pregnant or lactating • Prior txt with: MTX or SSZ • Impaired renal or hepatic system: creatinine > 150 mmol/dl, ALT, aspertate aminotransferase > 80 IU/l, alkaline phosphatase > 700 IU/l, gamma GT x3 • Other: abnormal white cell count (< 4 × 10*9/l) • Pre-existing pulmonary fibrosis • Use of oral steroids > 7.5 mg/d • Known SSZ allergies | Interventions, dose: D1: SSZ + MTX D2: SSZ + placebo D3: MTX + placebo Phase I MTX: 7.5 mg/w (3 × 2.5 mg) increasing by 2.5 mg/mo until max of 25 mg or toxicity SSZ: enteric coated 500 mg/d increased by 500 mg/wkly until 40 mg/kg per d to a max of 4g/d for initial 6 mos Placebo: Folic Acid 5 mg/wk given 3 days after MTX and MTX + placebo N: D1: 56 D2: 55 D3: 54 Overall: 687 Mean age, yrs: D1: 56 D2: 55 D3: 53 Overall: 55 Sex, % female: D1: 75 D2: 75 D3: 79 Overall: 77 Race, % white: NR | Mean disease duration, yrs: D1: 1.9 D2: 1.6 D3: 1.8 TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, % NR MTX naive, %: All Txt resistant, %: All Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 3.63 D2: 3.67 D3: 3.5 Sharp: D1: 17.0 D2: 14.0 D3: 12.0 | Median change 18 mos: DAS: D1: −0.67 D2: −0.30 D3: −0.26 (D1 vs. D2; P = 0.039) (D1 vs. D3; P = 0.023) (D2 vs. D3; P = 0.79) HAQ: D1: −0.50 D2: −0.25 D3: −2.00 (D1 vs. D2; P = 0.51) (D1 vs. D3; P = 0.57) (D2 vs. D3; P = 0.99) SJC: D1: −3.00 D2: −3.00 D3: −2.00 (D1 vs. D2; P = 0.94) (D1 vs. D3; P = 0.81) (D2 vs. D3; P = 0.74) ACR20, %: D1: 29 D2: 18 (OR 1.25 (95% CI, 0.56–2.79); P = 0.68) D3: 15 (OR 2.01 (95% CI, 0.85–4.76), P = 0.14) ACR50, %: D1: 11 D2: 6 (OR 1.43 (95% CI, 0.43–4.81), P = 0.76) D3: 7 (OR 1.79 (95% CI, 0.49–6.49), P = 0.53) ACR70, %: D1: 4 D2: 2 (OR 1.50 (95% CI, 0.24–9.34), P = 1.00) D3: 2 (OR 3.00 (95% CI, 0.30–29.78), P = 0.62) | NR | Overall Attrition Rate, %: 28.5 • 687 pts entered phase I (6 mos) • At 6 mos, 165 were not eliglbe to enter phase II (discontinued SSZ because of side effects: 19%, did not attend: 3.6%, died: 0.4%) • Another 191 were not randomized because DAS score was < 2.4 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Combe et al., 2006 Country, Setting: Europe, multicenter Funding: Wyeth Research Objective: To compare efficacy and safety of ETA and SSZ, alone and in combination, in pts with active RA despite SSZ txt Study Design: RCT Overall N: 260 Study Duration: 24 wks | Inclusion Criteria: • Age > 18 • Diagnosed according to ACR criteria; • Functional class of: I–III • Previous use of DMARDs: 2 to 3g SSZ/d for ≥ 4, w/o toxicity • Duration of condition < 20 yrs • Stable doses of oral corticosteroids (10 mg/d of PRE or equivalent), one NSAID, simple analgesics with no anti-inflammatory action or daily doses of aspirin (300 mg) Exclusion Criteria: • Prior txt with: (1) ETA or other TNF antagonists or (2) received a DMARD other than SSZ within 3 mos. Or any biologic or cyclophosphamide within 6 mos, corticosteroids within 4 wks • Presence of relevant comorbidity, including active infections | Interventions, dose: D1: SSZ (2,2.5, or 3 g/d) + placebo D2: ETA (25 mg SC twice wkly) + placebo D3: ETA (25 mg SC twice wkly) + SSZ (2,2.5, or 3 g/d) N: D1: 50 D2: 103 D3: 101 Overall: 254 Mean age, yrs: D1: 53.3 D2: 51.3 D3: 50.6 Overall: 51.4 Sex, % female: D1: 82.0 D2: 78.6 D3: 80.2 Overall: 79.9 Race, % white: NR | Mean disease duration, yrs: D1: 5.6 (sd 4.4) D2: 7.1 (sd 5.2) D3: 6.5 (sd 5.1) TJC, mean: D1: 14.0 D2: 14.7 D3: 14.1 SJC, mean: D1: 11.1 D2: 10.1 D3: 10.4 DMARD use, %: D1: 58.0 D2: 69.9 D3: 58.4 Corticosteroid use, % D1: 40.0 D2: 59.2 D3: 44.6 MTX naive, %: NR Txt resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 5.0 D2: 5.1 D3: 5.2 | At 24 weeks ACR20, %: D1: 28.0 D2: 73.8 D3: 74.0 (P < 0.01) ACR50, %: D1: 14.0 D2: 46.6 D3: 52.0 (P < 0.01) ACR70, %: D1: 2.0 D2: 21.4 D3: 25.0 (P < 0.01) In groups receiving ETA, significant differences in ACR core components were observed by wk 2 compared with those receiving SSZ alone (P < 0.01) DAS improvement, %: D1: 19.6 D2: 48.2 D3: 49.7 (P < 0.01) Mean HAQ improvement, %: D1: 9.2 D2: 35.3 D3: 40.2 (P < 0.01) Mean % improvement EuroQOL VAS D2: 64.6 D3: 67.6 (P = NS, NR) No meaningful clinical advantage to use of ETA in combination with SSZ | Infections: D1: 13 D2: 47 D3: 31 Infusion or injection reaction: D1: 3 D2: 38 D3: 21 Abdominal Pain: D1: 0 D2: 7 D3: 8 Headache: D1: 4 D2: 5 D3: 15 Nausea: D1: 3 D2: 3 D3: 12 URTI: D1: 5 D2: 10 D3: 11 | Overall Attrition Rate, %: 13 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Dougados et al., 1999 and Maillefert et al., 2003 Country, Setting: Finland, France, Germany (France only for 5 yr), multicenter Funding: Pharmacia Upjohn Research Objective: Clinical benefit of MTX + SSZ compared to either drug alone early, active RA pts fulfilling some criteria of poor potential long term outcome Study Design: RCT Overall N: 209 (146) Study Duration: 52 wks (5 yrs) | Inclusion Criteria: • Diagnosed according to ACR criteria • Duration < 1 yr • Presence of active disease as defined by DAS ≥ 3 (calculation based on Ritchie articular index, 44 SJC, and ESR) and presence of RF and/or HLA DR 1/4 • Concommitant drugs allowed were analgesics and NSAIDS Exclusion Criteria: • Prior txt with steroids, DMARDS, or any drugs to treat RA other than analgesic or NSAIDS • Pts with contraindications to use of SSZ or MTX | Interventions, dose: D1: SSZ + placebo D2: MTX + placebo D3: SSZ + MTX MTX: 7.5 mg wkly (2.5 mg 3 times per wk). After wk 16, could be increased to 15 mg wkly if efficacy inadequate SSZ: increased to 2 grams daily by d #9. Could be increased to 3 grams daily after wk 16 of study if efficacy was inadequate Other?: combo MTX + SSZ N: D1: 68 D2: 69 D3: 68 Mean age, yrs: D1: 52 D2: 50 D3: 52 Sex, % female: D1: 71 D2: 74 D3: 77 Race, % white: NR | Mean disease duration, yrs: D1: 2.9 mos since diagnosis, 10.8 since onset D2: 2.3 mos from diagnosis, 18.4 from onset D3: 3.4 mos from diagnosis, 10.6 from onset TJC, mean: NR SJC, mean: D1: 10.5 D2: 9.4 D3: 9.4 DMARD use, %: All groups: 0 Corticosteroid use, % All groups: 0 MTX naive, %: All groups: 100 Txt resistant, %: NR Pts with Early RA (≤3 yrs): All groups: 100 Baseline DAS, mean: D1: 4.23 D2: 4.13 D3: 4.24 RF positive, %: D1: 75 D2: 62 D3: 71 RAI: D1: 17.6 D2: 16.5 D3: 18.9 | DAS change: D1: −1.15 D2: −0.87 D3: −1.26 (P = 0.019 from inter-group comparisons using analysis of variance) RAI changes: D1: −7.1 D2: 4.2 D3: −9.4 (P = 0.001) ACR response, %: D1: 9 D2: 9 D3: 5 (P = NR) At 5 years Txt of pts with early RA with combination therapy of MTX and SSZ during first yr did not result in any long term differences in disease activity, quality of life, or structural damage compared to monotherapy with either drug used alone Mean DAS: D1: 2.2 (sd 1) D2: 2.2 (sd 1) D3: 2.2 (sd 1) (P = 0.9) HAQ: D1: 0.6 (0.7) D2: 0.6 (0.7) D3: 0.6 (0.6) (P = 0.9) Median radiologic score D2: 7.5 D3: 8.5: (P = 0.7)D3: 2.2 (sd 1.1) (P = 0.9) HAQ: D1: 0.6 (0.7) D2: 0.6 (0.7) D3: 0.6 (0.6) (P = 0.9) Median radiologic score D2: 7.5 D3: 8.5 (P = 0.7) Similar results with 3 groups (D3 vs. D2 vs. D1) instead of 2 groups (D3 vs. D2 or D1) when compared, but data not shown Attrition rate: 21% | Overall: D1: 75 D2: 75 D3: 91 Abdominal Pain: D1: 9 D2: 6 D3: 13 Dizziness: D1: 6 D2: 1 D3: 3 Headache: D1: 9 D2: 4 D3: 12 Nausea: D1: 32 D2: 23 D3: 49 | Overall Attrition Rate, %: 27% (28.8) ITT Analysis: Yes Quality Rating: Fair
Author, yr: Edwards, 2004 Country, Setting: Multinational, multicenter (26 rheumatology centers) Funding: Roche Research Objective: To confirm role of B cells in RA by evaluating effect of RIT in pts with active RA according to ACR and EULAR criteria Study Design: RCT Overall N: 161 Study Duration: 24 wks | Inclusion Criteria: • Age ≥ 21 • Diagnosed according to 1987 ACR criteria • Failed previous MTX treatment • > MTX 10 mg/wk and active disease • RF-positive • NSAIDS at stable doses or Css at doses < 12.5 mg per d of PNL • All received 17-d txt with Css and a 10 mg dose of leucovorin Exclusion Criteria: • Autoimmune disorder other than RA (except Srjogen’s) • Functional class IV • Active rheumatoid vasculitis • Systemic diseases associated with arthritis • CFS • Serious, uncontrolled diseases • Active infection • History of recurrent infection or recurrent bacterial infections with encapsulated organisms • Primary of secondary immunodeficiency • History of cancer | Interventions, dose: D1: MTX (≥10 mg/wk) D2: RIT (1000 mg on ds 1 and 15) D3: RIT (1000 mg on ds 1 and 15) + CYP (750 mg d 3,17) D4: RIT (1000 mg on ds 1 and 15) + MTX (≥10 mg/wk) N: D1: 40 D2: 40 D3: 41 D4: 40 Mean age, yrs: D1: 54 D2: 54 D3: 53 D4: 54 Sex, % female: D1: 80 D2: 73 D3: 83 D4: 75 Race, % white: NR | Mean disease duration, yrs: D1: 11 D2: 9 D3: 10 D4: 12 TJC, mean: D1: 32 D2: 34 D3: 33 D4: 32 SJC, mean: D1: 19 D2: 21 D3: 19 D4: 23 DMARD use (#): D1: 2.6+/− 1.3 D2: 2.5+/−1.6 D3: 2.6+/−1.4 D4: 2.5+/−1.4 Corticosteroid use, % NR MTX naive, %: 0 Txt resistant, %: 100 Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 6.9 D2: 6.8 D3: 6.9 D4: 6.8 | At 24 weeks ACR20, %: D2: 65 D4: 73 (P = NR) ACR50, %: D2: 33 D4: 43 (P = NR) ACR70, %: D2: 15 D4: 23 (P = NR) Rates of moderate or good EULAR responses, %: D2: 85 D4: 83 (P = NR) DAS: D2: −2.2 D4: −2.6 At 48 weeks ACR20, %: D2: 33 D4: 65 (P = NR) ACR50, %: D2: 15 D4: 35 (P = NR) ACR70, %: D2: 10% D4: 15% (P = NR) | Overall: D1: 80 D2: 80 D3: 73 D4: 85 SAEs: D1: 8.0 D2: 5.0 D3: 4.9 D4: 8.0 Infusion or injection reaction: D1: 30 D2: 45 D3: 32 D4: 33 Nausea: D1: 3 D2: 5 D3: 10 D4: 0 URTI: D1: 15 D2: 10 D3: 5 D4: 10 | Overall Attrition Rate, %: at 24 wks 6.2% at 48 wks 37.8% ITT Analysis: Yes Quality Rating: Fair
Author, yr: Emery, 2000 Country, Setting: Multinational, 117 centers Funding: NR Research Objective: To compare both short and long-term (up to 2 yr) clinical efficacy and safety of LEF and MTX for txt of RA Study Design: RCT Overall N: 999 Study Duration: 1 yr, optional second yr | Inclusion Criteria: • Age: 18+ • Diagnosed with RA according to ACR criteria: Active Disease • Previous use of DMARDs: only if discontinued 28 ds before trial • Duration of condition: for at least 4 mos, but no longer than 10 yrs • NSAIDs and steroids were allowed provided a stable dose of NSAIDs or steroid (≤10 mg/d) PNL for at least 28 ds prior to study entry • Women of childbearing age were required to use adequate contraception Exclusion Criteria: • Pregnant or lactating • Prior txt with: Intra-articular corticosteriod injections w/in 6 wks of efficacy assessment | Interventions, dose: D1: LEF Yr 1 D2: MTX Yr 1 D3: LEF Yr 2 D4: MTX Yr 2 MTX: 7.5 to 15 mg/wk LEF: loading dose of 100 mg/d for 3 ds, followed by maintenance dose 20/mg/d N: D1: 501 D2: 498 D3: 292 D4: 320 Mean age, yrs: D1: 58.3 D2: 57.8 D3: 57.7 D4: 57.0 Sex, % female: D1: 70.7 D2: 71.3 D3: 71.2 D4: 71.3 Race, % white: NR | Mean disease duration, yrs: D1: 3.7 D2: 3.8 D3: 3.5 D4: 3.8 TJC, mean: NR SJC, mean: NR DMARD use, %: D1: 66.3 D2: 66.9 D3: 64.7 D4: 66.9 Corticosteroid use, % D1: 36.3 D2: 33.5 D3: 14.0 D4: 11.3 MTX naive, %: NR DMARD Txt resistant, %: D1: 1.1 D2: 1.1 D3: 1.0 D4: 1.1 Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR NSAIDS, %: D1: 80 D2: 84.7 D3: 37.3 D4: 42.5 Larsen score: D1: 1.25 D2: 1.29 D3: 1.27 D4: 1.31 | At year 1 ACR20: D1: 50.5% D2: 64.8% (P < 0.001) HAQ improvement: Minimal quantitative difference between groups, but statistically significant (shown in figure only; P <0.05) Radiograph change, Larsen Scores: D1 and D2: 0.03 increase (P =NS, NR) Primary clinical efficacy endpoints: TJC: D1: −8.3 D2: - 9.7 SJC: D1: −6.8 D2: −9.0 Physician global assessment: D1: −0.9 D2: −1.2 Pt global assessment: D1: −0.9 D2: −1.2 At year 2 ACR20, %: D1: 64.3 D2: 71.7 (P = NS, NR) HAQ improvement: difference between groups in change from baseline HAQ, NS Radiograph change, Larsen Scores: No further increase in joint damage in pts txted with LEF and small improvement in MTX pts; small net result, but statistically significant difference with MTX better than LEF (overall scores and significance NR) | SAEs: D1: 7% D2: 8% Headache: D1: 6.2 D2: 4.8 Hepatotoxicity: D1: 5.4 D2: 16.3 D3: 2.7 D4: 5.9 Nausea: D1: 11.2 D2: 15.7 URTI: D1: 5.2 D2: 5.0 D3: 4.5 D4: 5.6 Deaths MTX: 2 | Overall Attrition Rate, %: • 26.3% (263/999) during yr 1 • Combined 2 yrs, attrition 50.3% (502/999) of those initially starting study at baseline • During yr 2, attrition 18.8% (115/612) of those agreeing to continue study for 2nd yr ITT Analysis: Yes Quality Rating: Fair
Author, yr: Geborek, 2002 Country, Setting: Sweden, primary care clinics, unversity clinic Funding: NR Research Objective: To assess efficacy and safety of ETA, INF, and LEF in a population- based setting Study Design: Nonrandomized open-label trial Overall N: 369 (33 pts tried 2 different txts and 1 tried all 3; 404 txts) Study Duration: 12 mos | Inclusion Criteria: • Age: 18+ • Previous use of DMARDs: required to have failed to respond to or not tolerated at least 2 DMARDs, including MTX • Diagnosis of RA according to clinical judgment of treating doctor • All pts included were required to have failed to respond to or not tolerated at least 2 DMARDs, including MTX • Pts were selected on basis of current disease activity and/or unacceptable steroid requirement as judged by treating doctor, but had different backgrounds concerning previous txt, concomitant diseases, and functional impairment and disability • Other meds allowed Exclusion Criteria: NR | Interventions, dose: D1: ETA (25 mg/twice wkly) D2: INF (3 mg/kg or higher) D3: LEF (20 mg/d) N: D1: 166 D2: 135 D3: 103 Mean age, yrs: D1: 54 D2: 55.4 D3: 61.3 Sex, % female: D1: 78 D2: 79 D3: 82 Race, % white: NR | Mean disease duration, yrs: D1: 14.9 D2: 14.1 D3: 14.9 TJC, mean: NR SJC, mean: NR DMARD use, %: D1: 100 D2: 100 D3: 100 Corticosteroid use, % D1: 83 D2: 81 D3: 73 MTX naive, %: D1: 0 D2: 0 D3: 0 Txt resistant, %: D1: 100 D2: 100 D3: 100 Pts with Early RA (≤3 yrs): NR | At 3 months ACR20/50: INF significantly higher than LEF (data NR; P < 0.01) ETA higher ACR 20 response rate than INF (data NR; P < 0.02) ETA had a significantly higher ACR50 response rate than INF (data NR; P <0.05) At 6 months ACR 20/50: ETA better than LEF (data NR; P < 0.01) ETA higher ACR 20 response rate than INF (data NR; P < 0.02) At 12 months No significant difference between ETA and INF ETA and INF led to significant reduction in prednisolone use starting at 2 wks No reduction in prednisolone use for LEF Baseline DAS, mean: D1: 5.8 D2: 5.6 D3: 5.4 HAQ: D1: 1.55 D2: 1.47 D3: 1.46 | Infusion reaction: 3.7% of INF pts experienced an infusion reaction | Overall Attrition Rate, %: N/A ITT Analysis: No Quality Rating: Fair
Author, yr: Genovese, 2004 Country, Setting: US, multicenter, specialty clinic Funding: Amgen, Inc., Thousand Oaks, CA Research Objective: To determine potential for additive or synergistic effects of combination therapy with selective anti-TNF-alpha agent ETA and anti-IL1 agent AKA Study Design: RCT Overall N: 242 Study Duration: 24 wks | Inclusion Criteria: • Age > 18 • RA according to ACR criteria • Duration of condition: > 6 mos • 6+ swollen joints • 9+ tender/painful joints • At least 2 of: morning stiffness lasting 45 or more minutes, serum CRP of > 1.5 mg/dl, or ESR > 28 mm/hr; and, MTX > 16 wks, stable dose of 10–25 mg/wk > 8 wks; continued txt with stable doses of MTX and other stable medications, such as corticosteroids Exclusion Criteria: • Any DMARD other than MTX within past 4 wks • Txt with AKA or any protein-based TNF-alpha inhibitor • Received any intraarticular or systemic corticosteroid injections within past 4 wks • Recent history of significant infection or other important concurrent illness | Interventions, dose: D1: ETA (25 mg twice wkly) D2: ETA (12.5 mg once wkly) + AKA (100 mg/d) D3: ETA (25 mg twice wkly) + AKA (100 mg/d) N: D1: 80 D2: 81 D3: 81 Mean age, yrs: D1: 54.4 D2: 53.8 D3: 55.7 Sex, % female: D1: 82.5 D2: 71.6 D3: 77.8 Race, % white: D1: 86.3 D2: 77.8 D3: 75.3 | Mean disease duration, yrs: D1: 9.7 D2: 9.5 D3: 10.6 TJC, mean: D1: 31 D2: 31 D3: 35.9 SJC, mean: D1: 21.4 D2: 19.8 D3: 23.4 DMARD use, %: NR Corticosteroid use, % D1: 48.8 D2: 54.3 D3: 44.4 MTX naive, %: Overall: 0 Txt resistant, %: Overall: 100 Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR MTX use, %: Overall: 100 HAQ: D1: 1.5 D2: 1.5 D3: 1.6 | At week 24 ACR20, %: D1: 68 D2: 51 D3: 62 D1 vs. D2 (P = 0.037) All others NS ACR50, %: D1: 41 D2: 39 D3: 31(P = 0.914) OR (ETA + AKA vs. ETA alone) 0.64 (90% CI, 0.37– 1.09); sensitivity analysis yielded similar results ACR70, %: D1: 21 D2: 24 D3: 14 (P = NR) Sustained ACR20 response: Between 43% and 54% of subjects in each group (specifics NR) EULAR response, %: D1: 79 D2: 66 D3: 73 (P = NR) Mean % reduction in DAS: D1: 39 D2: 41 D3: 40 (P = NR) | Overall: D1: 90 D2: 95.1 D3: 93.8 SAEs: D1: 2.5 D2: 4.9 D3: 14.8 Infections: D1: 40 D2: 37 D3: 46.9 Serious Infections: D1: 0 D2: 3.7 D3: 7.4 Infusion or injection reaction: D1: 40 D2: 67.9 D3: 70.4 URTI: D1: 20 D2: 11.1 D3: 13.6 | Overall Attrition Rate, %: 15.7 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Goekoop- Ruiterman et al., 2005 BeST Study Country, Setting: The Netherlands, 18 peripheral and 2 university hospitals Funding: Schering-Plough BV and Centocor Inc Dutch College of Health Insurances Research Objective: To compare clinical and radiographic outcomes of 4 different txt strategies in pts with early RA Study Design: RCT Overall N: 508 Study Duration: 12 mos | Inclusion Criteria: • Age > 18 yrs • RA according to ACR criteria • • Duration of condition < 2 yrs • • Active disease with at least 6 of 66 swollen joints • • At least 6 of 68 tender joints • • ESR > 28 mm/hr OR global health score greater than or equal to 20mm on 0 to 100 VAS • • Concomittant NSAIDS and intraarticular steroids Exclusion Criteria: • • Pregnant • Prior txt with: DMARDS other than antimalarials • Impaired renal or hepatic system • concomittant txt with an experimental drug • bone marrow hypoplasia • diabetes • alcohol or drug abuse • wish to conceive • inadequate contraception | Interventions, dose: D1: sequential monotherapy D2: step-up combination therapy D3: initial combination with PRE D4: initial combination with INF D5: NR Overall: Totals N: D1: 126 D2: 121 D3: 133 D4: 128 Overall: 508 Mean age, yrs: D1: 54 D2: 54 D3: 55 D4: 54 Overall: 54 Sex, % female: D1: 86 D2: 86 D3: 86 D4: 85 Overall: 86 Race, % white: NR | Mean disease duration, yrs: D1: 23 wks D2: 26 wks D3: 23 wks D4: 23 wks TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, % NR MTX naive, %: Overall: 100 Txt resistant, %: NR Pts with Early RA ( 3 yrs): Overall: 100 Baseline DAS, mean: D1: 4.5 +/− 0.9 D2: 4.5 +/− 0.8 D3: 4.4 +/− 0.9 D4: 4.3 +/− 0.9 D-HAQ (0 to 3 scale): D1: 1.4 +/−0.7 D2: 1.4 +/−0.6 D3: 1.4 +/−0.7 D4: 1.4 +/−0.7 | At 12 months Mean D-HAQ scores: D1: 0.7 +/− 0.7 D2: 0.7 +/− 0.6 D3: 0.5 +/− 0.5 D4: 0.5 +/− 0.5 (D1 vs. D3; P < 0.05) (D3 vs. D4; P = NS) All others NR Median total SHS increases (0 to 448 scale) from baseline: D1: 2.0 D2: 2.5 D3: 1.0 D4: 0.5 (D1 vs. D3; P = 0.003) (D1 vs. D4; P < 0.001) (D2 vs. D3; P = 0.007) (D2 vs. D4; P < 0.001) Progression of total SHS, %: D1: 67 D2: 73 D3: 87 D4: 93 (D1 vs. D3 and D4; P = 0.001) (D1 vs. D4; P < 0.001) (D2 vs. D3; P = 0.010) (D2 vs. D4; P < 0.001) Sharp van der Heijde median increase: D1: 2.0 D2: 2.5 D3: 1.0 D4: 0.5 (P < 0.001) Sustain DAS44 ≤ 2.4, %: D1: 53 D2: 64 D3: 71 D4: 74 (D1 vs. D3; P = 0.004) (D1 vs. D4; P < 0.001) P = NS and NR for others) Patients who progressed to erosive from nonerosive disease at baseline, % D1: 29 (9/31) D2: 53 (18/34) D3: 38 (14/37) D4: 15 (5/34) D1 vs D2, P = 0.050 D2 vs D4, P = 0.028 D3 vs D4, P =NS, NR | Overall: D1: 43 D2: 47 D3: 37 D4: 39 SAEs: D1: 6.3 D2: 7.4 D3: 12.8 D4: 4.7 Infections: D1: 4 D2: 7 D3: 8 D4: 8 Serious Infections: D1: 2.4 (pneumonia, HSV encephalitis, and fever) D2: 0.8 (diffuse peritonitis) D3: 0.8 (oral HSV) D4: 2.3 (pneumonia, pneumonitis, and septic arthritis) Infusion or injection reaction: D4: (10/128 ) = 7.8% Cardiovascular Events: D1: 2 (hypertension, TIA, PE) D2: 2 (peripheral bypass, pacemaker implantation) D3: 6 (3 MIs, heart failure D4: 2 (TIA, PE, peripheral vascular disease) Malignancies: D2: N:1 bladder D3: N:2 breast, lymphoma Adherence 24 (5%) non-adherent | Overall Attrition Rate, %: 3.3% (17/508) ITT Analysis: Yes Quality Rating: Good
Author, yr: Haagsma, 1997 Country, Setting: Netherlands, 1 academic and 6 peripheral clinics Funding: Pharmachemie BV; Pharmacia AB Research Objective: Compare efficacy and safety of SSZ, MTX, and combination of both in pts with early RA Study Design: RCT Overall N: 105 Study Duration: 52 wks | Inclusion Criteria: • Age: ≥ 18 • Diagnosed with RA according to ACR criteria: ACR criteria • RF positive and/or HLA-DR4 positive and/or HLA DR1 positive • Functional class of: DAS ≥ 3.0 • Duration of condition: < 12 mos • Analgesica and NSAIDS allowed Exclusion Criteria: • Prior txt with: DMARDS other than analgesics and NSAIDS • Other: contraindications to SSZ or MTX | Interventions, dose: D1: SSZ (1 g/day; max 3 g/day) D2: MTX (7.5 mg/wk; max 15 mg/wk) D3: MTX (7.5 mg/wk; max 15 mg/wk) + SSZ (1 g/day; max 3 g/day) N: D1: 34 D2: 35 D3: 36 Mean age, yrs: D1: 56.8 D2: 54.9 D3: 57.0 Sex, % female: D1: 61.8 D2: 65.7 D3: 66.7 Race, % white: NR | Mean disease duration, yrs: D1: 3.1 mos D2: 3.0 mos D3: 2.6 mos TJC, mean: D1: 20.8 D2: 20.6 D3: 24.8 SJC, mean: D1: 17.0 D2: 19.9 D3: 20.8 DMARD use, %: Overall: 0 Corticosteroid use, % Overall: 0 MTX naive, %: NR Txt resistant, %: NR Pts with Early RA (≤3 yrs): Overall: 100 Baseline DAS, mean: D1: 4.6 D2: 4.7 D3: 5.0 HAQ: D1: 0.97 D2: 0.92 D3: 1.20 | No significant differences in efficacy between combination (MTX, SSZ) and single therapy (MTX or SSZ), only a trend favoring combination therapy, MTX and SSZ were comparable At 52 weeks DAS mean change: D1: −1.6 (95% CI, −2.0 to − 1.2) D2: −1.7 (95% CI, −2.0 to − 1.4) D3: −1.9 (95% CI, −2.2 to − 2.3) Ritchie mean change: D1: −8.6 (95% CI, −10.7 to − 6.5) D2: −8.2 (95% CI, −10.1 to − 6.4) D3: −9.4 (95% CI, −11.1 to − 7.7) Swollen joints mean change: D1: SSZ −7.9 (95% CI, −10.1 to −5.7) D2: −10.2 (95% CI, −12.5 to − 8.0) D3: −11.3 (95% CI, −13.5 to − 9.2) HAQ change from baseline: D1: −0.32 (95% CI, −0.53 to − 0.10) D2: −0.46 (95% CI, −0.68 to −0.25) D3: −0.51 (95% CI, −0.76 to − 0.26) Number of pts with a response according to ACR criteria at end of study: D1: 25 D2: 25 D3: 28 Number of pts with good response according to EULAR definition: D1: 14 D2: 15 D3: 14 | Overall: D1: 88.2 D2: 77.1 D3: 88.9 SAEs: D1: 8.8 D2: 0 D3: 0 Abdominal Pain: D1: 26.5 D2: 20 D3: 36 Cardiovascular Events (Dyspnea): D1: 5.9 D2: 0 D3: 5.6 Dizziness: D1: 17.6 D2: 8.6 D3: 27.8 Headache: D1: 17.6 D2: 11.4 D3: 11.1 Nausea: D1: 29.4 D2: 25.7 D3: 63.9 URTI D1: 17.6 D2: 20.0 D3: 27.8 | Overall Attrition Rate, %: 19 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Hyrich et al., 2006 Country, Setting: Great Britain, multiclinic Funding: Schering Plough, Wyeth, Abbott, A mgen British Society for Rheumatology Biologics Register Research Objective: Compare outcome at 6 mos in unselected real- world RA pts treated with ETA or INF alone or with MTX or another DMARD Study Design: Prospective cohort study Overall N: 2711 Study Duration: 6 mos | Inclusion Criteria: • Age > 16 yrs • Diagnosed with RA according to 1987 ACR criteria; starting either ETA or INF as first biologic drug • Other meds were allowed Exclusion Criteria: NR | Interventions, dose: D1: ETA (25 mg 2x wk) D2: ETA + DMARD D3: ETA + MTX D4: INF (3 mg/kg wks 0,2,6 then every 8wks) D5: INF + DMARD D6: INF + MTX Some doses NR N: D1: 763 D2: 245 D3: 250 D4: 128 D5: 121 D6: 1204 Mean age, yrs: D1: 58 D2: 55 D3: 54 D4: 59 D5: 58 D6: 55 Sex, % female: D1: 80 D2: 79 D3: 76 D4: 79 D5: 74 D6: 77 Race, % white: NR | Mean disease duration, yrs: D1: 16 D2: 15 D3: 13 D4: 16 D5: 14 D6: 14 TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, % D1: 54 D2: 51 D3: 44 D4: 69 D5: 59 D6: 48 MTX naive, %: NR Treatment resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 6.8 D2: 6.6 D3: 6.6 D4: 6.8 D5: 6.8 D6: 6.7 | At 6 months EULAR response: D3 vs. D1: (OR 1.98, 95% CI, 1.45–2.71) D2 vs. D1 (OR 1.20, 95% CI, 0.89–1.61) D3 vs D2 (OR 1.66, 95% CI, 1.14–2.42) A better EULAR response in both MTX (OR 1.35 [95% CI, 0.92–2.00]) and DMARD (OR 1.26 [95% CI, 0.75–2.13]) subgroups as compared with INF monotherapy DAS28: D1: 4.8 +/−.4 D2: 4.6 +/− 1.5 D3: 4.3 +/− 1.5 D4: 5.0 +/− 1.6 D5: 4.9 +/− 1.6 D6: 4.6 +/− 1.6 | Adherence: Drug survival at 6 mos: ETA 20% INF 21% ETA subgroups (22% mono, 16% MTX co-therapy, 19% DMARD co-therapy) INF subgroups (30% vs. 21% MTX co- therapy, vs. 22% DMARD co-therapy) | Overall Attrition Rate, %: 21 ITT Analysis: N/A Quality; Rating: Good
Author, yr: Kirwan et al., 2004 Country, Setting: Belgium, Sweden, and United Kingdom, multicenter (16) Funding: Astra-Zeneca Research Objective: To compare BUD, a locally acting glucocorticoid with minimal systemic exposure, with conventional glucocorticoid txt and placebo in RA Study Design: RCT Overall N: 143 Study Duration: 12 wks | Inclusion Criteria: • Age 18 to 80 yrs • Diagnosed according to ACR criteria • Functional class I–III • Stable doses of NSAIDs (30 ds) and/or DMARDs (90 ds) Exclusion Criteria: • Pregnant or lactating • Glucocorticoids by any route for at least 30 ds • Systemic lupus erythematosus • Polymyalgia rheumatica • Psoriatic arthropathy • Spondylo-arthropathy • Smyloidosis • Active peptic ulcer disease • Uncontrolled DM • Other significant disease • Local or systemic infection • Allergy to BUD or other glucocorticoids; txt w/live viruses • (i.e., polio) or live bacteria (i.e., tubercle bacilli) during previous 90 days • Undergone resection of stomach or more than 100 cm of small bowel | Interventions, dose: D1: BUD (3 mg/d) D2: BUD (9 mg/d) D3: PNL (7.5 mg/d) D4: Placebo N: D1: 37 D2: 36 D3: 39 D4: 31 Mean age, yrs: D1: 54.2 D2: 57.8 D3: 53.4 D4: 54.7 Sex, % female: D1: 70 D2: 77 D3: 62 D4: 77 Race, % white: NR | Mean disease duration, yrs: D1: 13.1 D2: 8.5 D3: 7.0 D4: 7.2 TJC, mean: D1: 14.2 D2: 11.8 D3: 12.3 D4: 12.6 SJC, mean: D1: 12.9 D2: 9.8 D3: 11.6 D4: 11.8 DMARD use, %: D1: 76 D2: 69 D3: 67 D4: 65 Corticosteroid use, % NR MTX naive, %: NR Txt resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR HAQ: D1: 1.61 D2: 1.57 D3: 1.51 D4: 1.52 | Functional capacity and health related quality of life are secondary outcomes for this study ACR20, %: D1: 22 D2: 42 D3: 56 D4: 25 D2 vs D3, P = 0.11 TJC: D1: 2.23 (−0.63 to 5.1) D2: 3.65 (0.75 to 6.54) (P <0.05) D3: 4.83 (2.01 to 7.65) (P <0.001) SJC: D1: 1.53 (0.92 to 3.98) D2: 3.81 (1.3 to 6.52) (P < 0.01) D3: 3.67 (1.25 to 6.09) (P <0.01) Pain: D1: 6.6 (−5.8 to 18.9) D2: 11.4 (−1.3 to 24) D3: 22.3 (10 to 34.6) (P <0.001) DAS, patient: D1: 7.9 (−4.7 to 20.5) D2: 16.4 (3.6 to 29.3) (P < 0.05) D3: 24.5 (12.1 to 37) (P <0.001) DAS, physician: D1: 0.25 (−0.12 to 0.62) D2: 0.45* (0.07 to 0.82) (P < 0.05) D3: 0.66 (0.3 to 1.03) (P < 0.001) HAQ: D1: 0.009 (−0.19 to 0.21) D2: 0.107 (−0.31 to 0.09) D3: 0.383 (0.188 to 0.578) (P < 0.001) Diffrence: D3 vs. D1: 0.393; P < 0.001 D3 vs. D2: 0.276; P < 0.01 SF-36: D1: 2 (−2 to 6) D2: 3.7 (−0.4 to 7.8) D3: 7.4 (3.5 to 11.4) (P < 0.001) SF-36 Mental Subscale D1: 4.8 (−0.8 to 10.4) D2: 6.0 (0.4 to 11.7) ( D3 vs D1; P < 0.05) D3: 7.2 (1.7 to 12.8) (D3 vs D2; P < 0.001) | Overall: D1: 89D2: 94 D3: 85 D4: 90 SAEs: D1: 5 D2: 0 D3: 5 D4: 6 Abdominal Pain: D1: 11 D2: 8 D3: 10 D4: 6 Headache: D1: 11 D2: 14 D3: 15 D4: 3 URTI: D1: 19 D2: 11 D3: 15 D4: 3 | Overall Attrition Rate, %: 16 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Klareskog, 2004; van der Heijde, 2006 TEMPO study Country, Setting: Multinational (Europe), multicenter Funding: Wyeth Research Research Objective: To compare safety and efficacy of combination of ETA and MTX with monotherapies in pts with RA who had failed previous DMARD txt Study Design: RCT Overall N: 686 (2 yr results: 503) Study Duration: 52 wks (2 yrs, 100 wks) | Inclusion Criteria: • Age ≥ 18 • Diagnosed according to ACR criteria • Functional class I–III • Less than satisfactory response to at least 1 DMARD other than MTX • Duration 6 mos to 20 yrs • RA defined as > 10 swollen and > 12 painful joints and at least one of: ESR > 28 mm/h, CRP > 20 mg/L, or morning stiffness for > 45 minutes • Folic acid 5 mg twice per wk • NSAIDs Exclusion Criteria: • TNF antagonist, any immuno-suppressive drugs w/in 6 mos • Any investigational drug or biologic agent w/in 3 mos DMARD or css injection w/in 4 mos • Previous txt with MTX if pt experienced clinically toxic side effects or had no response | Interventions, dose: D1: MTX (20 mg/wk) D2: ETA (25 mg 2x wkly) D3: ETA (25 mg 2x wkly) + MTX (7.5 titrated to 20 mg/wk) N: D1: 228 (152) D2: 223 (163) D3: 231 (188) Overall (at 2yrs): 503 Mean age, yrs: D1: 53 D2: 53.2 D3: 52.5 Overall (at 2yrs): 52.1 Sex, % female: D1: 79 D2: 77 D3: 74 Overall (at 2yrs): 76 Race, % white: D1: 98 D2: 99 D3: 98 Overall (at 2yrs): 99 | Mean disease duration, yrs: D1: 6.8 D2: 6.3 D3: 6.8 TJC, mean: D1: 33.1 D2: 35 D3: 34.2 SJC, mean: D1: 22.6 D2: 23 D3: 22.1 DMARD use, %: NR Corticosteroid use, % D1: 64 D2: 57 D3: 62 MTX naive, %: D1: 58 D2: 58 D3: 56 Txt resistant, %: Overall: 100 Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 5.5 D2: 5.7 D3: 5.5 Sharp: D1: 26.8 D2: 21.8 D3: 21.8 JSN: D1: 13.3 D2: 11.5 D3: 10.3 | At 24 weeks AUC of ACR-N, %-yrs: D1: 12.2 D2: 14.7 D3: 18.3 (P < 0.0001) ACR20, %: D1: 75 D2: 76 D3: 85 (P = 0.0151) ACR50, %: D1: 43 D2: 48 D3: 69 (P < 0.0001) ACR70, %: D1: 19 D2: 24 D3: 43 (P < 0.0001) At 52 weeks DAS < 1.6 remission, %: D1: 13 D2: 16 D3: 35 (D3 vs. D2: P < 0.0001; D2 vs. D1: P = 0.5031) HAQ, decline: D1: 0.65 D2: 0.7 D3: 1.0 (P < 0.05) D3 therapy significantly more likely to attain HAQ DI similar to population norms (< 0.5) than monotherapy Radiograhic outcomes Total Sharp Score change: D1: 0.28 D2: 0.52 D3: −0.54; D3 vs D2; P = 0.0006 D2 vs D1; P =0.047 Erosion score change: D1: 1.68 D2: 0.21 D3: −0.30; D3 vs D2; P = 0.0001 D2 vs D1; P =0.008 JSN score change: D2: 0.32 D3: −0.23; P = 0.0007 At 2 years Total Sharp score change: D1: 1.12 D2: 1.10 D3: −0.56; P = 0.05 D3 vs D2; P = 0.05 D2 vs D1; P = NR Erosion score change D2: 0.36 D3: −0.76 P < 0.05 JSN score change D2: 0.74 D3: 0.20; P = NS, NR | Overall: D1: 81 (87) D2: 86 (92) D3: 81 (86) Infections: D1: 64 (75) D2: 59 (71) D3: 67 (76) Serious Infections: D1: 4 (7) D2: 4 (6) D3: 4 (6) Infusion or injection reaction: D1: 2 (2) D2: 21 (21) D3: 10 (11) Abdominal Pain: D1: 18 D2: 12 D3: 18 Hypertension: D1: 5 D2: 13 D3: 9 Headache: D1: 14 D2: 15 D3: 15 Nausea: D1: 32 (39) D2: 10 (13) D3: 24 (29) | Overall Attrition Rate, %: 52 wks: 23.5 2 Yrs: 38.4 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Kristensen et al., 2006 Country, Setting: Sweden, multicenter Funding: Osterlund and Kock Foundations, 80-yr Fund of King Gustav V, and Reumatikerfor-bundet Research Objective: LUNDEX index to compare long-term efficacy and tolerability of biologic therapies in RA pts treated in clinical practice Study Design: Prospective cohort study Overall N: 949 Study Duration: Varied (results reported for 3 yrs) | Inclusion Criteria: • Unsuccessful txt with 2 DMARDS including MTX • Pts diagnosed with RA according to clinical judgment of treating physician • Treated at 8 centers in Southern Sweden during March 1999 through January 2004 • Meds allowed, NR Exclusion Criteria: • Prior txt with biologic therapy | Interventions, dose: D1: ETA (25 mg s.c. twice wkly) D2: INF (≥3 mg/kg at 0, 2, 6, and 12 wks and then every 8 wks) N: D1: 309 D2: 640 Mean age, yrs: D1: 55.1 D2: 56.2 Sex, % female: D1: 82 D2: 75 Race, % white: NR | Mean disease duration, yrs: D1: 14.7 D2: 12.7 TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, % NR MTX naive, %: NR Txt resistant, %: Overall: 100 Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 5.9 D2: 5.6 MTX use, %: D1: 31 D2: 73 HAQ: D1: 1.6 D2: 1.4 | At 3 months D1: 63 D2: 45 (P < 0.001) At 6 months D1: 61 D2: 47 (P = NS) At 12 months LUNDEX values (index of drug efficacy in clinical practice): D1: ~ 55% (~4 0% at 3 yrs) D2: ~ 45% (~ 30% at 3 yrs) ACR20, %: D1: 69 D2: 53 (P = 0.001) At 24 months ACR20, %: D1: 65 D2: 56 (P = NS) At 36 months ACR20, %: D1: 63 D2: 61 (P = NS) ACR50, %: D1: 39 D2: 39 (P = NS) ACR 70, %: D1: 16 D2: 18 (P = NS) EULAR (moderate), %: D1: 46 D2: 29 (P = NS) EULAR (good), %: D1: 36 D2: 45 (P = NS) Intermediate Outcome Measures: INF had significantly lower adherence compared to ETA (P < 0.001) | NR | Overall Attrition Rate, %: NR ITT Analysis: N/A Quality Rating: Fair
Author, yr: Listing et al., 2006 Country, Setting: Germany Registry Data Funding: Pharmas: Essex, Wyeth, A mgen, Abbott Research Objective: To investigate frequency of remission and improved functional status in pts with 2 or more DMARD failures who have received new txt with biologics Study Design: Prospective cohort study Overall N: 1,083 Study Duration: 1 yr | Inclusion Criteria: • Age: 18 to 75 • Diagnosed with RA according to ACR criteria • Failed at least 2 prior treatments with DMARDs Exclusion Criteria: • Only 1 DMARD failure • No failure of MTX • Rec’ new txt ≥ 1 days before study entry • DAS < 3.2 at baseline | Interventions, dose: D1: Biologics (ADA, ANA, ETA, INF) (dose NR) D2: DMARDs as a class (dose NR) N: D1: 818 D2: 265 Mean age, yrs: D1: 53.7 D2: 57.4 Sex, % female: D1: 76.6 D2: 83.8 Race, % white: NR | Mean disease duration, yrs: D1: 10 D2: 9 TJC, mean: D1: 12.9 D2: 10.5 SJC, mean: D1: 10.5 D2: 8.2 DMARD use, %: Overall: 100 Corticosteroid use, % NR MTX naive, %: NR Txt resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 6.1 D2: 5.5 # previous DMARDs: D1: 4.0 D2: 2.8 | Biologics had double chance of remission compared to conventional DMARD therapies, via multivariate regression (OR: 1.95; 95% CI, 1.20–3.19) Severely disabled pts (≤ 50% of full function) in D1 (biologics) significantly more likely to achieve physical independence (≥67% of full function) than D2 (DMARDs/controls) (OR 3.88, 95% CI, 1.7–8.8) Functional remission ( ≥83% of full function) more often achieved in D1 (biologics)than in D2 (DMARDs/controls) (OR 2.18 95% CI, 1.04–4.6) At 12 months DAS28 remission, %: D1: 24.9 D2: 12.4 (P < 0.004) ARA remission, %: D1: 16.1 D2: 8.3 (P < 0.036) Pts in remission by DAS Criteria, %: D1: 16.3 D2: 15.3 Pts in ARA Remission, %: D1: 13.2 D2: 10.2 Approximately half of pts in remission at 6 mos relapsed until 12 mos, %: D1: 55 D2: 58 Patients with moderate disease acitvitiy (DAS28, 3.2–5.1) at start of treatment, had high remission rates in biologics group: DAS 30.6 ARA 16.9% Sustained remission at 6 and 12 months achieved in <10 % of patients | NR | Overall Attrition Rate, %: 14% ITT Analysis: No Quality Rating: Fair
Author, yr: Mottonen, 1999; Korpela, 2004; Puolakka, 2004 FIN-RACo Study Country, Setting: Finland, NR Funding: Finnish Society for Rheumatology and Medical Research Foundation of Turku University Central Hospital Research Objective: Efficacy and tolerability of combo of DMARDs vs. a single DMARD Study Design: RCT Overall N: 199 randomized, 187 completed 2 yrs, 160 at 5 yrs Study Duration: 24 mos (5 yr followup) | Inclusion Criteria: • Age: 18 to 65 • Diagnosed with RA according to ACR criteria: active disease, 1987 criteria • Duration of condition: < 2 yrs Exclusion Criteria: • Previous use of DMARDs • Underwent glucocorticoid glucocorticoid therapy within the previous • 2 weeks serious comorbidity • suspected inabilty to • comply with the protocol • hypersensitivity to any study medication • history of cancer • pregnant women • women of childbearing age who were not using reliable methods of contraception | Interventions, dose: D1: Combo: MTX + HCQ + SSZ + PNL D2: Single DMARD (SSZ could be changed to MTX or 3^rd^ DMARD) ± PNL PNL: 5 to 10 mg/day MTX: 7.5 to 10 mg/wk SSZ: 2 g/day Combo: 500 mg/2xd Single: 1000 mg 2xd w/ or w/out PNL HCQ: 300 mg/d Combo: if patient reaches remission in first year, patietn could be tapered and PNL could be discontinued at 9 and 18 months N: D1: 97 D2: 98 Mean age, yrs: D1: 45 D2: 46 Sex, % female: D1: 58 D2: 66 Race, % white: NR | Mean disease duration, yrs: D1: 7.3 mos D2: 8.6 mos TJC, mean: D1: 18 D2: 20 SJC, mean: D1: 14 D2: 14 DMARD use, %: NR Corticosteroid use, % NR MTX naive, %: NR Txt resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR Larsen Score: D1: 0 D2: 2 | At 2 years Eroded joints, number: D1: 2 D2: 3 (P = 0.006) btw groups Progression of radiological joint damage lower in combination versus monotherapy Larsen Erosion Score improvement: D1: 2 D2: 10 (P = 0.002) Median increase in Larsen Score: D1: 1.5 D2: 2.0 (P < 0.001) Clinical remission, %: D1: 37.9 D2: 18.4 (P = 0.011) ACR50, %: D1: 71 D2: 58 (P = 0.058) Median work disability per pt-observation yr, days: D1: 12.4 D2: 32.2 (P = 0.008) At 5 years Eroded joints, number: D1: 3 D2: 6 Larsen Erosion Score: D1: 11 D2: 24 (P = 0.001) Median increase in Larsen Score: D1: 1.5 D2: 2.0 (P < 0.001) 5 year Remiission D1: 28 D2: 22 (P = NS) Increase in Larsen score D1: lower than (P =0.004) | Overall: D1: 70 D2: 71 SAEs: D1: 3 D2: 5 Cardiovascular Events: D1: 1 MI D2: 2 MIs Malignancies: 1 prostate cancer; 1 multiple myeloma URTI: 1 pneumonia | Overall Attrition Rate, %: 195 started txt (97/98) 178 completed 2 yrs (87/91); 160 at 5 yrs (78/82) ITT Analysis: Yes Quality Rating: Fair
Author, year: O’Dell et al., 1996 Country, Setting: US, multicenter (Rheumatology clinics) Funding: Lederle, Sanofi, Winthrop, and Pharmacia provided study drugs Research Objective: To determine whether DMARDs were effective as combination therapy for RA and whether combinations studied had better efficacy than MTX alone Study Design: RCT Overall N 102 Study Duration: 2 yrs | Inclusion Criteria: • Age 19–70 • Diagnosed w/ ACR criteria > 6 mos • Poor response to at least 1 DMARD • At least 3 of: ESR ≥ 28 mm/hr, morning stiffness ≥ 45 mins, ≥ 8 tender joints, ≥ 3 swollen joints; stable therapy w/ Css ≤ 10 mg/day; • NSAIDs allowed Exclusion Criteria: • Pregnant or lactating • Prior combo treatment with any 2: gold, HCQ, penicil-lamine, SSZ, MTX • Impaired renal or hepatic system • Stage IV disease • Allergy to study drugs • Pulmonary or CVD • Visual difficulties • Retinal disease • Macular degeneration • Active peptic ulcer disease | Interventions: D1: MTX (7.5 to 17.5 mg/week) D2: SSZ (1 g/day) + HCQ (400 mg/day) D3: MTX + SSZ+HCQ N D1: 36 D2: 35 D3: 31 Mean age, yrs: D1: 50 D2: 49 D3: 50 Sex, % female: D1: 69 D2: 74 D3: 65 Race, % white: NR | Mean disease duration, yrs: D1: 10 D2: 6 D3: 10 TJC, mean: D1: 31 D2: 32 D3: 29 SJC, mean: D1: 31 D2: 31 D3: 27 DMARD use, %: All groups: 100 Current Corticosteroid use, %) D1: 53% D2: 46% D3: 52% MTX naive, %: D1: 92 D2: 89 D3: 87 Treatment resistant, %: All 100 Pts with Early RA (≤3 yrs): All groups: 0 Baseline DAS, mean: NR Duration of morning stiffness (minutes): D1: 190 D2: 156 D3: 135 RF: D1: 89% D2: 85% D3: 84% | Outcome improved by at least 50%, as determined by whether 3 following requirements had been fulfilled (modified Paulus composite criteria): • morning stiffness of less than 30 minutes’duration, decreased by 50%; • joint tenderness decreased by 50%; • joint swelling decreased by 50%; • ESR < 30 mm per hour in women and < 20 mm per hour in men Comparison between MTX + SSZ+HCQ and each of other groups with respect to good responses was statistically significant (P = 0.003 by log-rank test) At 2 years Maintenance of at least 50% improvement at 9 mos to end of 2-year treatment period (total n=50): D1: 33%, 12/36 pts D2: 40%, 14/35 pts D3: 77%, 24/31 pts (D3 vs D2, P = 0.003 and D3 vs. D1, P < 0.001 for respective comparisons between D3 (3-drug group) and D2; D3 vs D1) | Similar withdrawal rates due to Adverse Events across groups Treatment with all 3 drugs did not produce more toxic effects than did MTX alone D1: discontinued treatment because of toxic effects: • 2 w/ pneumonia; • 1 each had stomatitis, diarrhea, nausea, and vertigo; • 1 pt had sepsis and died. D2: 3 discontinued due to pneumonia, diarrhea, and Crohn’ disease; D3: 3 in 3-drug group discontinued due to nausea, cervical cancer, and weight gain. No pt had serum aspartate aminotransferase values more than twice upper limit of normal D3: higher serum creatinine values than D2 or D1 at nine mos (P = 0.03) | Overall Attrition Rate, %: 51% ITT Analysis: Yes Quality Rating: Fair for KQ1 Good for KQ3
Author, yr: O’Dell et al., 2002 Country, Setting: US, multicenter (7) Funding: Pharmacia & Upjohn, Mylan, Sanofi-Winthrop-meds. Albert G. and Bernice F. Hansen Foundation Research Objective: Efficacy of combination therapy with MTX, HCQ, and SSZ to MTX + HCQ and to MTX + SSZ in txt of RA Study Design: RCT Overall N: 171 Study Duration: 2 yrs | Inclusion Criteria: • Age: 19–80 yrs • Diagnosed with RA according to ACR criteria • Duration of condition: > 6 mos • Active disease with at least 3 of 4 following features: ESR > 28 mm/hour, duration of morning stiffness ≥ 45 minutes, ≥ 8 tender joints, and ≥ 3 swollen joints Exclusion Criteria: • Previous combination therapy with any medications studied • Significant liver or renal disease • Stage IV disease • Allergy to any study drugs • women of childbearing age not using adequate contraception • Significant hematologic, pulmonary, or CVD | Interventions, dose: D1: MTX and HCQ D2: MTX and SSZ D3: MTX, HCQ, and SSZ: All pts MTX: accelerated from 7.5 mg/wk to 17.5 mg/wk in all pts not in remission SSZ: escalated from 500 mg twice daily to 1gram twice daily in pts not in remission HCQ: 200 mg twice daily N: D1: 58 D2: 55 D3: 58 Overall: 171 Mean age, yrs: D1: 50.9 D2: 52.5 D3: 48.9 Overall: 50.9 Sex, % female: D1: 78 D2: 84 D3: 76 Overall: 79 Race, % white: NR | Mean disease duration, yrs: D1: 7.9 +/− 10 D2: 5.8 +/− 5.9 D3: 6.9 +/− 8.4 TJC (mean +/− SD): D1: 15.7 +/− 8.2 D2: 15.6 +/− 7.4 D3: 19.7 +/− 9.2 SJC, mean: D1: 21.1 +/− 8.3 D2: 19.1 +/− 7.9 D3: 24.0 +/− 8.8 DMARD use, %: NR Corticosteroid use, % D1: 71 D2: 56 D3: 50 MTX naive, %: D1: 43.1 D2: 54.5 D3: 41.4 Txt resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR % RF positive: D1: 88 D2: 88 D3: 89 ESR: D1: 28.5 +/− 20.3 D2: 34.1 +/− 26.5 D3: 30.1 +/− 21.0 | At 2 years ACR 20, %: D1: 60, 35/58 pts D2: 49 27/55 pts D3: 78, 45/58 pts (D3 vs D2; P = 0.002) (D3 vs. D1; (P = 0.05) ACR 50, %: D1: 40 D2: 29 D3: 55 (D3 vs D2; P = 0.005) (D3 vs. D1, P = 0.10) ACR 70, %: D1: 26 D2: 18 D3: 16 (P = NS) Changes in values for ACR core set, improvement in triple therapy group was greater than either of other 2 txt groups. TJC differences were statistically significant, D3 vs D1 (P ≤ 0.005) Reduced morning stiffness, minutes: D1: −59.2 +/− 103.3 D2: −53.2 +/− 89.5 D3: −109.3 +/− 86.4 minutes (D3 vs. D1; P = 0.01) (D3 vs. D2; P = 0.006) | Overall: D1: 8.6 D2: 9.1 D3: 6.9 Infections: D2: 1.8 Serious Infections: D1: 1.7 Cardiovascular Events: D1: 1.7 (1 MI) Headache: D2: 1.8 Hepatotoxicity: D3: 1.7 Malignancies: D3: 1.7 (1 non-Hodgkins lymphoma) | Overall Attrition Rate, %: 14.6% (25/171 subjects) ITT Analysis: Yes Quality Rating: Good
Author, yr: St. Clair, 2004; Smolen, 2006 ASPIRE Trial Country, Setting: Multinational, unversity hospitals Funding: Centocor Research Objective: To compare benefits of initiating txt with MTX and anti-TNFá with those of MTX txt alone in pts with RA of < 3 yrs duration Study Design: RCT Overall N: 1049 Study Duration: 54 wks | Inclusion Criteria: • Age: 18 to 75 • Diagnosed according to 1987 ACR criteria • Persistent synovitis for > 3 mos and < 3 yrs • > 10 swollen joints, and > 12 tender joints • 1 or more of following: a positive test result for serum RF, radiographic erosions of hands or feet, or a serum C-reactive protein level of > 2.0 mg/dl Oral corticosteroids; NSAIDS • 20 mg MTX (required) Exclusion Criteria: • Prior txt with: MTX, received other DMARDs within 4 wks of entry • Used ETA, INF, ADA or other anti-TNF-á agent • History of TB; HIV, hepatitis B or C virus, CHF, or lymphoma or other malignancy within past 5 yrs (excluding excised skin cancers) | Interventions, dose: D1: MTX (20 mg/wk) + placebo D2: MTX + INF (3 mg/kg/wk) D3: MTX + INF (6 mg/kg/wk) N: D1: 282 D2: 359 D3: 363 Mean age, yrs: D1: 50 D2: 51 D3: 50 Sex, % female: D1: 75 D2: 71 D3: 68 Race, % white: NR | Mean disease duration, yrs: D1: 0.9 D2: 0.8 D3: 0.9 TJC, mean: D1: 34 D2: 32 D3: 33 SJC, mean: D1: 22 D2: 21 D3: 22 DMARD use, %: D1: 35 D2: 29 D3: 32 Corticosteroid use, % NR MTX naive, %: Overall: 100 Txt resistant, %: NR Pts with Early RA (≤3 yrs): Overall: 100 Baseline DAS, mean: NR JSN: D1: 3.0 D2: 2.9 D3: 2.9 HAQ: D1: 1.5 D2: 1.5 D3: 1.5 | At weeks 30 to 54 HAQ: D1: 0.68 D2: 0.80 D3: 0.88; (D2 vs. D1; P = 0.03) (D3 vs. D1; P < 0.001) At 54 weeks HAQ > 0.22, %: D1: 65.2 D2: 76.0 D3: 75.5 (D2 vs. D1; P = 0.003) (D3 vs. D1; P < 0.004) ACR20, %: D1: 53.6 D2: 62.4 D3: 66.2 (D2 vs. D1; P = 0.028) (D3 vs. D1; P < 0.001) ACR50, %: D1: 32.1 D2: 45.6 D3: 50.4 (D2 vs. D1; P = 0.001) (D3 vs. D1; P < 0.001) ACR70, %: D1: 21.2 D2: 32.5 D3: 37.2 (D2 vs. D1; P = 0.002) (D3 vs. D1; P < 0.001) ACR-N, %: D1: 26.4 D2: 38.9 D3: 46.7 (P < 0.001) Modified Sharp: D1: 3.7 D2: 0.4 D3: 0.5 (P < 0.001) Increase in radiographic score, %: INF: 39 vs. MTX 61 (P < 0.001) Employability: INF+MTX (OR 2.4, P < 0.001) MTX (P = 0.56) Combo has higher probability of improvement than MTX alone Net increase in employability: MTX+INF: 8% MTX-only: 2% Employability status changed from employable to unemployable, %: INF: 8 MTX-only: 14 (P = 0.05) SF-36 Physical component summary scores D1: 11.7 D2: 13.2 D3: 10.1 D3 vs. D1, P =0.10 D3 vs. D2; P =0.003 Modified Sharp/van der Heijde Score change: D1: 3.7 D2: 0.4 D3: 0.5 P < 0.001 Erosion Score change: D1: 3.0 D2: 0.3 D3: 0.1 P < 0.001 JSN Score change: D1: 0.6 D2: 0.1 D3: 0.2 P < 0.001 | SAEs: D1: 11 D2: 14 D3: 14 Serious Infections: D1: 2.1 D2: 5.6 D3: 5.0 Infusion or injection reaction: D1: 7 D2: 21 D3: 15 TB: D1: 0 D2: 0.8 D3: 0.3 Nausea: D1: 18 D2: 20 D3: 17 URTI: D1: 21 D2: 25 D3: 28 | Overall Attrition Rate, %: 14.9 ITT Analysis: Yes Quality Rating: Fair
Author, year: Smolen et al., 1999; Larsen 2001; Scott 2001 Country, Setting: Multinational, multicenter Funding: Hoechst Marion Roussel Research Objective: Efficacy and safety of novel DMARD leflunomide was compared to placebo and sulfasalazine Study Design: RCT Overall N: 266 (358 including placebo arm) Study Duration: 24 wks (12 and 24 month followup) | Inclusion Criteria: • Age: ≥ 18 • Active RA defined by: ≥ 6 tender and swollen joints, based on a 28-joint count, physician and pt global assessments of RA activity of “air, poor, or very poor” CRP > 2.0 mg/dL or ESR > 28 mm/h • Functional class I – III • Other DMARDs discontinued ≥ 4 wks • Stable doses of NSAIDS permitted-acetylsalicylic acid, oral steroids (prednisolone ≤ 10 mg/day), and up to 3 intra-articular steroid injections, not exceeding 60 mg triamcinolone • Intra-articular steroid injections not permitted during first 6 mos Exclusion Criteria: • Pregnant or lactating | Interventions: D1: LEF D2: SSZ N: D1: 133 D2: 133 Mean age, yrs: D1: 58.3 D2: 58.9 Sex, % female: D1: 75.9 D2: 69.2 Race, % white: NR | Mean disease duration, yrs: D1: 7.6 D2: 7.4 TJC, mean: NR SJC, mean: NR DMARD use, %: D1: 60.2 D2: 48.9 Corticosteroid use, %: D1: 28.6 D2: 27.8 MTX naive, %: NR Treatment resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR RF positive: D1: 79% D2: 80% | At 24 weeks ACR 20, %: D1: 55 D2: 56 ACR 50, %: D1: 33 D2: 30 Improving HAQ scores, change (%): D1: −0.50 (45) D2: −0.29 (29) (P = 0.0086) Change in Sharp; number, change (SD): D1: 87 1.23 (2.85) D2: 84 2.32 (10.11) Larsen score change: D1: 0.01 D2: 0.01 (P = NS) At 1 year Change in Sharp; number, change (SD): D1: 60 0.97 (6.11) D2: 53 1.38 (2.88) Larsen score change: D1: 0.02 D2: 0.02 (P = NS) At 2 years Larsen score change: D1: −0.07 D2: −0.02 (P = NS) Similar ACR20 response rates D1: 48; D2: 44; P=NR | SAEs: D1: 5 D2: 7 Headache: D1: 7 D2: 11 Nausea: D1: 10 D2: 17 URTI: D1: 14 D2: 15 Diarrhea: D1: 17 D2: 9 Alopecia: D1: 8 D2: 5 Rash: D1: 10 D2: 9 Withdrawal due to AEs: D1: 14 D2: 19 2 cases of reversible agranulocytosis in SSZ | Overall Attrition Rate, %: 33% at 24 wks ITT Analysis: Yes Quality Rating: Fair
Author, year: Strand et al., 1999; Cohen 2001; Strand, Tagwell 1999 Country, Setting: US and Canada, multicenter (47 university & private rheumatology practices) Funding: Hoescht Marion Roussel Research Objective: Efficacy and safety of LEF with placebo and MTX in active RA Study Design: RCT Overall N: 482 (active arms-364) Study Duration: 12 mos (w/ 1 year followup) | Inclusion Criteria: • Age: 18 or older • Diagnosed according to ACR criteria; DMARDs discontinued at least 30 days prior • Duration of condition at least 6 mos • 10 mg stable prednisone (or equivalent) • NSAIDs if dosages stable at least 30 days prior to enrollment Exclusion Criteria: • Pregnant or lactating • Prior treatment with: MTX • Inflammatory joint disease not caused by RA, • History of clinically significant drug or alcohol abuse, or admitted to consumption of more than 1 alcoholic drink per day | Interventions: D1: LEF (20 mg/week) D2: MTX (7.5 to 15 mg/week) N: D1: 182 D2: 182 Mean age, yrs: D1: 54.1 D2: 53.3 Sex, % female: D1: 72.5 D2: 75.3 Race, % white: NR | Mean disease duration, yrs: D1: 7.0 D2: 6.5 TJC, mean: D1: 15.5 D2: 15.8 SJC, mean: D1: 13.7 D2: 13.0 DMARD use, %: D1: 55.5 D2: 56.0 Corticosteroid use, %: D1: 53.8 D2: 52.7 MTX naive, %: Both groups 100 Treatment resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR RF positive: D1: 64.8 D2: 59.4 MHAQ: D1: 0.8 D2: 0.8 | At 12 mos ACR 20, % D1: 52 D2: 46 ACR 50, % D1: 34 D2: 23 ACR 70, % D1: 20 D2: 9 MHAQ mean change D1: −0.3 D2: −0.2 Sharp score change D1: 0.53 (n:131) D2: 0.88 (n= 138) (P = 0.05) Mean change HAQ-DI D1: −0.45 (n= 164) D2: −0,26 (n= 168) (P ≤ 0.01) Mean change SF-36 physical component D1: 7.6 (n= 157) D2: 4.6 (n=162) Work productivity mean change D1: 9.8 (n= 138) D2: 7.5 (n= 148) Discontinuation rate, %: D1: 22 D2: 10.4 (P = NR) At 2 yrs ACR 20, % D1: 79 D2: 67 (P = 0.049) ACR 50, % D1: 34 D2: 28 ACR70, % D1: 17 D2: 12 Sharp score change D1: 1.6 (n= 71) D2: 1.2 (n= 66) HAQ DI change D1: −0.6 (n= 97) D2: 0.37 (n=101) Discontinuation rate, %: D1: 27 D2: 17 | SAEs: D1: 1.1 D2: 2.7 Infections: D1: 56.6 D2: 59.9 Abdominal Pain: D1: 13.7 D2: 15.4 Nausea: D1: 20.9 D2: 19.2 Back pain: D1: 8 D2: 2 Diarrhea: D1: 36.8 D2: 21.6 Oral Ulcers: D1: 6.8 D2: 10.5 GI Events: D1: 5.5 D2: 1.7 Elevated Transaminases: D1: 7.1 D2: 4.4 Adherence: Non-adherence as the reason for reason for withdrawal D1: 1 D2: 1 At 24 months SAEs, %: D1: 18.9 D2: 18.9 | Overall Attrition Rate, %: 51% at 1 year ITT Analysis: Yes Quality Rating: Fair
Author, yr: Svensson et al 2005 Country, Setting Sweden, multicenter Funding: Swedish Rheumatism Association and others Research Objective Efficacy of low-dose PNL on joint damage and disease activity in pts with early RA being treated concomitantly with DMARDs Study Design: RCT Overall N: 250 Study Duration: 2 yrs | Inclusion Criteria: • Age 18 to 80 yrs • Diagnosed according ARA 1987 revised criteria • Duration ≤ 1 yr: pt in BARFOT study • DAS28 score >3.0 • Started by treating rheumatologist on first DMARD • Concomitant NSAIDS txt permitted • Intraarticular steroid injections allowed except 2 wks prior to any clinical evaluation Exclusion Criteria: • Pregnant or lactating • Glucocorticoids, DMARDs • Contraindication for glucocorticoid therapy • Previous fragility fractures, pts < 65 years with T score < −2.5 on bone mineral densitometry • 65 or older with Z score ≤ 1 | Interventions, dose: D1: DMARD (SSZ 2 g/day or MTX mean dose 10 mg/week, dosages NR) + PNL (7.5 mg/d) D2: DMARD only N: D1: 119 D2: 131 Mean age, yrs: D1: 51 D2: 59 Sex, % female: D1: 65 D2: 63 Race, % white: D1: NR D2: NR | Mean disease duration, yrs: D1: 6.5 mos D2: 5.8 mos TJC, mean: NR SJC, mean: NR DMARD use, %: Overall: 100 Corticosteroid use, %: NR MTX naive, %: NR Txt resistant, %: NR Pts with Early RA (≤3 yrs): Overall: 100 Baseline DAS, mean: D1: 5.28 D2: 5.42 HAQ: D1: 1.01 D2: 0.98 SOFI: D1: 8 D2: 9 | At 2 yrs: DAS < 2.6 disease remission, % achieved D1: 55.5 D2: 32.8 (P = 0.0005) DAS28, scores over time ± SD D1: 5.3 ± 1.1 at baseline to 2.7 ± 1.5 after 1 yr and 2.7 ± 1.3 after 2 yrs D2: 5.4 ± 1.0, 3.3 ± 1.5, and 3.2 ± 1.4 HAQ scores mean decrease over time: D1: 1.0 at baseline to 0.4 at 1 year and 0.5 D2: 1.0, 0.6, and 0.7 (P value NR) Improvement in mean SOFI index D1: mean decreased from 8 at baseline to 4 at 1 year and 4 after 2 years D2: 9, 6, and 7 respectively (P value NR) Total sharp score, edian IQR change i D1: 1.8 (IQR 0.5–6.0) D2: 3.5 (IQR 0.5–10.0) (P = 0.019) Newly eroded joints per pt, median D1: 0.5 (IQR 0–2) D2: 1.25 (IQR 0–3.25) (P = 0.007) Radiographic progression beyond smallest detectable difference, % D1: 25.9 D2: 39.3 (P = 0.033) Joint space narrowing score, median change D1: 1 D2: 2 (P = 0.08) | NR | Overall Attrition Rate, %: 6.6% ITT Analysis: Yes Quality Rating: Fair
Author, yr: van Riel et al., 2006 Country, Setting: Multinational, multicenter Funding: Wyeth Research Objective: Evaluate efficacy and safety of ETA monotherapy vs. ETA + MTX in RA pts with inadequate response to MTX Study Design: RCT, open-label Overall N: 315 Study Duration: 16 wks | Inclusion Criteria: • Age: ≥ 18 • Diagnosed according to ACR criteria • Functional class of: I–III • Previous use of DMARDs • Inadequal control of RA symptoms on MTX ≥ 12.5 mg/wk for ≥ 3 mos Exclusion Criteria: • DMARDS other than MTX within 12 wks of screening; prednison ≥ 10 mg/d • Corticosteroid injections within 6 wks • ‘ignificant’concurrent medical illness | Interventions, dose: D1: ETA (25 mg s.c. twice wkly) D2: ETA (25 mg s.c. twice wkly) + MTX (≥ 12.5 mg/wk) N: D1: 159 D2: 155 Mean age, yrs: D1: 53 D2: 54 Sex, % female: D1: 79.2 D2: 76.8 Race, % white: D1: 99.4 D2: 98.7 | Mean disease duration, yrs: D1: 10.0 D2: 9.8 TJC, mean: D1: 14.6 D2: 14.7 SJC, mean: D1: 11.2 D2: 11.9 DMARD use, %: NR Corticosteroid use, % D1: 49.1 D2: 55.5 MTX naive, %: Overall: 0 Txt resistant, %: Overall: 100 Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 6.2 D2: 6.3 HAQ: D1: 1.6 D2: 1 | DAS28 improvement of > 1.2 units, %: D1: 72.8 D2: 75.2 Difference −2.3 (95% CI, − 13.1-8.2; P = 0.658) EULAR response maintained, %: D1: 80.0 D2: 82.4 (P = NR) ACR 20, %: D1: 71.0 D2: 67.1 Difference 3.9 (95% CI, −6.4– 14,2; P = 0.46) ACR 50, %: D1: 41.9 D2: 40.1 Difference 1.8,(95% CI, −9.2– 12.8; P = 0.75) ACR 70, %: D1: 17.4 D2: 18.4 Difference −1.0 (95% CI, − 9.6-7.6; P = 0.82) | Overall: D1: 62.9 D2: 70.3 SAEs: D1: 5.0 D2: 4.5 Infections: D1: 24.5 D2: 32.3 Serious Infections: D1: 0.6 D2: 0.3 Infusion or injection reaction: D1: 6.3 D2: 6.5 Dizziness: D1: 0.6% D2: 0 Headache: D1: 8.8 D2: 6.5 URTI: D1: 8.2 D2: 12.9 | Overall Attrition Rate, %: 17.2 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Weaver et al., 2006 Country, Setting: US, Rheumatology practices (509) Funding: Immunex Corporation Research Objective: To evaluate effectiveness of select biologics, MTX (MTX), and other DMARDs in management of adult RA in routine clinical practice Study Design: Prospective cohort study Overall N: 5,397 Study Duration: 12 mos | Inclusion Criteria: • Age: 18 or older • Diagnosed with RA according to ACR criteria: 1987 ACR • Pts requiring a change in RA txt Exclusion Criteria: • Pregnant or lactating • Active infection, • Concurrent enrollment in a clinical trial | Interventions, dose: D1: MTX (10 to 15 mg/wk) D2: ETA (50 mg/wk) D3: ETA (50 mg/wk) +MTX D4: INF (3.8 mg/8wks) D5: INF (3.8 mg/8wks) + MTX (15 mg/wk) D6: LEF (20 mg/d) D7: LEF (20 mg/d) +MTX (15 mg/wk) D8: MTX (15 mg/wk) +HCQ (400 mg/d) D9: MTX (15 mg/wk) +HCQ (400 mg/d) +SSZ (2000 mg/d) N: D1: 941 D2: 1251 D3: 1783 D4: 120 D5: 540 D6: 204 D7: 191 D8: 325 D9: 42 Mean age, yrs: D1: 56.8 D2: 53.2 D3: 52.6 D4: 60.2 D5: 58.5 D6: 57.7 D7: 55.5 D8: 53.8 D9: 47.8 Sex (% female D1: 75 D2: 75 D3: 79 D4: 71 D5: 77 D6: 76 D7: 78 D8: 80 D9: 79 Race, % white: D1: 77 D2: 81 D3: 81 D4: 78 D5: 81 D6: 78 D7: 82 D8: 83 D9: 79 | Mean disease duration, yrs: D1: 3.5 D2: 9.2 D3: 7.7 D4: 10.6 D5: 9.5 D6: 10.1 D7: 7.4 D8: 4.6 D9: 7.2 TJC, mean: D1: 13 D2: 13.4 D3: 13.3 D4: 14.8 D5: 3.9 D6: 12.8 D7: 12.2 D8: 11.8 D9: 10.1 SJC, mean: D1: 11.3 D2: 11.1 D3: 11.5 D4: 13.9 D5: 12.0 D6: 11.8 D7: 11.4 D8: 9.2 D9: 10.2 DMARD use, %: D1: 25 D2: 75 D3: 96 D4: 85 D5: 96 D6: 75 D7: 95 D8: 78 D9: 88 Corticosteroid use, % D1: 53 D2: 48 D3: 51 D4: 63 D5: 57 D6: 48 D7: 56 D8: 50 D9: 48 MTX naive, %: NR Treatment resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR RF factor positive: D1: 72 D2: 65 D3: 69 D4: 68 D5: 69 D6: 75 D7: 73 D8: 71 D9: 71 | mACR20, %: D1: 37 D2: 41 D3: 43 D4: 26 D5: 35 Adjusting for baseline covariates D3: vs. D1(OR 1.29, 95% CI, 1.09–1.52; P < 0.01) D2 vs. D1 (OR 1.23, 95% CI, 1.02–1.47; P < 0.05) D1 vs. D5 (OR 0.96 CI 0.76– 1.21 p = 0.72) D1 vs. D4 (OR 0.66, 95% CI, 0.43–1.02; P = 0.06) Mean change HAQ improvement, % D1: 7 D2: 17 (P < 0.001) D3: 17 (P < 0.001) mACR20 response D5 vs. D1: (OR 0.68, 95% CI, 0.48–0.96; P < 0.05) D6 vs. D1 (OR 0.76, 95% CI, 0.54–1.06; P = 0.11) D8 vs, D1: (OR 0.94, 95% CI, 0.72–1.23; P = 0.64) D9 vs. D1: (OR 0.57, 95% CI, 0.27–1.18; P = 0.13) SJC % improvement D1 vs D1: 34 (N/A) D2 vs. D1: 53 (P < 0.0001) D4 vs. D1: 29 (P = NS) D3 vs. D1: 55 (P < 0.0001) D5 vs D1:48 (P < 0.01) TJC % improvement D1: 34(N/A) D2 vs. D1: 53% (P < 0.001) D4 vs D1: 29% (P = NS) D3 vs D1: 55% (P < 0.0001) D5 vs D1: 48% (P = NS) HAQ % improvement amongst pts < 65 yrs D2: 22 D4: 4 (P = NR) | NR | Overall Attrition Rate, %: 33.2 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Zink, 2005 Country, Setting: Germany, clincal Funding: Essex Pharma, Wyeth Pharma, Amgen, and Abbott Research Objective: To compare drug continuation rates in pts. with RA who start on a biological agent or on a DMARD after previous DMARD failure Study Design: Retrospective cohort study Overall N: 1,523 Study Duration: 1 yr | Inclusion Criteria: • Age: 18 to 75 • Diagnosed with RA according to ACR criteria • Previous use of DMARDs: at least 2 Exclusion Criteria: NR | Interventions (dose): D1: ETA D2: INF D3: AKA D4: Total Control Group D5: LEF D6: LEF + MTX Dosages NR N: D1: 511 D2: 343 D3: 70 D4: 599 D5: 120 D6: 141 Mean age, yrs: D1: 53.7 D2: 53.6 D3: 54.3 D4: 56.5 D5: 58 D6: 57.4 Sex, % female: D1: 77.9 D2: 71.1 D3: 77.1 D4: 82.8 D5: 85.8 D6: 78.0 Race, % white: NR | Mean disease duration (yrs): D1: 9 D2: 8.5 D3: 13 D4: 6 D5: 9 D6: 7 TJC, mean: D1: 13.3 D2: 12.6 D3: 12.6 D4: 10 D5: 10.6 D6: 10.9 SJC, mean: D1: 10.4 D2: 10.7 D3: 10.2 D4: 7.7 D5: 7.4 D6: 8.5 DMARD use (#): D1: 3.9 D2: 3.7 D3: 4.2 D4: 2.1 D5: 2.4 D6: 2.2 Corticosteroid use, %: NR MTX naive, %: NR | Continuation rates D1 and D2 similar D3 significantly lower Txt continuation at 1 yr, % D1: 68.6 ETA+ MTX: 71.6 D2: 65.4 D6: 66.2 D3: 59 AKA vs. ETA; P = 0.004; ANA vs. INF; P = 0.03 Txt discontinuation because of adverse events, %: D2: 18.7 INF+MTX: 18.2 D1: 12.6% ETA+MTX 13.3 D3: 16.3 Txt discontinuation because of lack of efficacy, %: D1: 19.9 ETA + MTX:16.9; D2: 45 INF+MTX: 17.9 D3: 29.6 Txt resistant, %: NR Pts. with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 6.1 D2: 6 D3: 6.1 D4: 5.4 D5: 5.5 D6: 5.6 MTX use: D1: 91.2 D2: 92.1 D3: 78.6 D4: 68.7 D5: 94.2 D6: 90.7 | NR | Overall Attrition Rate, %: N/A ITT Analysis: N/A: registry Quality Rating: Good

Evidence Table 2

KQ 1. Rheumatoid arthritis systematic reviews: treatment response, disease progression, and remission

Study Characteristics | Inclusion and Exclusion Criteria | Characteristics and Interventions | Baseline Disease and Treatment Characteristics | Health Outcomes | Adverse Events (%) | Analysis and Quality Rating
Author, year, country, funding: Clark, 2004, International: Europe, U.S., Canada, Australia, Health Technology Assessment Programme (U.K.) Study Design: Systematic review and meta analysis Aims of Review: To review evidence on clinical benefits, hazards, and cost-effectiveness of AKA in adult RA pts Number of Pts: 2,905 | Studies included: Efficacy Trials: • Bresnihan (1998) • Cohen (2001) • Cohen (2002) • Unpublished report by Amgen (2001; STN 103950 Clinical Review; low-dose for 3 mos) Safety Trial: • Fleischmann (2001) Characteristics of included studies: • RCTs (except 1) of AKA or AKA + MTX in pts with highly active RA • Fleischmann control arm consisted of placebo + DMARD txt Characteristics of included populations: • Mean ages 50s • Duration 6 mos to 10 yrs • Majority had failed at least 1 DMARD and some were taking MTX up to trial start • Majority taking low-dose steroids and NSAIDs Characteristics of interventions: • AKA alone: • AKA from 2.5 mg/day to 150 mg/day • AKA + MTX: AKA 0.04 mg/kg per day to 2.0 mg/kg per day or fixed dose 100 mg/day | Adjusted indirect comparisons with anti TNF agents (ETA, INF) suggested that AKA may be significantly less effective at relieving clinical symptoms than anti-TNF agents (−0.21; 95% CI, −0.32 to −0.10) Adjusted indirect comparisons: • RD (95% CI) • TNF+MTX vs. MTX 0.37 (0.28 to 0.45) • AKA+MTX vs. MTX 0.16 (0.09 to 0.23) • AKA+MTX vs. TNF+MTX −0.21 (−0.32 to −0.10) | Withdrawals due to adverse events: • Control: 4.1% to 9% • AKA: 5% to 13% Specific adverse events: • SAEs: Control: 3.2% to 11.6% AKA: 4.4% to 12.8% • Malignancy: Control: 0% to 1.8% AKA: 0% to 1.1% • Injection Site Reactions: Control: 3% (low-dose study) to 33% AKA: 19.8% (low-dose study) to 73% • Any infection: Control: 13.3% (low-dose study) to 50% AKA: 13.5% (low-dose study) to 48.4% • Serious infections: Control: 0.4% to 1.4% AKA: 0.8% to 2.1% • Neutropenia: Control: 0% to 4% AKA: 0% to 9% • Antibodies to IL-1Ra: Control: 0% to 1.8% AKA: 0.9% to 5% | Publication Bias Assessed: NR Heterogeneity Assessed: Yes Standard Method of Study Appraisals: Yes Comprehensive Search Strategy: Yes Quality Rating: Good
Author, year, country, funding: Gartlehner et al., 2006 US Study Design: Metaanalysis (random effects model); systematic review Aims of the Review: To assess comparative efficacy and safety of biologic agents for RA Number of Patients: ADA: 2,354 ETA: 1,151 INF: 704 AKA:1,039 (#’s refer to 17 sudies used for adjusted indirect comparisons of efficacy) | Studies included: • • 26 controlled trials • • 18 additional studies assessed safety Characteristics of included studies: • • Often limited to 1 year of follow-up • • Reported on DAS-28 • • Radiographic progression, functional capacity, and QOL Characteristics of included populations: • • Narrowly defined populations • • Mean age 53.4 • • 76% female • • 89% caucasion Characteristics of interventions: • • All efficacy studies except 1 were funded by the pharmaceutical industry • • All 12 weeks plus of duration (for observational studies it was 3 months or greater and 100 or more patients) | • • Adjusted indirect comparison indicate no significant differences in efficacy between antiTNF drugs • • Anti-TNF drugs appear to be more efficacious than AKA but do not differ among each other. Indirect comparisons of INF and of anti-TNF drugs as a class compared to AKA yielded a statistically significant greater efficacy on ACR 20 [RR 0.58 (95%CI 0.38–0.90) and RR 0.61 (95% CI 0.39–0.96), respectively], but not ACR 50 • • Few studies assessed longterm radiographic outcomes. In general, rate of radiographic progression was significantly lower in patients treated with biologics than in placebo-treated patients, regardless of concomitant DMARD therapy. Similarly, QoL improved significantly for patients treated with biologics | • • Because of lack of sound long-term safety data, evidence is insufficient to draw firm conclusions about comparative safety of biologics • • Higher rates of injection site reactions for AKA than ADA and ETA (56% vs. 19% vs. 25%) | Publication Bias Assessed: Yes Heterogeneity Assessed: Yes Standard Method of Study Appraisals: Yes Comprehensive Search Strategy: Yes - briefly describe in box: Searched Medline, Embase, Cochrane and International Pharmaceutical Abstracts from 1980–2006. Also explored CDER database. Quality Rating: Good
Author, year, country, funding: Hochberg et al., 2003 Multinational NR Study Design: Systematic review and indirect comparisons Aims of the Review: Differences in efficacy of TNF alpha blocking agents, as measured by rate ratios for American College of Rheumatology (ACR) 20/50/70 responses, in patients with RA with an incomplete response to methotrexate. Number of Patients: 1053 380 placebo 673 active | Studies included: Maini et al. 1999 Lipsky et al. 2000 Weinblatt et al 1999 Weinblatt et al. 2003 Characteristics of included studies: Placebo controlled, double blind, randomised clinical trials of at least 24 weeks’ Characteristics of included populations: NR- assuming that it is adults with active RA with lack of response to MTX Characteristics of interventions: the addition of TNF blocking agents (INF, ETA and ADA) to methotrexate in a “step-up” strategy | Indirect comparisons, Relative Risk (95% CI) • • Etanercept vs. adalimumab ACR 20 1.10 (0.57 to 2.12) 2.60 (0.35 to 19.0) • • Infliximab vs. adalimumab 1.07 (0.66 to 1.73) 1.35 (0.47 to 3.85) • • Etanercept vs. infliximab 1.03 (0.49 to 2.18) 1.92 (0.22 to 17.0) | NR | Publication Bias Assessed: NR Heterogeneity Assessed: Yes Standard Method of Study Appraisals: NR Comprehensive Search Strategy: Yes - briefly describe in box Quality Rating: Fair
Author, year, country, funding: Osiri et al., 2002 Multinational Cochrane Collaboration Study Design: Systematic review of RCTs and CCTs Aims of Review: To determine efficacy and toxicity of LEF compared to placebo or other DMARDs in txt of RA Meta-analysis stratified comparison between LEF and Placebo or other DMARDs by outcomes at different length of txts Number of Pts: 1,144 LEF 312 to Placebo 680 to MTX 132 to SSZ Only 920 used in meta-analysis 2 yr extension: LEF:158 SSZ: 60 MTX 101 | Studies included: 6 trials Characteristics of included studies: Randomized, double-blind, placebo and/or active controlled Characteristics of included populations: All with active RA Characteristics of interventions: 5, 10 or 25 mg/d vs placebo or MTX or SSZ | • • LEF significantly better than placebo at 6,12 and 24 mos. • • LEF vs. MTX • • ACR 20: Significantly more responders for MTX than LEF at 12 mos; OR: 1.43 (1.15–1.77) • • No significant differences at 2 yrs but more responders with MTX than with LEF; OR 1.28 (0.98–1.67) • • ACR 50, ACR 70: differences in ACR 50/70 repsonses between LEF and MTX were NS | • • Total withdrawals lower in LEF group (10% greater than Placebo [70/416 vs 18/311]); LEF not diff in efficacy and tolerability than MTX and SSZ, except that LEF was more efficaious than SSZ at 24 mos • • AEs+ GI sympotms, elevated liver funcitn tests, alopecia, and infections | Publication Bias Assessed: NR Heterogeneity Assessed: Yes Standard Method of Study Appraisals: Yes Comprehensive Search Strategy: Yes Quality Rating: Good
Author, year, country, funding: Wailoo et al., 2006 AHRQ Study Design: Decision analytic model and metaanalysis Aims of the Review: Cost effectiveness of ETA, ADA,, ANA and INF alone and in sequence Number of Patients: 17,000 in disease registry (National Databank for Rheumatic Diseases) and 6694 in RCTs | Studies included: Disease registry (National Databank for Rheumatic Diseases) and 6694 in 13 RCTs Characteristics of included studies: Treatment duration of at least 6 months Characteristics of included populations: Adult patients with RA Characteristics of interventions: Placebo and MTX controlled | • • Odds ratio of ACR50 • • INF/ETA 1.17 (0.68, 2.08) • • ADA/ETA 1.02 (0.54, 1.97) • • ADA/INF 0.87 (0.47, 1.57) | NR | Publication Bias Assessed: Yes Heterogeneity Assessed: NR Standard Method of Study Appraisals: NR Comprehensive Search Strategy: Yes Quality Rating: Fair

Evidence Table 3

KQ1. Psoriatic arthritis trials: treatment response, disease progression, and remission

Study Characteristics | Inclusion and Exclusion Criteria | Characteristics and Interventions | Baseline Disease and Treatment Characteristics | Health Outcomes | Adverse Events (%) | Analysis and Quality Rating
Author, yr: Antoni et al., 2005; Kavanaugh et al., 2006 IMPACT Study Country, Setting: Multinational, 9 clinical sites Funding: NIH; Centocor, Inc.; Schering-Plough Research Institute; Competence Network Research Objective: Efficacy and tolerability of INF for the articular and dermatologic manifestations of active PsA Study Design: RCT Overall N: 104 Study Duration: 50 wks (1–16 wks RCT 16–50 open, all treated with INF) | Inclusion Criteria: • • Age ≥ 18 • • Failure of 1 or more DMARD • • Active peripheral polyarticular arthritis • • MTX ≥ 15 mg/wk w/folic acid supplementation • • LEF, SSZ, HCQ, intramuscular gold, penicillamine, or azathioprine stable for 4 wks • • oral corticosteroids (dosage of 10 mg PRE equivalent/d or less) • • NSAIDs stable for at least 2 wks Exclusion Criteria: • • Monoclonal antibody or fusion protein • • History of TB: positive tests for RF or latent TB investigational drug within 3 mos | Interventions: D1: Placebo D2: INF (5mg/kg at wks 0,2,6,14, then every 8 wks) N: D1: 52 D2: 52 Mean age, yrs: D1: 45.2 D2: 45.7 Sex, % female: D1: 42.3 D2: 42.3 Race, % white: NR | Mean disease duration, yrs: D1: 11 D2: 11.7 TJC, mean: D1: 20.4 D2: 23.7 SJC, mean: D1: 14.7 D2: 14.6 DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 5.4 D2: 5.5 Concomitant MTX, %: 56 | • • ACR50 Placebo 0/52 (0.0%) vs. INF 24/52 (46.2%) • • ACR70 Placebo 0/52 (0.0%) vs. INF 15/52 (28.8%) • • # of tender joints Placebo −23.6 vs. INF 55.2 • • # of swollen joints Placebo −1.8 vs. INF 59.9 • • DAS Placebo 2.8 vs. INF 45.5 P < 0.001 • • HAQ Placebo −1.6 vs. INF 49.8 P < 0.001 • • PsARC Placebo −12% vs. INF +86% P < 0.001 • • ACR20 wk 16 Placebo 5/52 (9.6%) vs. INF 34/52 (65.4%) P < 0.001 • • At 50 wks • • Total modified vdH-S score, 85% and 84% in Placebo/INF and INF/INF groups had no worsening. • • Change in erosion scores INF/INF 0.921, placebo/INF 0.536 (P = 0.780) • • Change in JSN INF/INF −0.51, placebo/INF −0.47 (P = 0.211) • • 16 wks-PsARC INF 75% vs. Placebo 21% (P < 0.001) • • PASI75 INF 68% vs, placebo 0% (P < 0.001) | Overall: D1: 65 D2: 73 D3: 84 Headache: D1: 3 D2: 4 URTI: D1: 5 D2: 1 | Overall Attrition Rate (%): 5 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Antoni, 2005; Kavanaugh et al., 2006 IMPACT2 study Country, Setting: Multinational 36 sites in clinics Funding: Centocor Inc and Schering-Plough Research Objective: Efficacy, health related quality of life and physical function in pts with PsA Study Design: RCT Overall N: 200 Study Duration: 14 to 24 wks (pts with inadequate response entered early escape at wk 16) | Inclusion Criteria: • • Diagnosed with PsA • • Diagnosed at least 6 mos before first infusion of study drug • • Inadequate response to current or previous DMARDs or NSAIDs • • Pts had to have active plaque psoriasis with at least 1 qualifying target lesion at least 2 cm in diameter • • Negative test for RF in their serum • • Stable doses of MTX, oral corticosteroids, NSAIDs Exclusion Criteria: • • TNF α inhibitors; active or latent TB • • Chronic or clinically significant infection, malignancy, or CHF | Interventions: D1: Placebo D2: INF (5 mg/kg at wks 0, 2, 6, 14, 22) N: D1: 100 D2: 100 Mean age, yrs: D1: 46.5 D2: 47.1 Sex, % female: D1: 49 D2: 29 Race, % white: NR | Mean disease duration, yrs: D1: 7.5 D2: 8.4 TJC, mean: D1: 25.1 D2: 24.6 SJC, mean: D1: 14.4 D2: 13.9 DMARD use, %: NR Corticosteroid use, %: D1: 10 D2: 15 MTX naive, %: NR Txt resistant, %:Overall 100 Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR Concomitant MTX, %: D1: 45 D2: 47 PASI: D1: 10.2 D2: 11.4 | • • Placebo vs. INF (%): • • ACR 50 at wk 14 3 vs. 36 (P < 0.001) and wk 24 4 vs. 41 (P < 0.001) • • ACR70 at wk 14 1 vs. 15 (P < 0.001) and wk 24 2 vs. 27 (P < 0.001) • • PsARC at wk 14 27 vs. 77 (P < 0.001) and wk 24 32 vs. 70 (P < 0.001) • • HAQ improvement at wk 14 −18.4 vs. 48.6 (P < 0.001) and wk 24 −19.4 vs. 46 (P < 0.001) • • SF-36 (change from baseline) • • Physical wk 14 1.1 vs. 9.1 (P < 0.001) and wk 24 1.3 vs. 7.7 (P < 0.001) • • Mental wk 14-1.2 vs. 3.8 (P = 0.001) and wk 24 0.4 vs. 3.9 (P = 0.047) • • ACR20 at Wk 14 11 vs. 58 (P < 0.001) and Wk 24 16 vs. 54 (P < 0.001) • • PASI 50: wk 14: 9 vs. 82 (P <0.01), wk 24: 8 vs. 75 (P <75 (P<0.01); PASI 75 wk 14: 2 vs. 64 (P < 0.01), wk 24: 1 vs. 50 (P < 0.01); • • improvement wk 14: 0 vs. 41 (P < 0.01), wk 24: 0 vs. 39 (P < 0.01) • • median productivity at 14 wks 9.2% vs. 67.5% (P < 0.0001) • • missed workdays at 14 wks 13% vs. 3.7% (P = 0.138) | Overall: D1: 67 D2: 67 SAEs: D1: 6 D2: 9 Infusion or injection reaction: D1: 6 D2: 7 Dizziness: D1: 5 D2: 4 Headache: D1: 5 D2: 6 URTI: D1: 14 D2: 10 | Overall: Attrition Rate (%): Wk 14: NR Wk 24: 7.5 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Kaltwasser et al., 2004 and Nash et al., 2006 Country, Setting: Multinational, multicenter (31) Funding: Aventis Research Objective: Efficacy and safety of LEF versus placebo in pts with PsA and psoriasis Study Design: RCT Overall: N: 190 (ITT = 186) Study Duration: 24 wks | Inclusion Criteria: • • Age 18 to 70 • • Diagnosed with PsA • • NSAIDs or Css (prednisone dose of 10 mg/day or steroid equivalent administered orally) • • Discontinue DMARDs, biologics and systemic antipsoriatic txt 28 days Exclusion Criteria: • • Pregnant or lactating; leflunomide • • Impaired renal or hepatic system • • Nonpsoriatic inflammatory joint disease or arthritis onset < 16 yrs • • RH factor +, rheumatoid nodules, serious infections, malignancy, or CVD, HIV, hepatitis B or C antigen positivity, guttate, pustular, or erythrodermic forms of psoriasis, body weight <45 kg • • Impaired bone marrow function; history of drug or alcohol abuse | Interventions: D1: Placebo D2: LEF N: D1: 91 D2: 95 Mean age, yrs: Drug 1: 46.9 Drug 2: 48.6 Overall Sex, % female: D1: 37.4 D2: 42.1 Race, % white: D1: 95.6 D2: 97.9 | Mean disease duration, yrs: D1: 10 D2: 11 TJC, mean: NR SJC, mean: NR DMARD use, %: D1: 49.5 D2: 61.1 Corticosteroid use, %: D1: 9.9 D2: 15.8 DMARD naive, %: D1: e 50.5 D2: 38.9 Txt resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR Concomitant MTX, %: 0 | • • 56 of 95 leflunomide-treated pts (58.9%; 95% CI, 48.4–68.9) and 27 of 91 placebo-treated pts (29.7% [95% CI, 20.6–40.2]) were classified as responders by PsARC (P < 0.0001) Change in HAQ total score • • Placebo (N:90) −0.05 ± 0.46 (P = 0.0267) • • Leflunomide (N:94) −0.19 ± 0.51 Change in PASI score • • Placebo (N:90) −0.6 ± 6.1 P = 0.0030 • • Leflunomide (N:92) −2.1 ± 5.9 Change in DLQI total score • • Placebo (N:89) −0.2 ± 5.1 P = 0.0173 • • Leflunomide (N:90) −1.9 ± 5.1 | Overall: D1: 76.1 D2: 85.4 SAEs: D1: 5.4 D2: 13.5 Serious Infections: D1: 0 D2: 0 Diarrhea: D1: 13.0 D2: 24.0 Headache: D1: 7.6 D2: 11.5 Nausea: D1: 8.7 D2: 9.4 | Overall Attrition Rate (%): 47.9% ITT Analysis: Yes Quality Rating: Fair
Author, yr: Mease et al., 2000 Country, Setting: US, single center in Seattle Funding: Immunex Corp. Research Objective: To study the efficacy and safety of etanercept in pts with psoriatic arthritis and psoriasis Study Design: RCT Overall N: 60 Study Duration: 12 wks | Inclusion Criteria: • • Age 18 to 70 • • Diagnosed with PsA according to: > 3 swollen, tender, or painful joints • • Inadequate response to NSAIDs • • Hepatic transasminase concentrations no greater than 2x upper limit of normal • • Hemoglobin 85 g/L or higher • • Platelet count 125,000 per mL or more and serum creatinine 152-4 mmol/L or below • • MTX < 25 mg/wk and stable for 4 wks • • Corticosteriods if the dose < 10 mg/d of PRE, stable for at least 2 wks and maintained at a constant dose throughout study Exclusion Criteria: • • Evidence of skin conditions other than psoriasis | Interventions: D1: Placebo D2: ETA (25mg 2x wkly) N: D1: 30 D2: 30 Mean age, yrs: D1: 43.5 D2: 46 Sex, % female: D1: 40 D2: 47 Race, % white: D1: 83 D2: 90 | Mean disease duration, yrs: D1: 9.5 D2: 9 TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: D1: 40 D2: 20 MTX naive, %: NR Txt resistant, %: Overall 100 Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR Concomitant MTX: D1: 47 D2: 47 | • • PsARC ETA 26 (87%) vs. Placebo 7 (23%) P < 0.0001 95% CI, 44–83; ACR50 ETA 15 (50%) vs. Placebo 1 (3%) P = 0.0001 95% CI, 28–66; • • ACR70 ETA 4 (13%) vs. Placebo 0 (0%) P = 0.0403 95% CI, 1–26; • • HAQ ETA 0.1 (0,1) vs. Placebo 1.3 (0.9,1.6) P < 0.001 • • ACR20 was achieved by 73% ETA treated pts compared with 13% placebo treated pts (P < 0.0001) • • Median % improvements in tender and swollen joint counts at 12 wks ETA 75% and 72% respectively vs. placebo 5% worsening and 19% improvement; disability according to HAQ significantly more improved in ETA than placebo (83% vs. 3%, P < 0.0001) • • 26% of ETA vs. 0 of placebo pts achieved 75% improvement in PASI at 12 wks (P = 0.0154); similar differences between ETA and placebo also seen at 25% and 50% improvements in PASI scores | SAEs: D1: 0 D2: 3.3 Infusion or injection reaction: D1: 20 D2: 3 Headache: D1: 13 D2: 10 URTI: D1: 57 D2: 57 | Overall Attrition Rate (%): 6.6% ITT Analysis: Yes Quality Rating: Fair
Author, yr: Mease et al., 2004; Mease et al., 2006 (2nd yr outcomes) Country, Setting: US, 17 sites Funding: Immunex Research Objective: Safety, efficacy, and effect on radiographic progression of ETA in pts with PsA Study Design: RCT Overall N: 205 Study Duration: 24 wks (with 48 wk open-label phase) | Inclusion Criteria: • • Age 18 70 • • Diagnosed with PsA ≥ 3 swollen and 3 tender joimts • • Inadequate response to NSAID • • At least one of PsA subtypes: distal interphalangeal joint involvement, polyarticular arthritis, arthritis mutilans, asymmetric peripheral arthritis, or ankylosing spondylitis-like arthritis • • Stable plaque psoriasis with a qualifying lesion • • MTX therapy (stable 2 mo ≤ 25 mg/wk) • • Css (stable 4 wks ≤ 10 mg/d of prednisone) Exclusion Criteria: • • Oral retinoids, topical vitamin A or D analog preparations, and anthralin | Interventions: D1: placebo D2: ETA (25 mg 2x wkly) N: D1: 104 D2: 101 Mean age, yrs: D1: 47.3 D2: 47.6 Sex, % female: D1: 55 D2: 43 Race, % white: D1: 91 D2: 90 | Mean disease duration, yrs: D1: 9.2 D2: 9 TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: D1: 15 D2: 19 MTX naive, %: NR Txt resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR Concomitant MTX use, %: D1: 41 D2: 42 Sharp: D1: 18.3 D2: 25.89 | • • At 12 wks, 59% of ETA pts met ACR20 criteria compared with 15% placebo pts (P < 0.0001) • • 23% of ETA pts eligible for psoriasis evaluation achieved at least 75% improvement in psoriasis area and severity index, compared with 3% of placebo pts (P = 0.001) • • 12 mos; the mean annualized rate of change over one yr of txt in modified Sharp score was −0.03 unit, compared with 1.00 unit in the placebo (P = 0.0001) • • HAQ- improvement from baseline in ETA group 54% vs. 6% of placebo group (P < 0.0001) • • 72% & 70% of ETA achieved PsARC at 12 and 24 wks, respectively, compared with 31% and 23% of placebo pts | SAEs: D1: 3.9 D2: 4 Infusion or injection reaction: D1: 9 D2: 36 Headache: D1: 5 D2: 8 URTI: D1: 23 D2: 21 UTI: D1: 6 D2: 6 | Overall Attrition Rate (%): 19.5 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Mease et al., 2005 ADEPT Study Country, Setting: Multinational, multi-clinic (50) Funding: Abbott Laboratories Research Objective: Safety and efficacy of ADA compared with placebo in txt of active psoriatic arthritis Study Design: RCT Overall N: 313 Study Duration: 24 wks | Inclusion Criteria: • • Age ≥ 18 • • Moderate to severe PsA • • Active psoriatic skin lesions or a documented history of psoriasis • • Inadequate response or intolerance to NSAIDs • • MTX ≥ 3 mos with stable dose 4 wks Exclusion Criteria: • • CYP, tacrolimus, DMARDs, or oral retinoids (4 wks) • • Topical txts for psoriasis within 2 wks, other than medicated shampoos or low-potency topical steroids • • Anti-TNF • • History of TB • • Central nervous system demyelinating disease • • Listeriosis, or severe infection within 30 ds or oral antibiotics within 14 ds | Interventions: D1: placebo D2: ADA (40mg every other wk) N: D1: 162 D2: 151 Mean age, yrs: D1: 49.2 D2: 48.6 Sex, % female: D1: 45.1 D2: 43.7 Race, % white: D1: 93.8 D2: 97.4 | Mean disease duration, yrs: D1: 9.2 D2: 9.8 TJC, mean: D1: 25.8 D2: 23.9 SJC, mean: D1: 14.3 D2: 14.3 Mean number previous DMARDS: D1: 1.5 D2: 1.5 Corticosteroid use, %: NR MTX naive, %: NR Txt resistant, %: NR Pts with Early RA (≤3yrs): NR Baseline PASI (mean): D1: 8.3 D2: 7.4 Concomitant MTX use, %: D1: 50 D2: 51 Baseline HAQ: D1: 1.0 D2: 1.0 | • • PsARC ADA 60% wk. vs. placebo 23% • • ACR50 ADA, 39% vs. placebo, 6% (P < 0.001) • • ACR70 ADA, 23% vs. placebo, 1% (P < 0.001) • • The PASI75 ADA 59% vs. placebo 1% (P < 0.001) (N:69 per group). • • HAQ DI change placebo −0.1 ± 0.4 vs. ADA −0.4 ± 0.5 (P < 0.001) • • ACR20 ADA 57% vs. placebo 15% (between-group difference 42%, 95% CI, 31–52%; P < 0.001). • • Mmean change in modified total Sharp was −0.2 for ADA versus placebo (P < 0.001) • • Erosion scores (mean change ADA 0.0 vs. placebo 0.6) and JSN scores (mean change ADA −0.2 vs. placebo 0.4) (P < 0.001 for both) • • SF-36: SF-36 PCS; change in baseline to wk 12 for placebo vs ADA; 1.4 vs 9.3 (P < 0.001) • • Change in baseline to wk 24; 1.4 vs 9.3 (P < 0.001) • • SF-36 MCS • • Change in baseline to wk 12; 1.2 vs 1.6 (P NS) • • Change in baseline to wk 12; 0.6 vs 1.8 (P NS) | Infusion or injection reaction: D1: 3.1 D2: 6.6 Headache: D1: 8.6 D2: 6.0 URTI: D1: 14.8 D2: 12.6 UTI: NR | Overall Attrition Rate (%): 7.6 ITT Analysis: Yes Quality Rating: Fair.

Evidence Table 5

KQ2. Rheumatoid arthritis trials: functional capacity and quality of life

Study Characteristics | Inclusion and Exclusion Criteria | Characteristics and Interventions | Baseline Disease and Txt Characteristics | Health Outcomes | Adverse Events, % | Analysis and Quality Rating
Author, yr: Bathon, 2000; Genovese 2002; Kosinski et al., 2002; Genovese, 2005 ERA study Country, Setting: US, clinics Funding: Immunex Research Objective: To compare ETA and MTX in pts with early RA Study Design: RCT Overall N: 632 (468 extension) Study Duration: 12 mos (1 year open label extension; 2 more years, total of 5 yrs) | Inclusion Criteria: • Age: 18+ • Diagnosed with RA according to ACR criteria • Duration of condition: < 3 yrs • Positive serum test for RF or at least 3 bone erosions evident on radiographs of hands, wrists, or feet • At least 10 swollen joints and at least 12 tender or painful • joints • ESR ≥ 28 mm per hour • Serum CRP concentration of at least 2.0 mg per deciliter • Morning stiffness that lasted at least 45 minutes • Stable doses of NSAIDS and PRE allowed Exclusion Criteria: • Prior txt with MTX • No other important concurrent illnesses | Interventions, dose: D1: MTX (19 mg/wk) D2: ETA (10 mg twice wkly) D3: ETA (25 mg twice wkly) N: D1: 49 D2: 50 D3: 51 Mean age, yrs: D1: 49 D2: 50 D3: 51 Sex, % female: D1: 75 D2: 75 D3: 74 Race, % white: D1: 88 D2: 84 D3: 86 | Mean disease duration, yrs: D1: 12 mos D2: 11 mos D3: 12 mos TJC, mean: D1: 30 (16.1) D2: 31 (15.5) D3: 31 (15.8) SJC, mean: D1: 24 (11.9) D2: 24 (11.7) D3: 24 (11.9) DMARD use, %: NR Corticosteroid use, % D1: 41 D2: 42 D3: 39 MTX naive, %: D1: 100 D2: 100 D3: 100 Txt resistant, %: NR Pts with Early RA (≤3 yrs): D1: 100 D2: 100 D3: 100 Baseline DAS, mean: NR | First 12 weeks Mean changes in SF-36, HAQ, and ASHI significantly better in with ETA vs. MTX (P < 0.0001) 16 to 52 weeks No significant difference in SF-36, HAQ, and ASHI scores between groups At 6 months Significantly more pts on ETA (25 mg) than on MTX achieved ACR50 and ACR70 responses (data NR, P < 0.05) At 12 months ACR 20 response rates, %: D1: 65 D3: 72 (P = 0.16) Mean increase in Sharp score D1: 1.00 D3: 1.59 (P = 0.11) Erosion score change D1: 1.03 D3: 0.47 (P = 0.002) Despite improvement, QoL measures remained below general population (P < 0.0001); at start QoL measures were significantly below that of general population (P < 0.0001) 24 month open-label extension: ACR20,% D1: 59 D3: 72 (P = 0.005); ACR50, % D1: 49 D3: 42 ACR 70,% D1: 29 D2: 24 HAQ improvement of at least 0.5 units, %: D1: 55 D2: 37 (P < 0.001) Total modified Sharp score change D1: 1.3 D3: 3.2 (P = 0.001) Erosion score change D1: 0.7 D3: 1.9 (P = 0.001) | At year 2 SAEs: 20.6 Cardiovascular Events: 1.8 MI Malignancies: 3% overall Total events: 18 Breast: 3 Prostate: 3 Colon: 3 Lung: 12 Malignant melanoma: l2 Leukemia: 1 Kidney: 1 Hodgkins: 1 Adenocarcinoma: 1 URTI: Pnuemonia 2 Overall SAE rate of 0.093 events per pt-year comparable to rate observed in first year of efficacy study, events per pt-year MTX: 0.109 ETA: 0.091 | Overall Attrition Rate, %: 19 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Boers et al., 1997; Landewe et al., 2002 COBRA study Country, Setting: Netherlands and Belgium, multicenter Funding: Netherland Research Objective: Comparing efficacy and radiographic outcomes of combination of SSZ, MTX and PNL with SSZ alone Study Design: RCT Overall N: 155 (148) Study Duration: 56 wks; (5 yr followup) | Inclusion Criteria: • Age: 18 to 69 • Diagnosed with RA according to ACR criteria • Duration of condition < 2 yrs • NSAID txt at least 3 mos, 6 or more active inflamed joints AND presence of 2 or more (9 or more tender joints, morning stiffness 45 min or more, EST of 28 or more in first hour Exclusion Criteria: • Pregnant or lactating: adequate contraception • Prior txt with: DMARDS except HCQ or steroids • Past TB • Impaired renal or hepatic system serious comorbidity surgery in past 3 • mos • Unable to comply with protocol • Allergy to study med • Alcohol or substance abuse | Interventions, dose: D1: Combined txt (SSZ, MTX, PNL) D2: SSZ Only SSZ: 2g/d MTX: 7.5 mg/wk, weaned after 40 wks PNL: 60 mg/d wk 1 40 mg/d wk 2 25 mg/d wk 3 20 mg/d wk 4 15 mg/d wk 5 10 mg/d wk 6 then 7.5 mg/d until wk 28 then weaned off N: D1: 76 D2: 79 Mean age, yrs: NR Sex, % female: D1: 66% D2: 52% Race, % white: NR | Mean disease duration, yrs: D1: 4 mos D2: 4 mos TJC, mean: NR SJC, mean: NR Antimalarial use (%): D1: 21 D2: 24 Corticosteroid use, % NR MTX naive, %: NR Txt resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR Erosions on hand or foot xrays, %: D1: 74 D2: 79 | At week 28 Mean pooled index D1: − 1.4 (95% CI, 1.2−1.6) D2: − 0.8 (95% CI, 0.6–1.0) (P < 0.0001) ACR20, %: D1: 72 D2: 49 (P = 0.006) ACR50, %: D1: 49 D2: 27 (P = 0.007) DAS median change: D1: −2.1 (SD 1.2) D2: −1.3 (SD 1.2) (P < 0.0001) HAQ mean change: D1: −1.1 (SD 0.8) D2: −0.6 (SD 0.6) (P < 0.0001) Sharp mean change: D1: 1 D2: 4 (P < 0.001) At week 56 Mean pooled index: D1: 1.1 (SD 0.8) D2: 0.9 (SD 0.8) (P =0.20) DAS median change: D1: 1.4 (SD 1.2) D2: 1.3 (SD 1.4) (P = 0.78) HAQ mean change: D1: 0.8 (SD 0.8) D2: 0.6 (SD 0.7) (P < 0.06) Sharp mean change: D1: 2 D2: 6 (P < 0.004) At week 80 Sharp mean change: D1: 4 D2: 12 (P < 0.01) Five yr follow up Sharp score mean change: D1: 5.6 (95% CI, 4.3, 7.1) (P = 0.001) D2: 8.6 (95%CI, 6.2–11) (P = 0.001) Time averaged DAS28, points/yr: D1: −0.07 D2: −0.17 | Overall: D1: 72.3 D2: 62.0 SAEs: D1: 2.6 D2: 7.6 Infections: D1: 15.8 D2: 7.6 Cardiovascular Events: D1: 7.9 D2: 5.1 Hepatotoxicity: D1: 2.6 D2: 0 | Overall Attrition Rate, %: 3.2 ITT Analysis: Yes Quality Rating: Good
Author, yr: Breedveld et al., 2006 PREMIER study Country, Setting: Multinational (Europe, North America, Australia), multicenter (133) Funding: Abbott Laboratories Research Objective: To compare efficacy and safety of ADA + MTX vs. MTX or ADA in pts with early, aggressive RA (RA) who had not previously received MTX txt Study Design: RCT Overall N: 799 Study Duration: 2 yrs | Inclusion Criteria: • Age: 18+ • Diagnosed with RA according to ACR criteria • Duration of condition: 3 yrs or less • MTX naive pts • > 8 swollen joints, > 10 tender joints, and an erythrocyte sedimentation rate of > 28 • Folic acid only other med allowed Exclusion Criteria: • Prior txt with: MTX, cyclophosphamide, cyclosporine, azathioprine | Interventions, dose: D1: MTX (20 mg/wk) D2: ADA (40 mg/biwkly) D3: ADA (40 mg/biwkly) + MTX (20 mg/wk) N: D1: 257 D2: 274 D3: 268 Mean age, yrs: D1: 52 D2: 52.1 D3: 51.9 Sex, % female: D1: 73.9 D2: 77.4 D3: 72 Race, % white: NR | Mean disease duration, yrs: D1: .8 D2: .7 D3: .7 TJC, mean: D1: 32.3 D2: 31.8 D3: 30.7 SJC, mean: D1: 22.1 D2: 21.8 D3: 21.1 DMARD use, %: NR Corticosteroid use, % D1: 35.4 D2: 36.5 D3: 35.8 MTX naive, %: NR Txt resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 6.3 D2: 6.4 D3: 6.3 HAQ: D1: 1.5 D2: 1.6 D3: 1.5 Erosion score: D1: 13.6 D2: 11.3 D3: 11.0 | At 6 months Radiographic progression; change in Sharp scores: D1: 3.5 D2: 2.1 (P < 0.001) At 1 yr Radiographic progression; change in Sharp scores: D1: 5.7 D2: 3.0 (P < 0.001) HAQ DI improvement, mean units +/− sd: D1: −0.8 +/− 0.7 D2: −0.8 +/− 0.6 D3: −1.1 +/− 0.6 D2 vs. D1, P = NR D3 vs. D1: P < 0.001 D3 vs. D2: P = 0.002) At 2 yrs ACR50 response, %: D1: 43 D2: 37 D3: 59 D3 vs. D2 or D1: P < 0.001 D1 vs. D2: P= NS Clinical remission, %: D1: 25 D2: 25 D3: 49 (both P < 0.001) Radiographic progression; change in Sharp scores: D1: 10.4 D2: 5.5 (P < 0.001) Withdrawal because of lack of efficacy, %: D1: 18 D2: 19 D3: 4.9 HAQ DI improvement, mean units +/− sd: D1: −0.9 +/− 0.6 D2: 0.9 +/− 0.7 D3: −1.0 +/− 0.7 D2 vs. D1, P = NR D3 vs. D1; P < 0.05 D3 vs. D2; P = 0.058 % with HAQ DI score of zero: D1: 19 D2: 19 D3: 33 D3 vs. D2, P < 0.001 D3 vs. D1: P < 0.001 % with HAQ DI improvement of ≥ 0.22 units from baseline: D1: 63 D2: 58 D3: 72 D3 vs. D2, P < 0.05 D3 vs. D1: P < 0.05 | SAEs: D1: 18.5 D2: 21.1 D3: 15.9 Infections: D1: 123 D2: 110 D3: 119 Serious Infections: D1: 2.9 D2: 0.7 D3: 1.6 Malignancies: D1: 0.4 D2: 0.9 D3: 0.9 Withdrawal because of adverse events: D1: 7% D2: 10% D3: 12% | Overall Attrition Rate, %: 32% ITT Analysis: Yes Quality Rating: Fair
Author, yr: Capell, 2006 Country, Setting: Scotland, 8 NHS sites Funding: Wyeth and Pharmacia -drugs Arthritis Research Campaign Research Objective: If a combination of SSZ and MTX is superior to either alone in RA pts with supoptimal response to 6 mos of SSZ Study Design: RCT Overall N: 165 Study Duration: Phase I: 6 mos; Phase 2: 12 additional mos for those with DAS > 2.4 after 6 mos | Inclusion Criteria: • Age: 18 to 80 • Duration of condition: < 10 yrs • Active disease defined by DAS > 2.4 after 6 mos SSZ txt were eligble for phase II • NSAIDs and other medications were continued • Intra-articular or intramuscular corticosteroid was permitted but not within 1 mo of 6, 12, & 18 mo assessments Exclusion Criteria: • Pregnant or lactating • Prior txt with: MTX or SSZ • Impaired renal or hepatic system: creatinine > 150 mmol/dl, ALT, aspertate aminotransferase > 80 IU/l, alkaline phosphatase > 700 IU/l, gamma • GT ×3 • Other: abnormal white cell count (< 4 × 10*9/l) • Pre-existing pulmonary fibrosis • Use of oral • steroids > 7.5 mg/d • Known SSZ allergies | Interventions, dose: D1: SSZ + MTX D2: SSZ + placebo D3: MTX + placebo Phase I MTX: 7.5 mg/w (3 x 2.5 mg) increasing by 2.5 mg/mo until max of 25 mg or toxicity SSZ: enteric coated 500 mg/d increased by 500 mg/wkly until 40 mg/kg per d to a max of 4g/d for initial 6 mos Placebo: Folic Acid 5 mg/wk given 3 days after MTX and MTX + placebo N: D1: 56 D2: 55 D3: 54 Overall: 687 Mean age, yrs: D1: 56 D2: 55 D3: 53 Overall: 55 Sex, % female: D1: 75 D2: 75 D3: 79 Overall: 77 Race, % white: NR | Mean disease duration, yrs: D1: 1.9 D2: 1.6 D3: 1.8 TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, % NR MTX naive, %: All Txt resistant, %: All Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 3.63 D2: 3.67 D3: 3.5 Sharp: D1: 17.0 D2: 14.0 D3: 12.0 | Median change 18 mos: DAS: D1: −0.67 D2: −0.30 D3: −0.26 (D1 vs. D2; P = 0.039) (D1 vs. D3; P = 0.023) (D2 vs. D3; P = 0.79) HAQ: D1: −0.50 D2: −0.25 D3: −2.00 (D1 vs. D2; P = 0.51) (D1 vs. D3; P = 0.57) (D2 vs. D3; P = 0.99) SJC: D1: −3.00 D2: −3.00 D3: −2.00 (D1 vs. D2; P = 0.94) (D1 vs. D3; P = 0.81) (D2 vs. D3; P = 0.74) ACR20, %: D1: 29 D2: 18 (OR 1.25 (95% CI, 0.56–2.79); P = 0.68) D3: 15 (OR 2.01 (95% CI, 0.85–4.76), P = 0.14) ACR50, %: D1: 11 D2: 6 (OR 1.43 (95% CI, 0.43–4.81), P = 0.76) D3: 7 (OR 1.79 (95% CI, 0.49–6.49), P = 0.53) ACR70, %: D1: 4 D2: 2 (OR 1.50 (95% CI, 0.24–9.34), P = 1.00) D3: 2 (OR 3.00 (95% CI, 0.30–29.78), P = 0.62) | NR | Overall Attrition Rate, %: 28.5 • 687 pts entered phase I (6 mos) • At 6 mos, 165 were not eliglbe to enter phase II (discontinued SSZ because of side effects: 19%, did not attend: 3.6%, died: 0.4%) • Another 191 were not randomized because DAS score was < 2.4 ITT Analysis: Yes Quality Rating: Fair
Author, yr:Combe et al., 2006 Country, Setting: Europe, multicenter Funding: Wyeth Research Objective: To compare efficacy and safety of ETA and SSZ, alone and in combination, in pts with active RA despite SSZ txt Study Design: RCT Overall N: 260 Study Duration: 24 wks | Inclusion Criteria: • Age > 18 • Diagnosed according to ACR criteria; • Functional class of: I–III • Previous use of DMARDs: 2 to 3g SSZ/d for ≥ 4, w/o toxicity • Duration of condition < 20 yrs • Stable doses of oral corticosteroids (10 mg/d of PRE or equivalent), one • NSAID, simple analgesics with no anti-inflammatory action or daily doses of aspirin (300 mg) Exclusion Criteria: • Prior txt with: (1) ETA or other TNF antagonists or (2) received a DMARD other than SSZ within 3 mos. Or any biologic or cyclophosphamide within 6 mos, corticosteroids within 4 wks • Presence of relevant comorbidity, including active infections | Interventions, dose: D1: SSZ (2,2.5, or 3 g/d) + placebo D2: ETA (25 mg SC twice wkly) + placebo D3: ETA (25 mg SC twice wkly) + SSZ (2,2.5, or 3 g/d) N: D1: 50 D2: 103 D3: 101 Overall: 254 Mean age, yrs: D1: 53.3 D2: 51.3 D3: 50.6 Overall: 51.4 Sex, % female: D1: 82.0 D2: 78.6 D3: 80.2 Overall: 79.9 Race, % white: NR | Mean disease duration, yrs: D1: 5.6 (sd 4.4) D2: 7.1 (sd 5.2) D3: 6.5 (sd 5.1) TJC, mean: D1: 14.0 D2: 14.7 D3: 14.1 SJC, mean: D1: 11.1 D2: 10.1 D3: 10.4 DMARD use, %: D1: 58.0 D2: 69.9 D3: 58.4 Corticosteroid use, % D1: 40.0 D2: 59.2 D3: 44.6 MTX naive, %: NR Txt resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 5.0 D2: 5.1 D3: 5.2 | At 24 weeks ACR20, %: D1: 28.0 D2: 73.8 D3: 74.0 (P < 0.01) ACR50, %: D1: 14.0 D2: 46.6 D3: 52.0 (P < 0.01) ACR70, %: D1: 2.0 D2: 21.4 D3: 25.0 (P < 0.01) In groups receiving ETA, significant differences in ACR core components were observed by wk 2 compared with those receiving SSZ alone (P < 0.01) DAS improvement, %: D1: 19.6 D2: 48.2 D3: 49.7 (P < 0.01) Mean HAQ improvement, %: D1: 9.2 D2: 35.3 D3: 40.2 (P < 0.01) Mean % improvement EuroQOL VAS D2: 64.6 D3: 67.6 (P = NS, NR) No meaningful clinical advantage to use of ETA in combination with SSZ | Infections: D1: 13 D2: 47 D3: 31 Infusion or injection reaction: D1: 3 D2: 38 D3: 21 Abdominal Pain: D1: 0 D2: 7 D3: 8 Headache: D1: 4 D2: 5 D3: 15 Nausea: D1: 3 D2: 3 D3: 12 URTI: D1: 5 D2: 10 D3: 11 | Overall Attrition Rate, %: 13 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Dougados et al., 1999 and Maillefert et al., 2003 Country, Setting: Finland, France, Germany (France only for 5 yr), multicenter Funding: Pharmacia Upjohn Research Objective: Clinical benefit of MTX + SSZ compared to either drug alone early, active RA pts fulfilling some criteria of poor potential long term outcome Study Design: RCT Overall N: 209 (146) Study Duration: 52 wks (5 yrs) | Inclusion Criteria: • Diagnosed according to ACR criteria • Duration < 1 yr • Presence of active disease as defined by DAS ≥ 3 (calculation based on Ritchie articular index, 44 SJC, and ESR) and presence of RF and/or HLA DR 1/4 • Concommitant drugs allowed were analgesics and NSAIDS Exclusion Criteria: • Prior txt with steroids, DMARDS, or any drugs to treat RA other than analgesic or NSAIDS • Pts with contraindications to use of SSZ or MTX | Interventions, dose: D1: SSZ + placebo D2: MTX + placebo D3: SSZ + MTX MTX: 7.5 mg wkly (2.5 mg 3 times per wk). After wk 16, could be increased to 15 mg wkly if efficacy inadequate SSZ: increased to 2 grams daily by d #9. Could be increased to 3 grams daily after wk 16 of study if efficacy was inadequate Other?: combo MTX + SSZ N: D1: 68 D2: 69 D3: 68 Mean age, yrs: D1: 52 D2: 50 D3: 52 Sex, % female: D1: 71 D2: 74 D3: 77 Race, % white: NR | Mean disease duration, yrs: D1: 2.9 mos since diagnosis, 10.8 since onset D2: 2.3 mos from diagnosis, 18.4 from onset D3: 3.4 mos from diagnosis, 10.6 from onset TJC, mean: NR SJC, mean: D1: 10.5 D2: 9.4 D3: 9.4 DMARD use, %: All groups: 0 Corticosteroid use, % All groups: 0 MTX naive, %: All groups: 100 Txt resistant, %: NR Pts with Early RA (≥3 yrs): All groups: 100 Baseline DAS, mean: D1: 4.23 D2: 4.13 D3: 4.24 RF positive, %: D1: 75 D2: 62 D3: 71 RAI: D1: 17.6 D2: 16.5 D3: 18.9 | DAS change: D1: −1.15 D2: −0.87 D3: −1.26 (P = 0.019 from inter-group comparisons using analysis of variance) RAI changes: D1: −7.1 D2: −4.2 D3: −9.4 (P = 0.001) ACR response, %: D1: 59 D2: 59 D3: 65 (P = NR) At 5 years Txt of pts with early RA with combination therapy of MTX and SSZ during first yr did not result in any long term differences in disease activity, quality of life, or structural damage compared to monotherapy with either drug used alone Mean DAS: D1: 2.2 (sd 1) D2: 2.2 (sd 1) D3: 2.2 (sd 1)(P = 0.9) HAQ: D1: 0.6 (0.7) D2: 0.6 (0.7) D3: 0.6 (0.6) (P = 0.9) Median radiologic score D2: 7.5 D3: 8.5: (P = 0.7)D3: 2.2 (sd 1.1)(P = 0.9) HAQ: D1: 0.6 (0.7) D2: 0.6 (0.7) D3: 0.6 (0.6) (P = 0.9) Median radiologic score D2: 7.5 D3: 8.5 (P = 0.7) Similar results with 3 groups (D3 vs. D2 vs. D1) instead of 2 groups (D3 vs. D2 or D1) when compared, but data not shown Attrition rate: 21% | Overall: D1: 75 D2: 75 D3: 91 Abdominal Pain: D1: 9 D2: 6 D3: 13 Dizziness: D1: 6 D2: 1 D3: 3 Headache: D1: 9 D2: 4 D3: 12 Nausea: D1: 32 D2: 23 D3: 49 | Overall Attrition Rate, %: 27% (28.8) ITT Analysis: Yes Quality Rating: Fair
Author, yr: Emery, 2000 Country, Setting: Multinational, 117 centers Funding: NR Research Objective: To compare both short and long-term (up to 2 yr) clinical efficacy and safety of LEF and MTX for txt of RA Study Design: RCT Overall N: 999 Study Duration: 1 yr, optional second yr | Inclusion Criteria: • Age: 18+ • Diagnosed with RA according to ACR criteria: Active Disease • Previous use of • DMARDs: only if discontinued 28 ds before trial • Duration of condition: for at least 4 mos, but no longer than 10 yrs • NSAIDs and steroids were allowed provided a stable dose of NSAIDs or steroid (≤ 10 mg/d) PNL for at least 28 ds prior to study entry • Women of childbearing age were required to use adequate contraception Exclusion Criteria: • Pregnant or lactating • Prior txt with: Intra-articular corticosteriod injections w/in 6 wks of efficacy assessment | Interventions, dose: D1: LEF Yr 1 D2: MTX Yr 1 D3: LEF Yr 2 D4: MTX Yr 2 MTX: 7.5 to 15 mg/wk LEF: loading dose of 100 mg/d for 3 ds, followed by maintenance dose 20/mg/d N: D1: 501 D2: 498 D3: 292 D4: 320 Mean age, yrs: D1: 58.3 D2: 57.8 D3: 57.7 D4: 57.0 Sex, % female: D1: 70.7 D2: 71.3 D3: 71.2 D4: 71.3 Race, % white: NR | Mean disease duration, yrs: D1: 3.7 D2: 3.8 D3: 3.5 D4: 3.8 TJC, mean: NR SJC, mean: NR DMARD use, %: D1: 66.3 D2: 66.9 D3: 64.7 D4: 66.9 Corticosteroid use, % D1: 36.3 D2: 33.5 D3: 14.0 D4: 11.3 MTX naive, %: NR DMARD Txt resistant, %: D1: 1.1 D2: 1.1 D3: 1.0 D4: 1.1 Pts with Early RA (≤ 3 yrs): NR Baseline DAS, mean: NR NSAIDS, %: D1: 80 D2: 84.7 D3: 37.3 D4: 42.5 Larsen score: D1: 1.25 D2: 1.29 D3: 1.27 D4: 1.31 | At year 1 ACR20: D1: 50.5% D2: 64.8% (P < 0.001) HAQ improvement: Minimal quantitative difference between groups, but statistically significant (shown in figure only; P < 0.05) Radiograph change, Larsen Scores: D1 and D2: 0.03 increase (P =NS, NR) Primary clinical efficacy endpoints: TJC: D1: −8.3 D2: − 9.7 SJC: D1: −6.8 D2: −9.0 Physician global assessment: D1: −0.9 D2: −1.2 Pt global assessment: D1: −0.9 D2: −1.2 At year 2 ACR20, %: D1: 64.3 D2: 71.7 (P = NS, NR) HAQ improvement: difference between groups in change from baseline HAQ, NS Radiograph change, Larsen Scores: No further increase in joint damage in pts txted with LEF and small improvement in MTX pts; small net result, but statistically significant difference with MTX better than LEF (overall scores and significance NR) | SAEs: D1: 7% D2: 8% Headache: D1: 6.2 D2: 4.8 Hepatotoxicity: D1: 5.4 D2: 16.3 D3: 2.7 D4: 5.9 Nausea: D1: 11.2 D2: 15.7 URTI: D1: 5.2 D2: 5.0 D3: 4.5 D4: 5.6 Deaths MTX: 2 | Overall Attrition Rate, %: • 26.3% (263/999) during yr 1 • Combined 2 yrs, attrition 50.3% (502/999) of those initially starting study at baseline • During yr 2, attrition 18.8% (115/612) of those agreeing to continue study for 2nd yr ITT Analysis: Yes Quality Rating: Fair
Author, yr: Goekoop-Ruiterman et al., 2005 BeST Study Country, Setting: The Netherlands, 18 peripheral and 2 university hospitals Funding: Schering-Plough BV and Centocor Inc Dutch College of Health Insurances Research Objective: To compare clinical and radiographic outcomes of 4 different txt strategies in pts with early RA Study Design: RCT Overall N: 508 Study Duration: 12 mos | Inclusion Criteria: • Age > 18 yrs • RA according to ACR criteria • Duration of condition < 2 yrs • Active disease with at least 6 of 66 swollen joints • At least 6 of 68 tender joints • ESR > 28 mm/hr OR global health score greater than or equal to 20mm on 0 to 100 VAS • Concomittant NSAIDS and intraarticular steroids Exclusion Criteria: • Pregnant • Prior txt with: DMARDS other than antimalarials • Impaired renal or hepatic system • concomittant txt with an experimental drug • bone marrow hypoplasia • diabetes • alcohol or drug abuse • wish to conceive • inadequate contraception | Interventions, dose: D1: sequential monotherapy D2: step-up combination therapy D3: initial combination with PRE D4: initial combination with INF D5: NR Overall: Totals N: D1: 126 D2: 121 D3: 133 D4: 128 Overall: 508 Mean age, yrs: D1: 54 D2: 54 D3: 55 D4: 54 Overall: 54 Sex, % female: D1: 86 D2: 86 D3: 86 D4: 85 Overall: 86 Race, % white: NR | Mean disease duration, yrs: D1: 23 wks D2: 26 wks D3: 23 wks D4: 23 wks TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, % NR MTX naive, %: Overall: 100 Txt resistant, %: NR Pts with Early RA (≤3 yrs): Overall: 100 Baseline DAS, mean: D1: 4.5 +/− 0.9 D2: 4.5 +/− 0.8 D3: 4.4 +/− 0.9 D4: 4.3 +/− 0.9 D-HAQ (0 to 3 scale): D1: 1.4 +/−0.7 D2: 1.4 +/−0.6 D3: 1.4 +/−0.7 D4: 1.4 +/−0.7 | At 12 months Mean D-HAQ scores: D1: 0.7 +/− 0.7 D2: 0.7 +/− 0.6 D3: 0.5 +/− 0.5 D4: 0.5 +/− 0.5 (D1 vs. D3; P < 0.05) (D3 vs. D4; P = NS) All others NR Median total SHS increases (0 to 448 scale) from baseline: D1: 2.0 D2: 2.5 D3: 1.0 D4: 0.5 (D1 vs. D3; P = 0.003) (D1 vs. D4; P < 0.001) (D2 vs. D3; P = 0.007) (D2 vs. D4; P < 0.001) Progression of total SHS, %: D1: 67 D2: 73 D3: 87 D4: 93 (D1 vs. D3 and D4; P = 0.001) (D1 vs. D4; P < 0.001) (D2 vs. D3; P = 0.010) (D2 vs. D4; P < 0.001) Sharp van der Heijde median increase: D1: 2.0 D2: 2.5 D3: 1.0 D4: 0.5 (P < 0.001) Sustain DAS44 ≤ 2.4, %: D1: 53 D2: 64 D3: 71 D4: 74 (D1 vs. D3; P = 0.004) (D1 vs. D4; P < 0.001) (P = NS and NR for others) Patients who progressed to erosive from nonerosive disease at baseline, % D1: 29 (9/31) D2: 53 (18/34) D3: 38 (14/37) D4: 15 (5/34) D1 vs D2, P = 0.050 D2 vs D4, P = 0.028 D3 vs D4, P =NS, NR | Overall: D1: 43 D2: 47 D3: 37 D4: 39 SAEs: D1: 6.3 D2: 7.4 D3: 12.8 D4: 4.7 Infections: D1: 4 D2: 7 D3: 8 D4: 8 Serious Infections: D1: 2.4 (pneumonia, HSV encephalitis, and fever) D2: 0.8 (diffuse peritonitis) D3: 0.8 (oral HSV) D4: 2.3 (pneumonia, pneumonitis, and septic arthritis) Infusion or injection reaction: D4: (10/128) = 7.8% Cardiovascular Events: D1: 2 (hypertension, TIA, PE) D2: 2 (peripheral bypass, pacemaker implantation) D3: 6 (3 MIs, heart failure D4: 2 (TIA, PE, peripheral vascular disease) Malignancies: D2: N:1 bladder D3: N:2 breast, lymphoma Adherence 24 (5%) non-adherent | Overall Attrition Rate, %: 3.3% (17/508) ITT Analysis: Yes Quality Rating: Good
Author, yr: Haagsma, 1997 Country, Setting: Netherlands, 1 academic and 6 peripheral clinics Funding: Pharmachemie BV; Pharmacia AB Research Objective: Compare efficacy and safety of SSZ, MTX, and combination of both in pts with early RA Study Design: RCT Overall N: 105 Study Duration: 52 wks | Inclusion Criteria: • Age: ≥ 18 • Diagnosed with RA according to ACR criteria: ACR criteria • RF positive and/or HLA-DR4 positive and/or HLA DR1 positive • Functional class of: DAS ≥ 3.0 • Duration of condition: < 12 mos • Analgesica and NSAIDS allowed Exclusion Criteria: • Prior txt with: DMARDS other than analgesics and NSAIDS • Other: contraindications to SSZ or MTX | Interventions, dose: D1: SSZ (1 g/day; max 3 g/day) D2: MTX (7.5 mg/wk; max 15 mg/wk) D3: MTX (7.5 mg/wk; max 15 mg/wk) + SSZ (1 g/day; max 3 g/day) N: D1: 34 D2: 35 D3: 36 Mean age, yrs: D1: 56.8 D2: 54.9 D3: 57.0 Sex, % female: D1: 61.8 D2: 65.7 D3: 66.7 Race, % white: NR | Mean disease duration, yrs: D1: 3.1 mos D2: 3.0 mos D3: 2.6 mos TJC, mean: D1: 20.8 D2: 20.6 D3: 24.8 SJC, mean: D1: 17.0 D2: 19.9 D3: 20.8 DMARD use, %: Overall: 0 Corticosteroid use, % Overall: 0 MTX naive, %: NR Txt resistant, %: NR Pts with Early RA (≤3 yrs): Overall: 100 Baseline DAS, mean: D1: 4.6 D2: 4.7 D3: 5.0 HAQ: D1: 0.97 D2: 0.92 D3: 1.20 | No significant differences in efficacy between combination (MTX, SSZ) and single therapy (MTX or SSZ), only a trend favoring combination therapy, MTX and SSZ were comparable At 52 weeks DAS mean change: D1: −1.6 (95% CI, −2.0 to −1.2) D2: −1.7 (95% CI, −2.0 to −1.4) D3: −1.9 (95% CI, −2.2 to −2.3) Ritchie mean change: D1: −8.6 (95% CI, −10.7 to −6.5) D2: −8.2 (95% CI, −10.1 to −6.4) D3: −9.4 (95% CI, −11.1 to −7.7) Swollen joints mean change: D1: SSZ −7.9 (95% CI, −10.1 to −5.7) D2: −10.2 (95% CI, −12.5 to −8.0) D3: −11.3 (95% CI, −13.5 to −9.2) HAQ change from baseline: D1: −0.32 (95% CI, −0.53 to −0.10) D2: −0.46 (95% CI, −0.68 to −0.25) D3: −0.51 (95% CI, −0.76 to −0.26) Number of pts with a response according to ACR criteria at end of study: D1: 25 D2: 25 D3: 28 Number of pts with good response according to EULAR definition: D1: 14 D2: 15 D3: 14 | Overall: D1: 88.2 D2: 77.1 D3: 88.9 SAEs: D1: 8.8 D2: 0 D3: 0 Abdominal Pain: D1: 26.5 D2: 20 D3: 36 Cardiovascular Events (Dyspnea): D1: 5.9 D2: 0 D3: 5.6 Dizziness: D1: 17.6 D2: 8.6 D3: 27.8 Headache: D1: 17.6 D2: 11.4 D3: 11.1 Nausea: D1: 29.4 D2: 25.7 D3: 63.9 URTI D1: 17.6 D2: 20.0 D3: 27.8 | Overall Attrition Rate, %: 19 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Klareskog, 2004; van der Heijde, 2006 TEMPO study Country, Setting: Multinational (Europe), multicenter Funding: Wyeth Research Research Objective: To compare safety and efficacy of combination of ETA and MTX with monotherapies in pts with RA who had failed previous DMARD txt Study Design: RCT Overall N: 686 (2 yr results: 503) Study Duration: 52 wks (2 yrs, 100 wks) | Inclusion Criteria: • Age ≥ 18 • Diagnosed according to ACR criteria • Functional class I–III • Less than satisfactory response to at least 1 DMARD other than MTX • Duration 6 mos to 20 yrs • RA defined as > 10 swollen and > 12 painful joints and at least one of: ESR > 28 mm/h, CRP > 20 mg/L, or morning stiffness for > 45 minutes • Folic acid 5 mg twice per wk • NSAIDs Exclusion Criteria: • TNF antagonist, any immuno-suppressive drugs w/in 6 mos • Any investigational drug or biologic agent w/in 3 mos DMARD or css injection w/in 4 mos • Previous txt with MTX if pt experienced clinically toxic side effects or had no response | Interventions, dose: D1: MTX (20 mg/wk) D2: ETA (25 mg 2x wkly) D3: ETA (25 mg 2x wkly) + MTX (7.5 titrated to 20 mg/wk) N: D1: 228 (152) D2: 223 (163) D3: 231 (188) Overall (at 2yrs): 503 Mean age, yrs: D1: 53 D2: 53.2 D3: 52.5 Overall (at 2yrs): 52.1 Sex, % female: D1: 79 D2: 77 D3: 74 Overall (at 2yrs): 76 Race, % white: D1: 98 D2: 99 D3: 98 Overall (at 2yrs): 99 | Mean disease duration, yrs: D1: 6.8 D2: 6.3 D3: 6.8 TJC, mean: D1: 33.1 D2: 35 D3: 34.2 SJC, mean: D1: 22.6 D2: 23 D3: 22.1 DMARD use, %: NR Corticosteroid use, % D1: 64 D2: 57 D3: 62 MTX naive, %: D1: 58 D2: 58 D3: 56 Txt resistant, %: Overall: 100 Pts with Early RA (≥3 yrs): NR Baseline DAS, mean: D1: 5.5 D2: 5.7 D3: 5.5 Sharp: D1: 26.8 D2: 21.8 D3: 21.8 JSN: D1: 13.3 D2: 11.5 D3: 10.3 | At 24 weeks AUC of ACR-N, %-yrs: D1: 12.2 D2: 14.7 D3: 18.3 (P < 0.0001) ACR20, %: D1: 75 D2: 76 D3: 85 (P = 0.0151) ACR50, %: D1: 43 D2: 48 D3: 69 (P < 0.0001) ACR70, %: D1: 19 D2: 24 D3: 43 (P < 0.0001) At 52 weeks DAS < 1.6 remission, %: D1: 13 D2: 16 D3: 35 (D3 vs. D2: P < 0.0001; D2 vs. D1: P = 0.5031) HAQ, decline: D1: 0.65 D2: 0.7 D3: 1.0 (P < 0.05) D3 therapy significantly more likely to attain HAQ DI similar to population norms (< 0.5) than monotherapy Radiograhic outcomes Total Sharp Score change: D1: 0.28 D2: 0.52 D3: −0.54; D3 vs D2; P = 0.0006 D2 vs D1; P =0.047 Erosion score change: D1: 1.68 D2: 0.21 D3:−0.30; D3 vs D2; P = 0.0001 D2 vs D1; P =0.008 JSN score change: D2:0.32 D3:−0.23; P = 0.0007 At 2 years Total Sharp score change: D1: 1.12 D2: 1.10 D3:−0.56; P = 0.05 D3 vs D2; P = 0.05 D2 vs D1; P = NR Erosion score change D2: 0.36 D3: −0.76 P < 0.05 JSN score change D2: 0.74 D3: 0.20; P = NS, NR | Overall: D1: 81 (87) D2: 86 (92) D3: 81 (86) Infections: D1: 64 (75) D2: 59 (71) D3: 67 (76) Serious Infections: D1: 4 (7) D2: 4 (6) D3: 4 (6) Infusion or injection reaction: D1: 2 (2) D2: 21 (21) D3: 10 (11) Abdominal Pain: D1: 18 D2: 12 D3: 18 Hypertension: D1: 5 D2: 13 D3: 9 Headache: D1: 14 D2: 15 D3: 15 Nausea: D1: 32 (39) D2: 10 (13) D3: 24 (29) | Overall Attrition Rate, %: 52 wks: 23.5 2 Yrs: 38.4 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Mottonen, 1999; Korpela, 2004; Puolakka, 2004 FIN-RACo Study Country, Setting: Finland, NR Funding: Finnish Society for Rheumatology and Medical Research Foundation of Turku University Central Hospital Research Objective: Efficacy and tolerability of combo of DMARDs vs. a single DMARD Study Design: RCT Overall N: 199 randomized, 187 completed 2 yrs, 160 at 5 yrs Study Duration: 24 mos (5 yr followup) | Inclusion Criteria: • Age: 18 to 65 • Diagnosed with RA according to ACR criteria: active disease, 1987 criteria • Duration of condition: < 2 yrs Exclusion Criteria: • Previous use of DMARDs • Underwent glucocorticoid glucocorticoid therapy within the previous • 2 weeks • serious comorbidity • suspected inabilty to • comply with the protocol • hypersensitivity to any study medication • history of cancer • pregnant women • women of childbearing age who were not using reliable methods of contraception | Interventions, dose: D1: Combo: MTX + HCQ + SSZ + PNL D2: Single DMARD (SSZ could be changed to MTX or 3^rd^ DMARD) ± PNL PNL: 5 to 10 mg/day MTX: 7.5 to 10 mg/wk SSZ: 2 g/day Combo: 500 mg/2xd Single: 1000 mg 2xd w/or w/out PNL HCQ: 300 mg/d Combo: if patient reaches remission in first year, patietn could be tapered and PNL could be discontinued at 9 and 18 months N: D1: 97 D2: 98 Mean age, yrs: D1: 45 D2: 46 Sex, % female: D1: 58 D2: 66 Race, % white: NR | Mean disease duration, yrs: D1: 7.3 mos D2: 8.6 mos TJC, mean: D1: 18 D2: 20 SJC, mean: D1: 14 D2: 14 DMARD use, %: NR Corticosteroid use, % NR MTX naive, %: NR Txt resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR Larsen Score: D1: 0 D2: 2 | At 2 years Eroded joints, number: D1: 2 D2: 3 (P = 0.006) btw groups Progression of radiological joint damage lower in combination versus monotherapy Larsen Erosion Score improvement: D1: 2 D2: 10 (P = 0.002) Median increase in Larsen Score: D1: 1.5 D2: 2.0 (P < 0.001) Clinical remission, %: D1: 37.9 D2: 18.4 (P = 0.011) ACR50, %: D1: 71 D2: 58 (P = 0.058) Median work disability per pt-observation yr, days: D1: 12.4 D2: 32.2 (P = 0.008) At 5 years Eroded joints, number: D1: 3 D2: 6 Larsen Erosion Score: D1: 11 D2: 24 (P = 0.001) Median increase in Larsen Score: D1: 1.5 D2: 2.0 (P < 0.001) 5 year Remiission D1: 28 D2: 22 (P = NS) Increase in Larsen score D1: lower than (P =0.004) | Overall: D1: 70 D2: 71 SAEs: D1: 3 D2: 5 Cardiovascular Events: D1: 1 MI D2: 2 MIs Malignancies: 1 prostate cancer; 1 multiple myeloma URTI: 1 pneumonia | Overall Attrition Rate, %: 195 started txt (97/98) 178 completed 2 yrs (87/91); 160 at 5 yrs (78/82) ITT Analysis: Yes Quality Rating: Fair
Author, yr: St. Clair, 2004; Smolen, 2006 ASPIRE Trial Country, Setting: Multinational, unversity hospitals Funding: Centocor Research Objective: To compare benefits of initiating txt with MTX and anti- TNFá with those of MTX txt alone in pts with RA of < 3 yrs duration Study Design: RCT Overall N: 1049 Study Duration: 54 wks | Inclusion Criteria: • Age: 18 to 75 • Diagnosed according to 1987 ACR criteria • Persistent synovitis for > 3 mos and < 3 yrs • > 10 swollen joints, and > 12 tender joints • 1 or more of following: a positive test result for serum RF, radiographic erosions of hands or feet, or a serum C-reactive protein level of > 2.0 mg/dl Oral corticosteroids; NSAIDS • 20 mg MTX (required) Exclusion Criteria: • Prior txt with: MTX, received other DMARDs within 4 wks of entry • Used ETA, INF, ADA or other anti- TNF-á agent • History of TB; HIV, hepatitis B or C virus, CHF, or lymphoma or other malignancy within past 5 yrs (excluding excised skin cancers) | Interventions, dose: D1: MTX (20 mg/wk) + placebo D2: MTX + INF (3 mg/kg/wk) D3: MTX + INF (6 mg/kg/wk) N: D1: 282 D2: 359 D3: 363 Mean age, yrs: D1: 50 D2: 51 D3: 50 Sex, % female: D1: 75 D2: 71 D3: 68 Race, % white: NR | Mean disease duration, yrs: D1: 0.9 D2: 0.8 D3: 0.9 TJC, mean: D1: 34 D2: 32 D3: 33 SJC, mean: D1: 22 D2: 21 D3: 22 DMARD use, %: D1: 35 D2: 29 D3: 32 Corticosteroid use, % NR MTX naive, %: Overall: 100 Txt resistant, %: NR Pts with Early RA (≤3 yrs): Overall: 100 Baseline DAS, mean: NR JSN: D1: 3.0 D2: 2.9 D3: 2.9 HAQ: D1: 1.5 D2: 1.5 D3: 1.5 | At weeks 30 to 54 HAQ: D1: 0.68 D2: 0.80 D3: 0.88; (D2 vs. D1; P = 0.03) (D3 vs. D1; P < 0.001) At 54 weeks HAQ > 0.22, %: D1: 65.2 D2: 76.0 D3: 75.5 (D2 vs. D1; P = 0.003) (D3 vs. D1; P < 0.004) ACR20, %: D1: 53.6 D2: 62.4 D3: 66.2 (D2 vs. D1; P = 0.028) (D3 vs. D1; P < 0.001) ACR50, %: D1: 32.1 D2: 45.6 D3: 50.4 (D2 vs. D1; P = 0.001) (D3 vs. D1; P < 0.001) ACR70, %: D1: 21.2 D2: 32.5 D3: 37.2 (D2 vs. D1; P = 0.002) (D3 vs. D1; P < 0.001) ACR-N, %: D1: 26.4 D2: 38.9 D3: 46.7 (P < 0.001) Modified Sharp: D1: 3.7 D2: 0.4 D3: 0.5 (P < 0.001) Increase in radiographic score, %: INF: 39 vs. MTX 61 (P < 0.001) Employability: INF+MTX (OR 2.4, P < 0.001) MTX (P = 0.56) Combo has higher probability of improvement than MTX alone Net increase in employability: MTX+INF: 8% MTX-only: 2% Employability status changed from employable to unemployable, %: INF: 8 MTX-only: 14 (P = 0.05) SF-36 Physical component summary scores D1: 11.7 D2: 13.2 D3: 10.1 D3 vs. D1, P =0.10 D3 vs. D2; P =0.003 Modified Sharp/van der Heijde Score change: D1: 3.7 D2: 0.4 D3: 0.5 P < 0.001 Erosion Score change: D1: 3.0 D2: 0.3 D3: 0.1 P < 0.001 JSN Score change: D1: 0.6 D2: 0.1 D3: 0.2 P < 0.001 | SAEs: D1: 11 D2: 14 D3: 14 Serious Infections: D1: 2.1 D2: 5.6 D3: 5.0 Infusion or injection reaction: D1: 7 D2: 21 D3: 15 TB: D1: 0 D2: 0.8 D3: 0.3 Nausea: D1: 18 D2: 20 D3: 17 URTI: D1: 21 D2: 25 D3: 28 | Overall Attrition Rate, %: 14.9 ITT Analysis: Yes Quality Rating: Fair
Author, year: Smolen et al., 1999; Larsen 2001; Scott 2001 Country, Setting: Multinational, multicenter Funding: Hoechst Marion Roussel Research Objective: Efficacy and safety of novel DMARD leflunomide was compared to placebo and sulfasalazine Study Design: RCT Overall N: 266 (358 including placebo arm) Study Duration: 24 wks (12 and 24 month followup) | Inclusion Criteria: • Age: ≥ 18 • Active RA defined by: ≥ 6 tender and swollen joints, based on a 28-joint count, physician and pt global assessments of RA activity of “fair, poor, or very poor”, CRP > 2.0 mg/dL or ESR > 28 mm/h • Functional class I – III • Other DMARDs discontinued ≥ 4 wks • Stable doses of NSAIDS permitted -acetylsalicylic acid, oral steroids (prednisolone ≤ 10 mg/day), and up to 3 intra-articular steroid injections, not exceeding 60 mg triamcinolone • Intra-articular steroid injections not permitted during first 6 mos Exclusion Criteria: • Pregnant or lactating | Interventions: D1: LEF D2: SSZ N: D1: 133 D2: 133 Mean age, yrs: D1: 58.3 D2: 58.9 Sex, % female: D1: 75.9 D2: 69.2 Race, % white: NR | Mean disease duration, yrs: D1: 7.6 D2: 7.4 TJC, mean: NR SJC, mean: NR DMARD use, %: D1: 60.2 D2: 48.9 Corticosteroid use, %: D1: 28.6 D2: 27.8 MTX naive, %: NR Treatment resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR RF positive: D1: 79% D2: 80% | At 24 weeks ACR 20, %: D1: 55 D2: 56 ACR 50, %: D1: 33 D2: 30 Improving HAQ scores, change (%): D1: −0.50 (45) D2: −0.29 (29) (P = 0.0086) Change in Sharp; number, change (SD): D1: 87 1.23 (2.85) D2: 84 2.32 (10.11) Larsen score change: D1: 0.01 D2: 0.01 (P = NS) At 1 year Change in Sharp; number, change (SD): D1: 60 0.97 (6.11) D2: 53 1.38 (2.88) Larsen score change: D1: 0.02 D2: 0.02 (P = NS) At 2 years Larsen score change: D1: −0.07 D2: −0.02 (P = NS) Similar ACR20 response rates D1: 48; D2: 44; P=NR | SAEs: D1: 5 D2: 7 Headache: D1: 7 D2: 11 Nausea: D1: 10 D2: 17 URTI: D1: 14 D2: 15 Diarrhea: D1: 17 D2: 9 Alopecia: D1: 8 D2: 5 Rash: D1: 10 D2: 9 Withdrawal due to AEs: D1: 14 D2: 19 2 cases of reversible agranulocytosis in SSZ | Overall Attrition Rate, %: 33% at 24 wks ITT Analysis: Yes Quality Rating: Fair
Author, year: Strand et al., 1999; Cohen 2001; Strand, Tagwell 1999 Country, Setting: US and Canada, multicenter (47 university & private rheumatology practices) Funding: Hoescht Marion Roussel Research Objective: Efficacy and safety of LEF with placebo and MTX in active RA Study Design: RCT Overall N: 482 (active arms- 364) Study Duration: 12 mos (w/1 year followup) | Inclusion Criteria: • Age: 18 or older • Diagnosed according to ACR criteria; DMARDs discontinued at least 30 days prior • Duration of condition at least 6 mos • 10 mg stable prednisone (or equivalent) • NSAIDs if dosages stable at least 30 days prior to enrollment) Exclusion Criteria: • Pregnant or lactating • Prior treatment with: MTX • Inflammatory joint disease not caused by RA, • History of clinically significant drug or alcohol abuse, or admitted to consumption of more than 1 alcoholic drink per day | Interventions: D1: LEF (20 mg/week) D2: MTX (7.5 to 15 mg/week) N: D1: 182 D2: 182 Mean age, yrs: D1: 54.1 D2: 53.3 Sex, % female: D1: 72.5 D2: 75.3 Race, % white: NR | Mean disease duration, yrs: D1: 7.0 D2: 6.5 TJC, mean: D1: 15.5 D2: 15.8 SJC, mean: D1: 13.7 D2: 13.0 DMARD use, %: D1: 55.5 D2: 56.0 Corticosteroid use, %: D1: 53.8 D2: 52.7 MTX naive, %: Both groups 100 Treatment resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR RF positive: D1: 64.8 D2: 59.4 MHAQ: D1: 0.8 D2: 0.8 | At 12 mos ACR 20, % D1: 52 D2: 46 ACR 50, % D1: 34 D2: 23 ACR 70, % D1: 20 D2: 9 MHAQ mean change D1: −0.3 D2: −0.2 Sharp score change D1: 0.53 (n:131) D2: 0.88 (n= 138) (P = 0.05) Mean change HAQ-DI D1: −0.45 (n= 164) D2: −0,26 (n= 168) (P ≤ 0.01) Mean change SF-36 physical component D1: 7.6 (n= 157) D2: 4.6 (n=162) Work productivity mean change D1: 9.8 (n= 138) D2: 7.5 (n= 148) Discontinuation rate, %: D1: 22 D2: 10.4 (P = NR) At 2 yrs ACR 20, % D1: 79 D2: 67 (P = 0.049) ACR 50, % D1: 34 D2: 28 ACR70, % D1: 17 D2: 12 Sharp score change D1: 1.6 (n= 71) D2: 1.2 (n= 66) HAQ DI change D1: −0.6 (n= 97) D2: 0.37 (n=101) Discontinuation rate, %: D1: 27 D2: 17 | SAEs: D1: 1.1 D2: 2.7 Infections: D1: 56.6 D2: 59.9 Abdominal Pain: D1: 13.7 D2: 15.4 Nausea: D1: 20.9 D2: 19.2 Back pain: D1: 8 D2: 2 Diarrhea: D1: 36.8 D2: 21.6 Oral Ulcers: D1: 6.8 D2: 10.5 GI Events: D1: 5.5 D2: 1.7 Elevated Transaminases: D1: 7.1 D2: 4.4 Adherence: Non-adherence as the reason for reason for withdrawal D1: 1 D2: 1 At 24 months SAEs, %: D1: 18.9 D2: 18.9 | Overall Attrition Rate, %: 51% at 1 year ITT Analysis: Yes Quality Rating: Fair
Author, yr: Svensson et al 2005 Country, Setting Sweden Multicenter Funding: Swedish Rheumatism Association and others Research Objective Efficacy of low- dose PNL on joint damage and disease activity in pts with early RA being treated concomitantly with DMARDs Study Design: RCT Overall N: 250 Study Duration: 2 yrs | Inclusion Criteria: • Age 18 to 80 yrs • Diagnosed according ARA 1987 revised criteria • Duration ≤1 yr: pt in BARFOT study • DAS28 score >3.0 • Started by treating rheumatologist on first DMARD • Concomitant NSAIDS txt permitted • Intraarticular steroid injections allowed except 2 wks prior to any clinical evaluation Exclusion Criteria: • Pregnant or lactating • Glucocorticoids, DMARDs • Contraindication for glucocorticoid therapy • Previous fragility fractures, pts < 65 years with T score < −2.5 on bone mineral densitometry • 65 or older with Z score ≤ 1 | Interventions, dose: D1: DMARD (SSZ 2 g/day or MTX mean dose 10 mg/week, dosages NR) + PNL (7.5 mg/d) D2: DMARD only N: D1: 119 D2: 131 Mean age, yrs: D1: 51 D2: 59 Sex, % female: D1: 65 D2: 63 Race, % white: D1: NR D2: NR | Mean disease duration, yrs: D1: 6.5 mos D2: 5.8 mos TJC, mean: NR SJC, mean: NR DMARD use, %: Overall: 100 Corticosteroid use, %: NR MTX naive, %: NR Txt resistant, %: NR Pts with Early RA (≤3 yrs): Overall: 100 Baseline DAS, mean: D1: 5.28 D2: 5.42 HAQ: D1: 1.01 D2: 0.98 SOFI: D1: 8 D2: 9 | At 2 yrs: DAS < 2.6 disease remission, % achieved D1: 55.5 D2: 32.8 (P = 0.0005) DAS28, scores over time ± SD D1: 5.3 ± 1.1 at baseline to 2.7 ± 1.5 after 1 yr and 2.7 ± 1.3 after 2 yrs D2: 5.4 ± 1.0, 3.3 ± 1.5, and 3.2 ± 1.4 HAQ scores mean decrease over time: D1: 1.0 at baseline to 0.4 at 1 year and 0.5 D2: 1.0, 0.6, and 0.7 (P value NR) Improvement in mean SOFI index D1: mean decreased from 8 at baseline to 4 at 1 year and 4 after 2 years D2: 9, 6, and 7 respectively (P value NR) Total sharp score,median IQR change i D1: 1.8 (IQR 0.5–6.0) D2: 3.5 (IQR 0.5–10.0) (P = 0.019) Newly eroded joints per pt, median D1: 0.5 (IQR 0–2) D2: 1.25 (IQR 0–3.25) (P = 0.007) Radiographic progression beyond smallest detectable difference, % D1: 25.9 D2: 39.3 (P = 0.033) Joint space narrowing score, median change D1: 1 D2: 2 (P = 0.08) | NR | Overall Attrition Rate, %: 6.6% ITT Analysis: Yes Quality Rating: Fair
Author, yr: Weaver et al., 2006 Country, Setting: US, rheumatology practices (509) Funding: Immunex Corporation Research Objective: To evaluate effectiveness of select biologics, MTX (MTX), and other DMARDs in management of adult RA in routine clinical practice Study Design: Prospective cohort study Overall N: 5,397 Study Duration: 12 mos | Inclusion Criteria: • Age: 18 or older • Diagnosed with RA according to ACR criteria: 1987 ACR • Pts requiring a change in RA txt Exclusion Criteria: • Pregnant or lactating • Active infection, • Concurrent enrollment in a clinical trial | Interventions, dose: D1: MTX (10 to 15 mg/wk) D2: ETA (50 mg/wk) D3: ETA (50 mg/wk) +MTX D4: INF (3.8 mg/8wks) D5: INF (3.8 mg/8wks) + MTX (15 mg/wk) D6: LEF (20 mg/d) D7: LEF (20 mg/d) +MTX (15 mg/wk) D8: MTX (15 mg/wk) +HCQ (400 mg/d) D9: MTX (15 mg/wk) +HCQ (400 mg/d) +SSZ (2000 mg/d) N: D1: 941 D2: 1251 D3: 1783 D4: 120 D5: 540 D6: 204 D7: 191 D8: 325 D9: 42 Mean age, yrs: D1: 56.8 D2: 53.2 D3: 52.6 D4: 60.2 D5: 58.5 D6: 57.7 D7: 55.5 D8: 53.8 D9: 47.8 Sex (% female D1: 75 D2: 75 D3: 79 D4: 71 D5: 77 D6: 76 D7: 78 D8: 80 D9: 79 Race, % white: D1: 77 D2: 81 D3: 81 D4: 78 D5: 81 D6: 78 D7: 82 D8: 83 D9: 79 | Mean disease duration, yrs: D1: 3.5 D2: 9.2 D3: 7.7 D4: 10.6 D5: 9.5 D6: 10.1 D7: 7.4 D8: 4.6 D9: 7.2 TJC, mean: D1: 13 D2: 13.4 D3: 13.3 D4: 14.8 D5: 3.9 D6: 12.8 D7: 12.2 D8: 11.8 D9: 10.1 SJC, mean: D1: 11.3 D2: 11.1 D3: 11.5 D4: 13.9 D5: 12.0 D6: 11.8 D7: 11.4 D8: 9.2 D9: 10.2 DMARD use, %: D1: 25 D2: 75 D3: 96 D4: 85 D5: 96 D6: 75 D7: 95 D8: 78 D9: 88 Corticosteroid use, % D1: 53 D2: 48 D3: 51 D4: 63 D5: 57 D6: 48 D7: 56 D8: 50 D9: 48 MTX naive, %: NR Treatment resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR RF factor positive: D1: 72 D2: 65 D3: 69 D4: 68 D5: 69 D6: 75 D7: 73 D8: 71 D9: 71 | mACR20, %: D1: 37 D2: 41 D3: 43 D4: 26 D5: 35 Adjusting for baseline covariates D3: vs. D1(OR 1.29, 95% CI, 1.09–1.52; P < 0.01) D2 vs. D1 (OR 1.23, 95% CI, 1.02–1.47; P < 0.05) D1 vs. D5 (OR 0.96 CI 0.76–1.21 p = 0.72) D1 vs. D4 (OR 0.66, 95% CI, 0.43–1.02; P = 0.06) Mean change HAQ improvement, % D1: 7 D2: 17 (P < 0.001) D3: 17 (P < 0.001) mACR20 response D5 vs. D1: (OR 0.68, 95% CI, 0.48–0.96; P < 0.05) D6 vs. D1 (OR 0.76, 95% CI, 0.54–1.06; P = 0.11) D8 vs, D1: (OR 0.94, 95% CI, 0.72–1.23; P = 0.64) D9 vs. D1: (OR 0.57, 95% CI, 0.27–1.18; P = 0.13) SJC % improvement D1 vs D1: 34 (N/A) D2 vs. D1: 53 (P < 0.0001) D4 vs. D1: 29 (P = NS) D3 vs. D1: 55 (P < 0.0001) D5 vs D1:48 (P < 0.01) TJC % improvement D1: 34(N/A) D2 vs. D1: 53% (P < 0.001) D4 vs D1: 29% (P = NS) D3 vs D1: 55% (P < 0.0001) D5 vs D1: 48% (P = NS) HAQ % improvement amongst pts < 65 yrs D2: 22 D4: 4 (P = NR) | NR | Overall Attrition Rate, %: 33.2 ITT Analysis: Yes Quality Rating: Fair

Evidence Table 6

KQ 2. Rheumatoid arthritis systematic reviews: functional capacity and quality of life

Study Characteristics | Inclusion and Exclusion Criteria | Characteristics and Interventions | Baseline Disease and Treatment Characteristics | Health Outcomes | Adverse Events (%) | Analysis and Quality Rating
Author, year, country, funding: Osiri et al., 2002 Multinational Cochrane Collaboration Study Design: Systematic review of RCTs and CCTs Aims of Review: To determine efficacy and toxicity of LEF compared to placebo or other DMARDs in txt of RA Meta-analysis stratified comparison between LEF and Placebo or other DMARDs by outcomes at different length of txts Number of Pts: 1,144 LEF 312 to Placebo 680 to MTX 132 to SSZ Only 920 used in meta- analysis 2 yr extension: LEF:158 SSZ: 60 MTX 101 | Studies included: 6 trials Characteristics of included studies: Randomized, double- blind, placebo and/or active controlled Characteristics of included populations: All with active RA Characteristics of interventions: 5, 10 or 25 mg/d vs placebo or MTX or SSZ | • LEF significantly better than placebo at 6,12 and 24 mos. • LEF vs. MTX • ACR 20: Significantly more responders for MTX than LEF at 12 mos; OR: 1.43 (1.15–1.77) • No significant differences at 2 yrs but more responders with MTX than with LEF; OR 1.28 (0.98–1.67) • ACR 50, ACR 70: differences in ACR 50/70 repsonses between LEF and MTX were NS | • Total withdrawals lower in LEF group (10% greater than Placebo [70/416 vs 18/311]); LEF not diff in efficacy and tolerability than MTX and SSZ, except that LEF was more efficaious than SSZ at 24 mos • AEs+ GI sympotms, elevated liver funcitn tests, alopecia, and infections | Publication Bias Assessed: NR Heterogeneity Assessed: Yes Standard Method of Study Appraisals: Yes Comprehensive Search Strategy: Yes Quality Rating: Good

Evidence Table 7

KQ2. Psoriatic arthritis trials: Functional capacity and quality of life

Study Characteristics | • Inclusion and Exclusion Criteria | Characteristics and Interventions | Baseline Disease and Treatment Characteristics | • Health Outcomes | Adverse Events (%) | Analysis and Quality Rating
Author, yr: Antoni et al., 2005 and Kavanaugh et al., 2006 IMPACT Study Country, Setting: Multinational 9 clinical sites Funding: NIH; Centocor, Inc.; Schering- Plough Research Institute; Competence Network Research Objective: Efficacy and tolerability of INF for the articular and dermatologic manifestations of active PsA Study Design: RCT Overall N: 104 Study Duration: 50 wks (1–16 wks RCT 16–50 open, all treated with INF) | Inclusion Criteria: • Age ≥ 18 • Failure of 1 or more DMARD • Active peripheral polyarticular arthritis • MTX ≥ 15 mg/wkw/folic acid supplementation • LEF, SSZ, HCQ, intramuscular gold, penicillamine, or azathioprine stable for 4 wks • oral corticosteroids (dosage of 10 mg PRE equivalent/d or less) • NSAIDs stable for at least 2 wks Exclusion Criteria: • Monoclonal antibody or fusion protein • History of TB: positive tests for RF or latent TB investigational drug within 3 mos | Interventions: D1: Placebo D2: INF (5mg/kg at wks 0,2,6,14, then every 8 wks) N: D1: 52 D2: 52 Mean age, yrs: D1: 45.2 D2: 45.7 Sex, % female: D1: 42.3 D2: 42.3 Race, % white: NR | Mean disease duration, yrs: D1: 11 D2: 11.7 TJC, mean: D1: 20.4 D2: 23.7 SJC, mean: D1: 14.7 D2: 14.6 DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 5.4 D2: 5.5 | • ACR50 Placebo 0/52 (0.0%) vs. INF 24/52 (46.2%) • ACR70 Placebo 0/52 (0.0%) vs. INF 15/52 (28.8%) • # of tender joints Placebo −23.6 vs. INF 55.2 • # of swollen joints Placebo − 1.8 vs. INF 59.9 • DAS Placebo 2.8 vs. INF 45.5 P < 0.001 • HAQ Placebo −1.6 vs. INF 49.8 P < 0.001 • PsARC Placebo −12% vs. INF +86% P < 0.001 • ACR20 wk 16 Placebo 5/52 (9.6%) vs. INF 34/52 (65.4%) P < 0.001 • At 50 wks • Total modified vdH-S score, 85% and 84% in Placebo/INF and INF/INF groups had no worsening. • Change in erosion scores INF/INF 0.921, placebo/INF 0.536 (P = 0.780) • Change in JSN INF/INF − 0.51, placebo/INF −0.47 (P = 0.211) • 16 wks-PsARC INF 75% vs. Placebo 21% (P < 0.001) • PASI75 INF 68% vs, placebo 0% (P < 0.001) | Overall: D1: 65 D2: 73 D3: 84 Headache: D1: 3 D2: 4 URTI: D1: 5 D2: 1 | Overall Attrition Rate (%): 5 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Antoni, 2005 And Kavanaugh et al., 2006 Country, Setting: Multinational 36 sites in clinics IMPACT2 Study Funding: Centocor Inc and Schering-Plough Research Objective: Efficacy, health related quality of life and physical function in pts with PsA Study Design: RCT Overall N: 200 Study Duration: 14 to 24 wks (pts with inadequate response entered wk 16) | Inclusion Criteria: • Diagnosed with PsA • Diagnosed at least 6 mos before first infusion of study drug • Inadequate response to current or previous DMARDs or NSAIDs • Pts had to have active plaque psoriasis with at least 1 qualifying target lesion at least 2 cm in diameter • Negative test for RF in their serum • Stable doses of MTX, oral corticosteroids, NSAIDs Exclusion Criteria • TNF α inhibitors; active or latent TB • Chronic or clinically significant infection, malignancy, or CHF | Interventions: D1: Placebo D2: INF (5 mg/kg at wks 0, 2, 6, 14, 22) N: D1: 100 D2: 100 Mean age, yrs: D1: 46.5 D2: 47.1 Sex, % female: D1: 49 D2: 29 Race, % white: NR | Mean disease duration, yrs: D1: 7.5 D2: 8.4 TJC, mean: D1: 25.1 D2: 24.6 SJC, mean: D1: 14.4 D2: 13.9 DMARD use, %: NR Corticosteroid use, %: D1: 10 D2: 15 MTX naive, %: NR Txt resistant, %: Overall 100 Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR MTX use, %: D1: 45 D2: 47 PASI: D1: 10.2 D2: 11.4 | • Placebo vs. INF (%): • ACR 50 at wk 14 3 vs. 36 (P < 0.001) and wk 24 4 vs. 41 (P < 0.001) • ACR70 at wk 14 1 vs. 15 (P < 0.001) and wk 24 2 vs. 27 (P < 0.001) • PsARC at wk 14 27 vs. 77 (P < 0.001) and wk 24 32 vs. 70 (P < 0.001) • HAQ improvement at wk 14 –18.4 vs. 48.6 (P < 0.001) and wk 24 -19.4 vs. 46 (P < 0.001) • SF-36 (change from baseline) • Physical wk 14 1.1 vs. 9.1 (P < 0.001) and wk 24 1.3 vs. 7.7 (P < 0.001) • Mental wk 14-1.2 vs. 3.8 (P = 0.001) and wk 24 0.4 vs. 3.9 (P = 0.047) • ACR20 at Wk 14 11 vs. 58 (P < 0.001) and Wk 24 16 vs. 54 (P < 0.001) • PASI 50: wk 14: 9 vs. 82 (P <0.01), wk 24: 8 vs. 75 (P <75 (P<0.01); PASI 75 wk 14: 2 vs. 64 (P < 0.01), wk 24: 1 vs. 50 (P < 0.01); • improvement wk 14: 0 vs 41 (P < 0.01), wk 24: 0 vs. 39 (P < 0.01) • median productivity at 14 wks 9.2% vs. 67.5% (P < 0.0001) • missed workdays at 14 wks 13% vs. 3.7% (P = 0.138) | Overall: D1: 67 D2: 67 SAEs: D1: 6 D2: 9 Infusion or injection reaction: D1: 6 D2: 7 Dizziness: D1: 5 D2: 4 Headache: D1: 5 D2: 6 URTI: D1: 14 D2: 10 | Overall: Attrition Rate (%): Wk 14: NR Wk 24: 7.5 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Kaltwasser et al., 2004 and Nash et al., 2006 Country, Setting: Multinational Multi-center (31) Funding: Aventis Research Objective: Efficacy and safety of LEF versus placebo in pts with PsA and psoriasis Study Design: RCT Overall: N: 190 (ITT = 186) Study Duration: 24 wks | Inclusion Criteria: • Age 18 to 70 • Diagnosed with PsA • NSAIDs or Css (prednisone dose of 10 mg/day or steroid equivalent administered orally) • Discontinue DMARDs, biologics and systemic antipsoriatic txt 28 days Exclusion Criteria: • Pregnant or lactating; leflunomide • Impaired renal or hepatic system • Nonpsoriatic inflammatory joint disease or arthritis onset < 16 yrs • RH factor +, rheumatoid nodules, serious infections, malignancy, or CVD, HIV, hepatitis B or C antigen positivity, guttate, pustular, or erythrodermic forms of psoriasis, body weight <45 kg • Impaired bone marrow function; history of drug or alcohol abuse | Interventions: D1: Placebo D2: LEF N: D1: 91 D2: 95 Mean age, yrs: Drug 1: 46.9 Drug 2: 48.6 Overall Sex, % female: D1: 37.4 D2: 42.1 Race, % white: D1: 95.6 D2: 97.9 | Mean disease duration, yrs: D1: 10 D2: 11 TJC, mean: NR SJC, mean: NR DMARD use, %: D1: 49.5 D2: 61.1 Corticosteroid use, %: D1: 9.9 D2: 15.8 DMARD naive, %: D1: e 50.5 D2: 38.9 Txt resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR | • 56 of 95 leflunomide-treated pts (58.9%; 95% CI, 48.4–68.9) and 27 of 91 placebo-treated pts (29.7% [95% CI, 20.6– 40.2]) were classified as responders by PsARC (P < 0.0001) Change in HAQ total score • Placebo (N:90) −0.05 ± 0.46 (P = 0.0267) • Leflunomide (N:94) −0.19 ± 0.51 Change in PASI score • Placebo (N:90) −0.6 ± 6.1 P = 0.0030 • Leflunomide (N:92) −2.1 ± 5.9 Change in DLQI total score • Placebo (N:89) −0.2 ± 5.1 P = 0.0173 • Leflunomide (N:90) −1.9 ± 5.1 | Overall: D1: 76.1 D2: 85.4 SAEs: D1: 5.4 D2: 13.5 Serious Infections: D1: 0 D2: 0 Diarrhea: D1: 13.0 D2: 24.0 Headache: D1: 7.6 D2: 11.5 Nausea: D1: 8.7 D2: 9.4 | Overall Attrition Rate, %: 47.9% ITT Analysis: Yes Quality Rating: Fair
Author, yr: Mease et al., 2000 Country, Setting: US Single center in Seattle Funding: Immunex Corp. Research Objective: To study the efficacy and safety of etanercept in pts with psoriatic arthritis and psoriasis Study Design: RCT Overall N: 60 Study Duration: 12 wks | Inclusion Criteria: • Age 18 to 70 • Diagnosed with PsA according to: > 3 swollen, tender, or painful joints • Inadequate response to NSAIDs • Hepatic transasminase concentrations no greater than 2x upper limit of normal • Hemoglobin 85 g/L or higher • Platelet count 125,000 per mL or more and serum creatinine 152-4 mmol/L or below • MTX < 25 mg/wk and stable for 4 wks • Corticosteriods if the dose < 10 mg/d of PRE, stable for at least 2 wks and maintained at a constant dose throughout study Exclusion Criteria: • Evidence of skin conditions other than psoriasis | Interventions: D1: Placebo D2: ETA (25mg 2x wkly) N: D1: 30 D2: 30 Mean age, yrs: D1: 43.5 D2: 46 Sex, % female: D1: 40 D2: 47 Race, % white: D1: 83 D2: 90 | Mean disease duration, yrs: D1: 9.5 D2: 9 TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: D1: 40 D2: 20 MTX naive, %: NR Txt resistant, %: Overall 100 Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR MTX: D1: 47 D2: 47 | • PsARC ETA 26 (87%) vs. Placebo 7 (23%) P < 0.0001 95% CI, 44–83; ACR50 ETA 15 (50%) vs. Placebo 1 (3%) P = 0.0001 95% CI, 28–66; • ACR70 ETA 4 (13%) vs. Placebo 0 (0%) P = 0.0403 95% CI, 1–26; • HAQ ETA 0.1 (0,1) vs. Placebo 1.3 (0.9,1.6) P < 0.001 • ACR20 was achieved by 73% ETA treated pts compared with 13% placebo treated pts (P < 0.0001) • Median % improvements in tender and swollen joint counts at 12 wks ETA 75% and 72% respectively vs. placebo 5% worsening and 19% improvement; disability according to HAQ significantly more improved in ETA than placebo (83% vs. 3%, P < 0.0001) • 26% of ETA vs. 0 of placebo pts achieved 75% improvement in PASI at 12 wks (P = 0.0154); similar differences between ETA and placebo also seen at 25% and 50% improvements in PASI scores | SAEs: D1: 0 D2: 3.3 Infusion or injection reaction: D1: 20 D2: 3 Headache: D1: 13 D2: 10 URTI: D1: 57 D2: 57 | Overall Attrition Rate, %: 6.6% ITT Analysis: Yes Quality Rating: Fair
Author, yr: Mease et al., 2004; Mease et al., 2006 (2nd yr outcomes) Country, Setting: US, 17 sites Funding: Immunex Research Objective: Safety, efficacy, and effect on radiographic progression of ETA in pts with PsA Study Design: RCT Overall N: 205 Study Duration: 24 wks (with 48 wk open-label phase) | Inclusion Criteria: • Age 18 70 • Diagnosed with PsA ≥ 3 swollen and 3 tender joimts • Inadequate response to NSAID • At least one of PsA subtypes: distal interphalangeal joint involvement, polyarticular arthritis, arthritis mutilans, asymmetric peripheral arthritis, or ankylosing spondylitis-like arthritis • Stable plaque psoriasis with a qualifying lesion • MTX therapy (stable 2 mo ≤ 25 mg/wk) • Css (stable 4 wks ≤ 10 mg/d of prednisone) Exclusion Criteria: • Oral retinoids, topical vitamin A or D analog preparations, and anthralin | Interventions: D1: placebo D2: ETA (25 mg 2x wkly) N: D1: 104 D2: 101 Mean age, yrs: D1: 47.3 D2: 47.6 Sex, % female: D1: 55 D2: 43 Race, % white: D1: 91 D2: 90 | Mean disease duration, yrs: D1: 9.2 D2: 9 TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: D1: 15 D2: 19 MTX naive, %: NR Txt resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR MTX use, %: D1: 41 D2: 42 Sharp: D1: 18.3 D2: 25.89 | • At 12 wks, 59% of ETA pts met ACR20 criteria compared with 15% placebo pts (P < 0.0001) • 23% of ETA pts eligible for psoriasis evaluation achieved at least 75%improvement in psoriasis area and severity index, compared with 3% of placebo pts (P = 0.001) • 12 mos; the mean annualized rate of change over one yr of txt in modified Sharp score was −0.03 unit, compared with 1.00 unit in the placebo (P = 0.0001) • HAQ- improvement from baseline in ETA group 54% vs. 6% of placebo group (P < 0.0001) • 72% & 70% of ETA achieved PsARC at 12 and 24 wks, respectively, compared with 31% and 23% of placebo pts | SAEs: D1: 3.9 D2: 4 Infusion or injection reaction: D1: 9 D2: 36 Headache: D1: 5 D2: 8 URTI: D1: 23 D2: 21 UTI: D1: 6 D2: 6 | Overall Attrition Rate, %: 19.5 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Mease et al., 2005 Country, Setting: Multinational, multi-clinic (50) ADEPT Study Funding: Abbott Laboratories Research Objective: Safety and efficacy of ADA compared with placebo in txt of active psoriatic arthritis Study Design: RCT Overall N: 313 Study Duration: 24 wks | Inclusion Criteria: • Age ≥ 18 • Moderate to severe PsA • Active psoriatic skin lesions or a documented history of psoriasis • Inadequate response or intolerance to NSAIDs • MTX ≥ 3 mos with stable dose 4 wks Exclusion Criteria: • CYP, tacrolimus, DMARDs, or oral retinoids (4 wks) • Topical txts for psoriasis within 2 wks, other than medicated shampoos or low-potency topical steroids • Anti-TNF • History of TB • Central nervous system demyelinating disease • Listeriosis, or severe infection within 30 ds or oral antibiotics within 14 ds | Interventions: D1: placebo D2: ADA (40mg every other wk) N: D1: 162 D2: 151 Mean age, yrs: D1: 49.2 D2: 48.6 Sex, % female: D1: 45.1 D2: 43.7 Race, % white: D1: 93.8 D2: 97.4 | Mean disease duration, yrs: D1: 9.2 D2: 9.8 TJC, mean: D1: 25.8 D2: 23.9 SJC, mean: D1: 14.3 D2: 14.3 Mean number previous DMARDS: D1: 1.5 D2: 1.5 Corticosteroid use, %: NR MTX naive, %: NR Txt resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline PASI (mean): D1: 8.3 D2: 7.4 MTX use: D1: 50 D2: 51 Baseline HAQ: D1: 1.0 D2: 1.0 | • PsARC ADA 60% wk. vs. placebo 23% • ACR50 ADA, 39% vs. placebo, 6% (P < 0.001) • ACR70 ADA, 23% vs. placebo, 1% (P < 0.001) • The PASI75 ADA 59% vs. placebo 1% (P < 0.001) (N:69 per group). • HAQ DI change placebo − 0.1 ± 0.4 vs. ADA −0.4 ± 0.5 (P < 0.001) • ACR20 ADA 57% vs. placebo 15% (between- group difference 42%, 95% CI, 31–52%; P < 0.001). • Mmean change in modified total Sharp was −0.2 for ADA versus placebo (P < 0.001) • Erosion scores (mean change ADA 0.0 vs. placebo 0.6 ) and JSN scores (mean change ADA −0.2 vs. placebo 0.4) (P < 0.001 for both) • SF-36: SF-36 PCS; change in baseline to wk 12 for placebo vs ADA; 1.4 vs 9.3 (P < 0.001) • Change in baseline to wk 24; 1.4 vs 9.3 (P < 0.001) • SF-36 MCS • Change in baseline to wk 12; 1.2 vs 1.6 (P NS) • Change in baseline to wk 12; 0.6 vs 1.8 (P NS) | Infusion or injection reaction: D1: 3.1 D2: 6.6 Headache: D1: 8.6 D2: 6.0 URTI: D1: 14.8 D2: 12.6 UTI: NR | Overall Attrition Rate, %: 7.6 ITT Analysis: Yes Quality Rating: Fair.

Evidence Table 8

KQ3. Rheumatoid arthritis trials: harms, tolerability, adverse effects, or adherence

Characteristics | Inclusion and Exclusion Criteria | Characteristics and Interventions | Baseline Disease and Treatment Characteristics | Health Outcomes | Adverse Events, % | Analysis and Quality Rating
Author, yr: Askling et al., 2005 Country, Setting: Sweden; registries Funding: Swedish Cancer Society; AFA Insurance Company; Wyeth-Ayerst; Schering-Plough; Abbott Immunology; Bristol-Myers Squibb; King Gustav V; Österlund and Kock Foundations; Reumatikerför-bundet Research Objective: The risk of TB pts with RA Study Design: Retrospective cohort study Overall N: 36,115 w/RA Study Duration: 467,770 PY | Inclusion Criteria: • Diagnosed with RA according to ACR criteria • RA inpatient btwn 1964 to 2001 Exclusion Criteria: • Psoriatic arthritis, SLE, or AS diagnosis | Interventions, dose: D1: RA inpatient D2: Early RA D3: TNF treated RA N: D1: 31,185 D2: 2430 D3: 2500 Mean age, yrs: D1: 0-39: 19.08%;40-59: 40.80%;60-79: 35.90%;80+: 4.22% D2: 0-39: 15.80%;40-59: 38.40%;60-79: 41.60%;80+: 4.20% D3: 0-39: 18.40%;40-59: 49.44%;60-79: 30.52%;80+: 1.64% Sex, % female: D1: 73.4 D2: 70.2 D3: 73.4 Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA ( 3 yrs): NR Baseline DAS, mean: D1: NA D2: 3.6 D3: 5.8 HAQ: D1: NA D2: 0.8 D3: 1.84 TB cases: D1: 27 D2: 2 | 1987 to 2001 • RA inpatient vs. General RR 3.9 (95% CI,3.1-5.0) • RA inpatient vs. General inpatient RR 1.6 (95% CI,1.3-1.9) 1999 to 2001 • RA inpatient vs. General were at increased risk of TB RR 2.0, (95% CI,1.2-3.4) • TNF treated RA had a 4-fold increased risk of TB RR 4.0, (95% CI,1.3-12) vs. RA inpatient | NA | Overall Attrition Rate, %: NA ITT Analysis: NA Quality Rating: Good
Author, yr: Askling et al., 2005 Country, Setting: Sweden, Multicenter Funding: Swedish Cancer Society; insurance company AFA; Wyeth Ayerst, Schering-Plough, Abbott, Bristol Myer Squibb; Swedish National Board of Health and Welfare Research Objective: Cancer pattern of contemporary pts with RA and risk of solid cancer after TNF Study Design: Retrospective cohort study Overall N: 60,930 Study Duration: NR | Inclusion Criteria: • Inpatient Register RA cohort: inpts > 16 yrs or age ever discharged with an RA diagnosis between January 1990 and December 31 2003 • Early RA cohort: pts diagnosed within 1 yr with RA from 1995 through 2003. • TNF antagonist cohort: pts with RA treated with ETA, INF, or ADA from a Swedish registry of pts treated with anti-TNF medications Exclusion Criteria: • Pregnant or lactating • Inpatient Register RA cohort • Pts discharged with SLE, AS, or PsA Observed and expected cancers during the 1st yr of follow up | Interventions, dose: D1: Inpatient RA Cohort D2: Early Arthritis RA Cohort D3: TNF antagonist cohort N: NR Mean age, yrs: NR Sex, % female: D1: 71.4 D2: 69.9 D3: 74.8 Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA ( 3 yrs): NR Baseline DAS, mean: D1: NR D2: 3.5 D3: 5.5 % age 45-74 yrs: D1: 56.3 D2: 65.4 D3: 71.8 | Inpatient RA cohort: Based on 3379 observed solid cancers, this cohort had minimally increased overall risk of solid cancer (SIR = 1.05, 95% CI,1.01 to 1.08) Overall RR was 1.19 (95% CI,1.13 to 1.26, N:1311) among men and 0.97 (95% CI,0.93 to 1.02, N:2068) among women GI cancer risk (SIR = 0.85, 95% CI,0.78 to 0.93); Lung cancers (SIR = 1.48, 95% CI,1.33 to 1.65); (SIR = 1.66, 95% CI,1.50 to 1.84); Early Arthritis cohort: 138 solid cancers (SIR = 1.1, 95% CI,0.9 to 1.3), women (SIR = 0.87, 95% CI,0.67 to 1.11, n =64) Men (SIR = 1.42, 95% CI,1.12 to 1.79, n =74) TNF cohort • 67 solid cancers observed (SIR = 0.9, 95% CI,0.7 to 1.2) Women (SIR = 0.87, 95% CI,0.63 to 1.16, N:45) Men 1.06 (95% CI,0.67 to 1.61, N:22) Risk of colorectal cancer (SIR = 1.2 lung cancer (SIR = 1.8), breast cancer (SIR = 0.4), NMSC ( SIR = 3.6) | NA | Overall Attrition Rate, %: NR ITT Analysis: NA: retrospective cohort Quality Rating: Fair
Author, yr: Askling, 2005 Country, Setting: Sweden, Registry data Funding: AFA Insurance Company, Pharmas: Swedish National Board of Health and Welfare; Swedish Cancer Society Research Objective: Risks of hemapoetic malignancies, especially those with associtaed with TNF Study Design: Retrospective cohort study Overall N: Prevalent Cohort (inpatient): 53,067 Study Duration: 4 yrs | Inclusion Criteria: • Age: Prevalence: 16+ • Diagnosed with RA according to ACR criteria • Prevalence: 1987 Exclusion Criteria: • Prevalence: discharged with systemic lupus, AS, or PsA | Interventions, dose: D1: Prevalence D2: Incidence D3: TNF Antagonist N: D1: 53,067 D2: 3,703 D3: 4,160 Mean age, yrs: NR Sex, % female: NR Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA ( 3 yrs): NR Baseline DAS, mean: NR | See AEs | Haematopoetic malignancnies: D1: SIR: 1.7 (1.5-1.8) D2: SIR: 1.6 (0.9-2.6) D3: 2.1 (1.1-3.8) | Overall Attrition Rate, %: ITT Analysis: NA Rating: Fair
Author, yr: Baecklund et al 2006 Country, Setting: Sweden, inpatient Funding: Swedish Rheumatism Society; Lions Cancer Research Foundation of Uppsala; AFA InsuranceSwedish Cancer Society Research Objective: To investigate which RA pts are at highest risk of lymphoma, and whether antirheumatic txt is hazardous or protective Study Design: Observational Overall N: 756 Study Duration: 1964 to 1995 | Inclusion Criteria: • Age: ≥ 16 • RA and lymphoma • All pts receiving inpatient care in Sweden discharged with a diagnosis of RA (ICD) • Randomly selected as potential controls 3 individuals from underlying RA cohort • From potential controls, we included first of 3 whose medical record could be identified and who fulfilled ACR criteria for RA Exclusion Criteria: NR | Interventions, dose: NR MTX SSZ Other?: steroids N: 756 378 cases 378 controls Mean age, yrs: NR Sex, % female: NR Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA ( 3 yrs): NR Baseline DAS, mean: NR | Risk of developing lymphoma is increased in subset of RA with severe disease.(Cases vs. controls) Inflammatory activity • Low inflammatory activity: 94 (25%) vs. 278 (74%) OR 1 (referent) • Medium: 196 (52%) vs. 94 (25%) OR 7.7 (95% CI,4.8-12.3) • High: 86 (23%) vs. 4 (1%) OR 71.3 (95% CI,24.1-211.4) Functional class • I 34 (9) vs. 138 (37) OR 1 (referent) • II 185 (49) vs. 204 (54) OR 3.9 (95% CI,2.4-6.3) • III 105 (28) vs. 31 (8) OR 13.8 (95% CI,7.2-26.2) • IV 52 (14) vs. 3 (1) OR 67.5 (95% CI,18.9-239.8) • DMARD OR 0.9 (95% CI,0.6-1.2) • MTX crude OR 0.8 (95% CI,0.4-1.4); adjusted OR 0.7 (95% CI,0.3-1.6) • SSZ; crude OR 0.6 (95% CI,0.4-1.0); adjusted OR 0.6 (95% CI,0.3-1.1) • Oral steroids (adjusted OR 0.6 [95% CI,0.4-0.9]) and intraarticular steroids (adjusted OR 0.4 [95% CI,0.2-0.6]), calculated with adjustment for disease activity and DMARD use | NA | Overall Attrition Rate, %: NA ITT Analysis: NA: Case contol study Quality Rating: Good
Author, yr: Bergstrom, 2004 Country, Setting: US, 5 practices Funding: NR Research Objective: To assess if pts who were treated with TNF antagonists have a higher risk of developing coccidioido-mycosis Study Design: Retrospective cohort study Overall N: 985 Study Duration: 3 yrs | Inclusion Criteria: • Pts with RA, reactive arthritis, PsA, JRA • Other meds were allowed Exclusion Criteria: • NA | Interventions, dose: D1: INF D2: Other Anti-TNF alpha D3: control N: D1: 7 D2: 4 D3: 974 Mean age, yrs: D1: 64.8 D2: 64 D3: 57.8 Sex, % female: D1: 71 D2: 75 D3: 77 Race, % white: D1: 86 D2: 75 D3: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA ( 3 yrs): NR Baseline DAS, mean: NR MTX use: D1: 100 D2: 50 D3: 50 | Pts treated with INF are at higher risk for developing symptomatic coccidioidomycosis 7 of 247 pts receiving INF and 4 of 738 pts receiving other therapies developed symptomatic coccidioidomycosis (relative risk 5.23, 95% confidence interval 1.54-17.71; P < 0.01) | NA | Overall Attrition Rate, %: NA ITT Analysis: NA: Quality Rating: Fair
Author, yr: Boers et al., 1997; Landewe et al., 2002 COBRA study Country, Setting: Netherlands and Belgium, multicenter Funding: Netherland Research Objective: Comparing efficacy and radiographic outcomes of combination of SSZ, MTX and PNL with SSZ alone Study Design: RCT Overall N: 155 (148) Study Duration: 56 wks; (5 yr followup) | Inclusion Criteria: • Age: 18 to 69 • Diagnosed with RA according to ACR criteria • Duration of condition < 2 yrs • NSAID txt at least 3 mos, 6 or more active inflamed joints AND presence of 2 or more (9 or more tender joints, morning stiffness 45 min or more, EST of 28 or more in first hour Exclusion Criteria: • Pregnant or lactating: adequate contraception • Prior txt with: DMARDS except HCQ or steroids • Past TB • Impaired renal or hepatic system serious comorbidity surgery in past 3 mos • Unable to comply with protocol • Allergy to study med • Alcohol or substance abuse | Interventions, dose: D1: Combined txt (SSZ, MTX, PNL) D2: SSZ Only SSZ: 2g/d MTX: 7.5 mg/wk, weaned after 40 wks PNL: 60 mg/d wk 1 40 mg/d wk 2 25 mg/d wk 3 20 mg/d wk 4 15 mg/d wk 5 10 mg/d wk 6 then 7.5 mg/d until wk 28 then weaned off N: D1: 76 D2: 79 Mean age, yrs: NR Sex, % female: D1: 66% D2: 52% Race, % white: NR | Mean disease duration, yrs: D1: 4 mos D2: 4 mos TJC, mean: NR SJC, mean: NR Antimalarial use (%): D1: 21 D2: 24 Corticosteroid use, % NR MTX naive, %: NR Txt resistant, %: NR Pts with Early RA ( 3 yrs): NR Baseline DAS, mean: NR Erosions on hand or foot xrays, %: D1: 74 D2: 79 | At week 28 Mean pooled index D1:-1.4 (95% CI, 1.2-1.6) D2:-0.8 (95% CI, 0.6-1.0) (P < 0.0001) ACR20, %: D1: 72 D2: 49 (P = 0.006) ACR50, %: D1: 49 D2: 27 (P = 0.007) DAS median change: D1:-2.1 (SD 1.2) D2:-1.3 (SD 1.2) (P < 0.0001) HAQ mean change: D1:-1.1 (SD 0.8) D2:-0.6 (SD 0.6) (P < 0.0001) Sharp mean change: D1: 1 D2: 4 (P < 0.001) At week 56 Mean pooled index: D1: 1.1 (SD 0.8) D2: 0.9 (SD 0.8) (P =0.20) DAS median change: D1: 1.4 (SD 1.2) D2: 1.3 (SD 1.4) (P = 0.78) HAQ mean change: D1: 0.8 (SD 0.8) D2: 0.6 (SD 0.7) (P < 0.06) Sharp mean change: D1: 2 D2: 6 (P < 0.004) At week 80 Sharp mean change: D1: 4 D2: 12 (P < 0.01) Five yr follow up Sharp score mean change: D1: 5.6 (95% CI, 4.3, 7.1) (P = 0.001) D2: 8.6 (95%CI, 6.2-11) (P = 0.001) Time averaged DAS28, points/yr: D1:-0.07 D2:-0.17 | Overall: D1: 72.3 D2: 62.0 SAEs: D1: 2.6 D2: 7.6 Infections: D1: 15.8 D2: 7.6 Cardiovascular Events: D1: 7.9 D2: 5.1 Hepatotoxicity: D1: 2.6 D2: 0 | Overall Attrition Rate, %: 3.2 ITT Analysis: Yes Quality Rating: Good
Author, yr: Brown, 2002 Country, Setting: US, NA Funding: Authors are from FDA and National Cancer Institute Research Objective: Occurrence of lympho-proliferative disorders in pts treated with ETA and INF Study Design: Database analysis; AERS system Overall N: 26 cases Study Duration: NA | Inclusion Criteria: MedWatch reports submitted to FDA for biologic products ETA and INF. All reports citing neoplasms, benign or malignant, were reviewed. Any report with a keyword of lymphoma or mentioned lymphoma in text was investigated further. Cases reported to MedWatch through December 2000 comprise basis for current summary Exclusion Criteria: NA | Interventions, dose: D1: ETA (various) D2: INF (various) N: D1: 18 D2: 8 Mean age, yrs: D1: 64 D2: 62 Sex, % female: D1: 61.1 D2: 25.0 Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA ( 3 yrs): NR Baseline DAS, mean: NR MTX use: D1: 72.2 D2: 25 | ETA 19 cases per 100,000 treated persons INF • 6.6 cases per 100,000 treated persons • In general, diffuse large B cell lymphoma (non-Hodgkin’s) were most common form • (21 of 26 were non-Hodgkin’s lymphomas) • Treated person rates of lymphomas in ETA and INF users is probably an underestimate based on underreporting, according to authors (Age adjusted rate of lymphomas in US from 1992-1998 18.3 per 100,000 people) • Median time to lymphoma diagnosis was 8 wks (range 2-52 wks) for ETA and 6 wks (range 2-44 wks) for INF | NA | Overall Attrition Rate, %: NA ITT Analysis: NA Quality Rating: Fair
Author, yr: Cannon et al., 2004 Country, Setting: US, claims database Funding: Aventis Pharmaceuticals; Veterans Affairs Research Objective: The incidence of serious adverse events during txt of RA with DMARDs, focusing on LEF Study Design: Retrospective cohort study Overall N: 40594 Study Duration: 2 yrs | Inclusion Criteria: • Age: 18 and older • Diagnosed with RA according to ACR criteria: ICD 9 code (rx for LEF-surrogate marker), 90 d observation period prior to entry Exclusion Criteria: • Impaired renal or hepatic system: if on DMARD other than LEF-hepatic event 90 ds prior to entering cohort • unable to determine sex or date of birth | Interventions, dose: NR HCT MTX LEF SSZ ETA INF N: NR Mean age, yrs: NR Sex, % female: NR Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA ( 3 yrs): NR Baseline DAS, mean: NR | Rates of AE in LEF group, alone and combined with MTX, were lower than or comparable to AE rates seen with MTX and other agents. LEF monotherapy had lowest rate of hepatic events in DMARD monotherapy groups All AE rates: LEF monotherapy (94 events/1000 PY, 95%CI, 84.4-104.8 ), MTX monotherapy (145 events/1000 PY, 95%CI,136.3-154.3), other DMARD (143 events/1000 PY, 95%CI,137.4-150.3), no DMARD (383 events/1000 PY, 95%CI,365.8-399.6) (P < 0.001). LEF + MTX (42.8/1000 PY, 95%CI, 32.8-55.9), LEF + other DMARD (58.7/1000 PY, 95%CI, 52.0-66.2), DMARD + MTX (69.5/1000 PY, 95%CI, 65.0-74.3; P = 0.002) | Overall (rate per 1000 PY adjusted for age, sex, and comorbidities): D1: 94.1 D2: 145.0 D3: 143.7 D4: 42.8 Hepatotoxicity (adjusted rate per 1000 PY): D1: 4.1 D2: 6.9 D3: 4.2 D4: 4.6 | Overall Attrition Rate, %: NR ITT Analysis: NA Quality Rating: Fair
Author, yr: Chakravarty, 2005 Country, Setting: US, multicenter Funding: Bristol-Myers-Squibb Research Objective: Rates of NMSC (non-melanoma skin camcer) in a large cohort of pts with RA or OA and to evaluate the role of immunosuppressi ve medications on the development of NMSC Study Design: Retrospective cohort study Overall N: 15,789 (RA); 3,639 (OA) Study Duration: NR | Inclusion Criteria: • Participants in National Data Bank for Rheumatic Diseases (NDB) • Recruited from 908 US rheumatologists; pts who returned at least 2 questionnaires between January 1999 and January 2003 Exclusion Criteria: NR | Interventions, dose: D1: pts with RA D2: pts with OA PRE MTX LEF TNF inhibitors N: D1: 15789 D2: 3639 Mean age, yrs: D1: 62 D2: 67 Sex, % female: D1: 77 D2: 83 Race, % white: D1: 91 D2: 94 | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA ( 3 yrs): NR Baseline DAS, mean: NR Skin cancer before NDB: D1: 3.8 D2: 5.8 History of smoking: D1: 56 D2: 46 | A total of 738 pts with RA reported new cases of NMSC during followup within the NDB; crude incidence rate = 18.1/1000 PY (95% CI, 16.8-19.4/1000 PY) After excluding prevalent cases of NMSC, incidence rate was 15.2/1000 PY (95% CI, 14.1-16.5) Based on multivariate Cox proportional hazard analysis restricted to pts with RA Use of PNL was associated with an increased hazard ratio (HR) (HR = 1.28, P = 0.014) for development of NMSC No association found with use of LEF or MTX alone Use of any anti-TNF (ETA, INF, and ADA) alone showed a slightly increased risk An approximately 2-fold HR for development of NMSC was found among pts with RA using both MTX and any TNF inhibitor (HR 1.97, P = 0.001) | NA | Overall Attrition Rate, %: After initial assessment, ~ 8% of pts decline to participate each yr ITT Analysis: NA Quality Rating: Fair
Author, yr: Chung, 2003 Country, Setting: US, University clinics (32 centers) Funding: Centocor Research Objective: To assess effectiveness and safety of INF in pts with moderate to severe congestive heart failure Study Design: RCT Overall N: 150 Study Duration: 28 wks | Inclusion Criteria: • Age: 18+ • Stable New York Heart Association (NYHA) class III or IV heart failure Exclusion Criteria: • Prior txt with txt within 3 mos of INF or other therapeutic agents that could interfere with actions of TNF (eg, ETA, pentoxifylline, thalidomide, or D2E7) • History of TB: had latent TB or had had TB within 3 yrs • NSAID other than aspirin; experienced a serious infection within 2 mos • Documented HIV infection | Interventions, dose: D1: placebo D2: INF 5mg/kg D3: INF 10mg/kg N: D1: 49 D2: 50 D3: 51 Mean age, yrs: D1: 60 D2: 62 D3: 62 Sex, % female: D1: 24 D2: 14 D3: 16 Race, % white: D1: 88 D2: 88 D3: 84 | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA ( 3 yrs): NR Baseline DAS, mean: NR | 10 mg/kg INF group were more likely to die or be hospitalized for heart failure than placebo (hazard ratio 2.84, 95% confidence interval 1.01 to 7.97; nominal P = 0.043 using log-rank test);Pts in the 10 mg/kg INF group were more likely to be hospitalized for heart failure or for any reason than pts in the placebo or 5 mg/kg INF groups | Overall: D1: 83.3 D2: 92.2 D3: 84 SAEs: D1: 29.2 D2: 23.5 D3: 44 Serious Infections: D1: 2.1 D2: 5.9 D3: 8 Dizziness: D1: 4.2 D2: 31.4 D3: 20 | Overall Attrition Rate, %: NR ITT Analysis: Yes Quality Rating: Fair
Author, yr: De Bandt et al., 2005 Country, Setting: France, clinical reports Funding: NR Research Objective: To report cases and incidence of anti-TNF-induced SLE from a French national survey Study Design: Case series Overall N: 10,700 (22 cases) Study Duration: varied | Inclusion Criteria: • Pts in France given INF or ETA; cases of SLE-like illness during anti-TNF txt were sought; retrospective survey of French rheumatologists and internists between June and October 2003 • All French hospital centres prescribing anti-TNF txts (ETA and INF at that time) were surveyed Exclusion Criteria: • Improper diagnosis of lupus | Interventions, dose: D1: Limited skin lupus D2: Complete lupus ETA: varied INF: varied N: D1: 10 D2: 12 Mean age, yrs: D1: of RA onset 39 D2: 36 Sex, % female: NR Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR INF/ETA: D1: 6/4 D2: 9/3 | Incidence 15/7700 = 0.19% with INF and 7/3800 = 0.18% with ETA 32 initially reported, 10 were ruled out leaving 22 cases 10 pts only had anti-DNA antibodies and skin manifestations 1 could classify as 'limited skin lupus' or 'toxidermia' in a context of autoimmunity, and 12 pts had more complete drug-induced lupus with systemic manifestations | NA | Overall Attrition Rate, %: NA ITT Analysis: NA Quality Rating: Fair
Author, yr: Dixon et al., 2006 Country, Setting: Britain Multicenter Funding: Schering Plouogh, Wyeth, Abbott, and Amgen all fund The British Society for Rheumatology Biologics Register (BSRBR) Research Objective: The rate of serious infection anti-TNF-pts compared with RA pts treated with traditional DMARDs Study Design: Prospective cohort study Overall N: 8,973 Study Duration: 11,220 PY | Inclusion Criteria: • ANTI-TNF cohort: diagnosed by physician w/RA • Treated with ETA, INF, or ADA as first anti-TNF drug, at least 6 mos of followup by September 2005 • Comparison cohort: physician diagnosis of RA, active disease (guideline DAS28 >4.2), current txt with a DMARD, and no previous use of biologic drugs. • Comparison pts also completed at least 6 mos of followup by September 2005. Exclusion Criteria: • Anti-TNF cohort: pts who had been registered >6 mos after start of biologic therapy | Interventions, dose: D1: DMARD D2: All anti-TNF D3: ETA D4: INF D5: ADA N: D1: 1354 D2: 7664 D3: 3596 D4: 2878 D5: 1190 Mean age, yrs: D1: 60 D2: 56 D3: 56 D4: 56 D5: 57 Sex, % female: D1: 71 D2: 76 D3: 77 D4: 76 D5: 74 Race, % white: NR | Median disease duration, yrs: D1: 6 D2: 12 D3: 12 D4: 12 D5: 11 TJC (median): D1: 6 D2: 16 D3: 16 D4: 16 D5: 15 SJC (median): D1: 5 D2: 11 D3: 11 D4: 12 D5: 12 DMARD use, %: NR Corticosteroid use, %: D1: 22 D2: 47 D3: 47 D4: 48 D5: 44 MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS mean: D1: 5.1 D2: 6.6 D3: 6.6 D4: 6.6 D5: 6.6 Diabetes %: D1: 5.5 D2: 5.4 D3: 6.0 D4: 4.6 D5: 5.5 COPD/asthma %: D1: 20 D2: 13 D3: 14 D4: 12 D5: 13 | :In pts with active RA, anti-TNF therapy was not associated with increased risk of overall serious infection compared with DMARD txt, after adjustment for baseline risk. In contrast, the rate of serious skin and soft tissue infections was increased, suggesting an important physiologic role of TNF in host defense in the skin and soft tissues beyond that in other tissues | Serious Infections: • D1: N:56 (41 events/1000 PY) • D2: N:525 (53 events/1000 PY) UTI: • D1: N:3 (2.2 events/1000 PY) • D2: N:45 (4.6 events/1000 PY) | Overall Attrition Rate, %: NA ITT Analysis: NA: Quality Rating: Fair
Author, yr: Breedveld et al., 2006 PREMIER study Country, Setting: Multinational (Europe, North America, Australia), multicenter (133) Funding: Abbott Laboratories Research Objective: To compare efficacy and safety of ADA + MTX vs. MTX or ADA in pts with early, aggressive RA (RA) who had not previously received MTX txt Study Design: RCT Overall N: 799 Study Duration: 2 yrs | Inclusion Criteria: • Age: 18+ • Diagnosed with RA according to ACR criteria • Duration of condition: 3 yrs or less • MTX naive pts • > 8 swollen joints, > 10 tender joints, and an erythrocyte sedimentation rate of > 28 • Folic acid only other med allowed Exclusion Criteria: • Prior txt with: MTX, cyclophosphamide, cyclosporine, azathioprine | Interventions, dose: D1: MTX (20 mg/wk) D2: ADA (40 mg/biwkly) D3: ADA (40 mg/biwkly) + MTX (20 mg/wk) N: D1: 257 D2: 274 D3: 268 Mean age, yrs: D1: 52 D2: 52.1 D3: 51.9 Sex, % female: D1: 73.9 D2: 77.4 D3: 72 Race, % white: NR | Mean disease duration, yrs: D1: .8 D2: .7 D3: .7 TJC, mean: D1: 32.3 D2: 31.8 D3: 30.7 SJC, mean: D1: 22.1 D2: 21.8 D3: 21.1 DMARD use, %: NR Corticosteroid use, % D1: 35.4 D2: 36.5 D3: 35.8 MTX naive, %: NR Txt resistant, %: NR Pts with Early RA ( 3 yrs): NR Baseline DAS, mean: D1: 6.3 D2: 6.4 D3: 6.3 HAQ: D1: 1.5 D2: 1.6 D3: 1.5 Erosion score: D1: 13.6 D2: 11.3 D3: 11.0 | At 6 months Radiographic progression; change in Sharp scores: D1: 3.5 D2: 2.1 (P < 0.001) At 1 yr Radiographic progression; change in Sharp scores: D1: 5.7 D2: 3.0 (P < 0.001) HAQ DI improvement, mean units +/-sd: D1:-0.8 +/-0.7 D2:-0.8 +/-0.6 D3:-1.1 +/-0.6 D2 vs. D1, P = NR D3 vs. D1: P < 0.001 D3 vs. D2: P = 0.002) At 2 yrs ACR50 response, %: D1: 43 D2: 37 D3: 59 D3 vs. D2 or D1: P < 0.001 D1 vs. D2: P= NS Clinical remission, %: D1: 25 D2: 25 D3: 49 (both P < 0.001) Radiographic progression; change in Sharp scores: D1: 10.4 D2: 5.5 (P < 0.001) Withdrawal because of lack of efficacy, %: D1: 18 D2: 19 D3: 4.9 HAQ DI improvement, mean units +/-sd: D1:-0.9 +/-0.6 D2:-0.9 +/-0.7 D3:-1.0 +/-0.7 D2 vs. D1, P = NR D3 vs. D1; P < 0.05 D3 vs. D2; P = 0.058 % with HAQ DI score of zero: D1: 19 D2: 19 D3: 33 D3 vs. D2, P < 0.001 D3 vs. D1: P < 0.001 % with HAQ DI improvement of ≥ 0.22 units from baseline: D1: 63 D2: 58 D3: 72 D3 vs. D2, P < 0.05 D3 vs. D1: P < 0.05 | SAEs: D1: 18.5 D2: 21.1 D3: 15.9 Infections: D1: 123 D2: 110 D3: 119 Serious Infections: D1: 2.9 D2: 0.7 D3: 1.6 Malignancies: D1: 0.4 D2: 0.9 D3: 0.9 Withdrawal because of adverse events: D1: 7% D2: 10% D3: 12% | Overall Attrition Rate, %: 32% ITT Analysis: Yes Quality Rating: Fair
Author, yr: Capell, 2006 Country, Setting: Scotland, 8 NHS sites Funding: Wyeth and Pharmacia-drugs Arthritis Research Campaign Research Objective: If a combination of SSZ and MTX is superior to either alone in RA pts with supoptimal response to 6 mos of SSZ Study Design: RCT Overall N: 165 Study Duration: Phase I: 6 mos; Phase 2: 12 additional mos for those with DAS > 2.4 after 6 mos | Inclusion Criteria: • Age: 18 to 80 • Duration of condition: < 10 yrs • Active disease defined by DAS > 2.4 after 6 mos SSZ txt were eligble for phase II • NSAIDs and other medications were continued • Intra-articular or intramuscular corticosteroid was permitted but not within 1 mo of 6, 12, & 18 mo assessments Exclusion Criteria: • Pregnant or lactating • Prior txt with: MTX or SSZ • Impaired renal or hepatic system: creatinine > 150 mmol/dl, ALT, aspertate aminotransferase > 80 IU/l, alkaline phosphatase > 700 IU/l, gamma GT x3 • Other: abnormal white cell count (< 4 x 10*9/l) • Pre-existing pulmonary fibrosis • Use of oral steroids > 7.5 mg/d • Known SSZ allergies | Interventions, dose: D1: SSZ + MTX D2: SSZ + placebo D3: MTX + placebo Phase I MTX: 7.5 mg/w (3 x 2.5 mg) increasing by 2.5 mg/mo until max of 25 mg or toxicity SSZ: enteric coated 500 mg/d increased by 500 mg/wkly until 40 mg/kg per d to a max of 4g/d for initial 6 mos Placebo: Folic Acid 5 mg/wk given 3 days after MTX and MTX + placebo N: D1: 56 D2: 55 D3: 54 Overall: 687 Mean age, yrs: D1: 56 D2: 55 D3: 53 Overall: 55 Sex, % female: D1: 75 D2: 75 D3: 79 Overall: 77 Race, % white: NR | Mean disease duration, yrs: D1: 1.9 D2: 1.6 D3: 1.8 TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, % NR MTX naive, %: All Txt resistant, %: All Pts with Early RA ( 3 yrs): NR Baseline DAS, mean: D1: 3.63 D2: 3.67 D3: 3.5 Sharp: D1: 17.0 D2: 14.0 D3: 12.0 | Median change 18 mos: DAS: D1:-0.67 D2:-0.30 D3:-0.26 (D1 vs. D2; P = 0.039) (D1 vs. D3; P = 0.023) (D2 vs. D3; P = 0.79) HAQ: D1:-0.50 D2:-0.25 D3:-2.00 (D1 vs. D2; P = 0.51) (D1 vs. D3; P = 0.57) (D2 vs. D3; P = 0.99) SJC: D1:-3.00 D2:-3.00 D3:-2.00 (D1 vs. D2; P = 0.94) (D1 vs. D3; P = 0.81) (D2 vs. D3; P = 0.74) ACR20, % : D1: 29 D2: 18 (OR 1.25 (95% CI, 0.56-2.79) ; P = 0.68) D3: 15 (OR 2.01 (95% CI, 0.85-4.76), P = 0.14) ACR50, %: D1: 11 D2: 6 (OR 1.43 (95% CI, 0.43-4.81), P = 0.76) D3: 7 (OR 1.79 (95% CI, 0.49-6.49), P = 0.53) ACR70, %: D1: 4 D2: 2 (OR 1.50 (95% CI, 0.24-9.34), P = 1.00) D3: 2 (OR 3.00 (95% CI, 0.30-29.78), P = 0.62) | NR | Overall Attrition Rate, %: 28.5 • 687 pts entered phase I (6 mos) • At 6 mos, 165 were not eliglbe to enter phase II (discontinued SSZ because of side effects: 19%, did not attend: 3.6%, died: 0.4%) • Another 191 were not randomized because DAS score was < 2.4 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Combe et al., 2006 Country, Setting: Europe, multicenter Funding: Wyeth Research Objective: To compare efficacy and safety of ETA and SSZ, alone and in combination, in pts with active RA despite SSZ txt Study Design: RCT Overall N: 260 Study Duration: 24 wks | Inclusion Criteria: • Age > 18 • Diagnosed according to ACR criteria; • Functional class of: I-III • Previous use of DMARDs: 2 to 3g SSZ/d for 4, w/o toxicity • Duration of condition < 20 yrs • Stable doses of oral corticosteroids (10 mg/d of PRE or equivalent), one NSAID, simple analgesics with no anti-inflammatory action or daily doses of aspirin (300 mg) Exclusion Criteria: • Prior txt with: (1) ETA or other TNF antagonists or (2) received a DMARD other than SSZ within 3 mos. Or any biologic or cyclophosphamide within 6 mos, corticosteroids within 4 wks • Presence of relevant comorbidity, including active infections | Interventions, dose: D1: SSZ (2,2.5, or 3 g/d) + placebo D2: ETA (25 mg SC twice wkly) + placebo D3: ETA (25 mg SC twice wkly) + SSZ (2,2.5, or 3 g/d) N: D1: 50 D2: 103 D3: 101 Overall: 254 Mean age, yrs: D1: 53.3 D2: 51.3 D3: 50.6 Overall: 51.4 Sex, % female: D1: 82.0 D2: 78.6 D3: 80.2 Overall: 79.9 Race, % white: NR | Mean disease duration, yrs: D1: 5.6 (sd 4.4) D2: 7.1 (sd 5.2) D3: 6.5 (sd 5.1) TJC, mean: D1: 14.0 D2: 14.7 D3: 14.1 SJC, mean: D1: 11.1 D2: 10.1 D3: 10.4 DMARD use, %: D1: 58.0 D2: 69.9 D3: 58.4 Corticosteroid use, % D1: 40.0 D2: 59.2 D3: 44.6 MTX naive, %: NR Txt resistant, %: NR Pts with Early RA ( 3 yrs): NR Baseline DAS, mean: D1: 5.0 D2: 5.1 D3: 5.2 | At 24 weeks ACR20, %: D1: 28.0 D2: 73.8 D3: 74.0 (P < 0.01) ACR50, %: D1: 14.0 D2: 46.6 D3: 52.0 (P < 0.01) ACR70, %: D1: 2.0 D2: 21.4 D3: 25.0 (P < 0.01) In groups receiving ETA, significant differences in ACR core components were observed by wk 2 compared with those receiving SSZ alone (P < 0.01) DAS improvement, %: D1: 19.6 D2: 48.2 D3: 49.7 (P < 0.01) Mean HAQ improvement, %: D1: 9.2 D2: 35.3 D3: 40.2 (P < 0.01) Mean % improvement EuroQOL VAS D2: 64.6 D3: 67.6 (P = NS, NR) No meaningful clinical advantage to use of ETA in combination with SSZ | Infections: D1: 13 D2: 47 D3: 31 Infusion or injection reaction: D1: 3 D2: 38 D3: 21 Abdominal Pain: D1: 0 D2: 7 D3: 8 Headache: D1: 4 D2: 5 D3: 15 Nausea: D1: 3 D2: 3 D3: 12 URTI: D1: 5 D2: 10 D3: 11 | Overall Attrition Rate, %: 13 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Doran et al., 2002 Country, Setting: US, Minnessota cohort Funding: Immunnex; NIH Research Objective: Identify predictors of serious infections amnong pts with RA Study Design: Retrospective Cohort Overall N: 609 Study Duration: 39 yrs | Inclusion Criteria: • Diagnosed with RA according to ACR criteria Exclusion Criteria: • NR | Interventions, dose: DMARDS N: NR Mean age, yrs: NR Sex, % female: NR Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR | • Age, /10-yr increment OR 1.49 95% CI, 1.33–1.67 P < 0.001 • Alcoholism OR 2.00 95%CI, 1.27–3.16 P = 0.003 • Leukopenia OR 2.17 95%CI, 1.58–2.98 P < 0.001 • Organic brain disease OR 2.94 95%CI, 2.08–4.16 P < 0.001 • DM OR 2.45 95%CI, 1.84–3.27 P < 0.001 • Chronic lung disease OR 2.83 95%CI, 2.15–3.72 P < 0.001 • Extraarticular RA OR 3.22 95%CI, 2.17–4.77 P < 0.001 • RF OR 1.65 95%CI, 1.24–2.20 P < 0.001 • RA nodules OR 1.76 95%CI, 1.32–2.33 P < 0.001 • Functional capacity OR 1.87 95%CI, 1.49–2.35 P < 0.001 • ESR OR 1.63 95%CI, 1.25–2.13 P < 0.001 • Chemo OR 5.02 95%CI, 2.44–10.3 P < 0.001 • Cyclophosphamide OR 6.14 95%CI, 3.12–11.8 P < 0.001 • Cyclosporine OR 1.99 95%CI, 1.25–3.16 p = 0.004 • Corticosteroids OR 1.90 95%CI, 1.47–2.47 P < 0.001 | NA | Overall Attrition Rate, %: NR ITT Analysis: NA Quality Rating: Fair
Author, yr: Dougados et al., 1999 and Maillefert et al., 2003 Country, Setting: Finland, France, Germany (France only for 5 yr), multicenter Funding: Pharmacia Upjohn Research Objective: Clinical benefit of MTX + SSZ compared to either drug alone early, active RA pts fulfilling some criteria of poor potential long term outcome Study Design: RCT Overall N: 209 (146) Study Duration: 52 wks (5 yrs) | Inclusion Criteria: • Diagnosed according to ACR criteria • Duration < 1 yr • Presence of active disease as defined by DAS ≥ 3 (calculation based on Ritchie articular index, 44 SJC, and ESR) and presence of RF and/or HLA DR 1/4 • Concommitant drugs allowed were analgesics and NSAIDS Exclusion Criteria: • Prior txt with steroids, DMARDS, or any drugs to treat RA other than analgesic or NSAIDS • Pts with contraindications to use of SSZ or MTX | Interventions, dose: D1: SSZ + placebo D2: MTX + placebo D3: SSZ + MTX MTX: 7.5 mg wkly (2.5 mg 3 times per wk). After wk 16, could be increased to 15 mg wkly if efficacy inadequate SSZ: increased to 2 grams daily by d #9. Could be increased to 3 grams daily after wk 16 of study if efficacy was inadequate Other?: combo MTX + SSZ N: D1: 68 D2: 69 D3: 68 Mean age, yrs: D1: 52 D2: 50 D3: 52 Sex, % female: D1: 71 D2: 74 D3: 77 Race, % white: NR | Mean disease duration, yrs: D1: 2.9 mos since diagnosis, 10.8 since onset D2: 2.3 mos from diagnosis, 18.4 from onset D3: 3.4 mos from diagnosis, 10.6 from onset TJC, mean: NR SJC, mean: D1: 10.5 D2: 9.4 D3: 9.4 DMARD use, %: All groups: 0 Corticosteroid use, % All groups: 0 MTX naive, %: All groups: 100 Txt resistant, %: NR Pts with Early RA (≤3 yrs): All groups: 100 Baseline DAS, mean: D1: 4.23 D2: 4.13 D3: 4.24 RF positive, %: D1: 75 D2: 62 D3: 71 RAI: D1: 17.6 D2: 16.5 D3: 18.9 | DAS change: D1: −1.15 D2: −0.87 D3: −1.26 (P = 0.019 from inter-group comparisons using analysis of variance) RAI changes: D1: −7.1 D2: −4.2 D3: −9.4 (P = 0.001) ACR response, %: D1: 59 D2: 59 D3: 65 (P = NR) At 5 years Txt of pts with early RA with combination therapy of MTX and SSZ during first yr did not result in any long term differences in disease activity, quality of life, or structural damage compared to monotherapy with either drug used alone Mean DAS: D1: 2.2 (sd 1) D2: 2.2 (sd 1) D3: 2.2 (sd 1)(P = 0.9) HAQ: D1: 0.6 (0.7) D2: 0.6 (0.7) D3: 0.6 (0.6) (P = 0.9) Median radiologic score D2: 7.5 D3: 8.5: (P = 0.7)D3: 2.2 (sd 1.1)(P = 0.9) HAQ: D1: 0.6 (0.7) D2: 0.6 (0.7) D3: 0.6 (0.6) (P = 0.9) Median radiologic score D2: 7.5 D3: 8.5 (P = 0.7) Similar results with 3 groups (D3 vs. D2 vs. D1) instead of 2 groups (D3 vs. D2 or D1) when compared, but data not shown Attrition rate: 21% | Overall: D1: 75 D2: 75 D3: 91 Abdominal Pain: D1: 9 D2: 6 D3: 13 Dizziness: D1: 6 D2: 1 D3: 3 Headache: D1: 9 D2: 4 D3: 12 Nausea: D1: 32 D2: 23 D3: 49 | Overall Attrition Rate, %: 27% (28.8) ITT Analysis: Yes Quality Rating: Fair
Author, yr: Edwards, 2004 Country, Setting: Multinational, multicenter (26 rheumatology centers) Funding: Roche Research Objective: To confirm role of B cells in RA by evaluating effect of RIT in pts with active RA according to ACR and EULAR criteria Study Design: RCT Overall N: 161 Study Duration: 24 wks | Inclusion Criteria: • Age ≥ 21 • Diagnosed according to 1987 ACR criteria • Failed previous MTX treatment • > MTX 10 mg/wk and active disease • RF-positive • NSAIDS at stable doses or Css at doses < 12.5 mg per d of PNL • All received 17-d txt with Css and a 10 mg dose of leucovorin Exclusion Criteria: • Autoimmune disorder other than RA (except Srjogen’s) • Functional class IV • Active rheumatoid vasculitis • Systemic diseases associated with arthritis • CFS • Serious, uncontrolled diseases • Active infection • History of recurrent infection or recurrent bacterial infections with encapsulated organisms • Primary of secondary immunodeficiency • History of cancer | Interventions, dose: D1: MTX (≥10 mg/wk) D2: RIT (1000 mg on ds 1 and 15) D3: RIT (1000 mg on ds 1 and 15) + CYP (750 mg d 3, 17) D4: RIT (1000 mg on ds 1 and 15) + MTX (≥10 mg/wk) N: D1: 40 D2: 40 D3: 41 D4: 40 Mean age, yrs: D1: 54 D2: 54 D3: 53 D4: 54 Sex, % female: D1: 80 D2: 73 D3: 83 D4: 75 Race, % white: NR | Mean disease duration, yrs: D1: 11 D2: 9 D3: 10 D4: 12 TJC, mean: D1: 32 D2: 34 D3: 33 D4: 32 SJC, mean: D1: 19 D2: 21 D3: 19 D4: 23 DMARD use (#): D1: 2.6+/− 1.3 D2: 2.5+/−1.6 D3: 2.6+/−1.4 D4: 2.5+/−1.4 Corticosteroid use, % NR MTX naive, %: 0 Txt resistant, %: 100 Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 6.9 D2: 6.8 D3: 6.9 D4: 6.8 | At 24 weeks ACR20, %: D2: 65 D4: 73 (P = NR) ACR50, %: D2: 33 D4: 43 (P = NR) ACR70, %: D2: 15 D4: 23 (P = NR) Rates of moderate or good EULAR responses, %: D2: 85 D4: 83 (P = NR) DAS: D2: −2.2 D4: −2.6 At 48 weeks ACR20, %: D2: 33 D4: 65 (P = NR) ACR50, %: D2: 15 D4: 35 (P = NR) ACR70, %: D2: 10% D4: 15% (P = NR) | Overall: D1: 80 D2: 80 D3: 73 D4: 85 SAEs: D1: 8.0 D2: 5.0 D3: 4.9 D4: 8.0 Infusion or injection reaction: D1: 30 D2: 45 D3: 32 D4: 33 Nausea: D1: 3 D2: 5 D3: 10 D4: 0 URTI: D1: 15 D2: 10 D3: 5 D4: 10 | Overall Attrition Rate, %: at 24 wks 6.2% at 48 wks 37.8% ITT Analysis: Yes Quality Rating: Fair
Author, yr: Emery, 2000 Country, Setting: Multinational, 117 centers Funding: NR Research Objective: To compare both short and long-term (up to 2 yr) clinical efficacy and safety of LEF and MTX for txt of RA Study Design: RCT Overall N: 999 Study Duration: 1 yr, optional second yr | Inclusion Criteria: • Age: 18+ • Diagnosed with RA according to ACR criteria: Active Disease • Previous use of DMARDs: only if discontinued 28 ds before trial • Duration of condition: for at least 4 mos, but no longer than 10 yrs • NSAIDs and steroids were allowed provided a stable dose of NSAIDs or steroid (≤ 10 mg/d) PNL for at least 28 ds prior to study entry • Women of childbearing age were required to use adequate contraception Exclusion Criteria: • Pregnant or lactating • Prior txt with: Intra-articular corticosteriod injections w/in 6 wks of efficacy assessment | Interventions, dose: D1: LEF Yr 1 D2: MTX Yr 1 D3: LEF Yr 2 D4: MTX Yr 2 MTX: 7.5 to 15 mg/wk LEF: loading dose of 100 mg/d for 3 ds, followed by maintenance dose 20/mg/d N: D1: 501 D2: 498 D3: 292 D4: 320 Mean age, yrs: D1: 58.3 D2: 57.8 D3: 57.7 D4: 57.0 Sex, % female: D1: 70.7 D2: 71.3 D3: 71.2 D4: 71.3 Race, % white: NR | Mean disease duration, yrs: D1: 3.7 D2: 3.8 D3: 3.5 D4: 3.8 TJC, mean: NR SJC, mean: NR DMARD use, %: D1: 66.3 D2: 66.9 D3: 64.7 D4: 66.9 Corticosteroid use, % D1: 36.3 D2: 33.5 D3: 14.0 D4: 11.3 MTX naive, %: NR DMARD Txt resistant, %: D1: 1.1 D2: 1.1 D3: 1.0 D4: 1.1 Pts with Early RA (≤ 3 yrs): NR Baseline DAS, mean: NR NSAIDS, %: D1: 80 D2: 84.7 D3: 37.3 D4: 42.5 Larsen score: D1: 1.25 D2: 1.29 D3: 1.27 D4: 1.31 | At year 1 ACR20: D1: 50.5% D2: 64.8% (P < 0.001) HAQ improvement: Minimal quantitative difference between groups, but statistically significant (shown in figure only; P < 0.05) Radiograph change, Larsen Scores: D1 and D2: 0.03 increase (P =NS, NR) Primary clinical efficacy endpoints: TJC: D1: −8.3 D2: − 9.7 SJC: D1: −6.8 D2: −9.0 Physician global assessment: D1: −0.9 D2: −1.2 Pt global assessment: D1: −0.9 D2: −1.2 At year 2 ACR20, %: D1: 64.3 D2: 71.7 (P = NS, NR) HAQ improvement: difference between groups in change from baseline HAQ, NS Radiograph change, Larsen Scores: No further increase in joint damage in pts txted with LEF and small improvement in MTX pts; small net result, but statistically significant difference with MTX better than LEF (overall scores and significance NR) | SAEs: D1: 7% D2: 8% Headache: D1: 6.2 D2: 4.8 Hepatotoxicity: D1: 5.4 D2: 16.3 D3: 2.7 D4: 5.9 Nausea: D1: 11.2 D2: 15.7 URTI: D1: 5.2 D2: 5.0 D3: 4.5 D4: 5.6 Deaths MTX: 2 | Overall Attrition Rate, %: • 26.3% (263/999) during yr 1 • Combined 2 yrs, attrition 50.3% (502/999) of those initially starting study at baseline • During yr 2, attrition 18.8% (115/612) of those agreeing to continue study for 2nd yr ITT Analysis: Yes Quality Rating: Fair
Author, yr: Feltelius, 2005 Country, Setting: Sweden, Swedish Society of Rheumatology database Funding: Wyeth Research Research Objective: To describe a nationwide system for postmarketing follow up of new antirheumatic drugs; to analyze safety and effectiveness in an ETA-treated cohort Study Design: Case series Overall N: 1, 073 Study Duration: >2 yrs | Inclusion Criteria: • Previous use of DMARDs: previous treatment with > 1 DMARD in addition to MTX • Active RA as evaluated by the attending physician Exclusion Criteria: • NR Interventions: D1: ETA Etanercept: 25mg twice weekly N: D1: 1073 Mean age (yrs): D1: 52 Sex, % female: D1: 76.6 Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: D1: 56.3 Corticosteroid use, %: D1: 95.2 MTX naive, %: NR Treatment resistant %: NR Patients with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 5.9 D1: MTX use: 40.1 | In 294 pts (27%), at least 1 adverse drug reaction (ADR) was reported (421 reports; mean 1.5 report per patient; median 1; rand 1 to 6) 80 ADR reports (19%) were serious and 331 (79%)were non-serious 76 pts (7%) experienced at least one serious event and 114 (11%) had events exclusively classified as nonserious Incidence of adverse events remained constant over time | Overall: D1: 27 (% of pts) Serious AEs: D1: 7 (% of pts) Infections: D1: 22 (% of all AE diagnoses) Serious Infections: D1: 5.4 (% of all AE diagnoses) Infusion or injection reaction: NR Abdominal Pain: NR Cardiovascular Events: D1: 4.8 (% of all AE diagnoses) Dizziness: NR Headache: NR Hepatotoxicity: D1: liver/biliary 0.6% (of all AE diagnoses) Malignancies: NR Nausea: NR URTI: NR UTI: NR | Overall Attrition Rate, %: NA ITT Analysis: Not applicable (Why not?) Quality Rating: Fair
Author, yr: Fleischmann 2003; 1478 and 1081 and 2008 Country, Setting: Multinational, multicenter Funding: Amgen Research Objective: Long term safety of AKA in a large population of pts with RA Study Design: RCT Overall N: 1414 (1399) enrolled (open label 1103) Study Duration: 6 mos (up to 30 mos open label for a total of 3 yrs) | Inclusion Criteria: • Age: 18+ • Diagnosed according to ACR criteria; duration 3+ mos • Stable doses of NSAIDs and Cs for one mo; and stable doses of DMARDs for 2 mos • NSAIDS, Cs, and DMARDs (except TNF inhibitors) Exclusion Criteria: • Pregnant or lactating • Uncontrolled medical condition • Malignancy other than basal cell carcinoma of skin or in situ carcinoma of cervix • Felty’s syndrome • HIV • Leukopenia • Neutropenia • Tthrombocytopenia • Abnormal liver function test result • Hepatitis B or C | Interventions, dose: D1: AKA (100mg/d) D2: placebo N: D1: 1116 D2: 283 Mean age, yrs: D1: 54.6 D2: 55.7 Sex, % female: D1: 74.7 D2: 74.6 Race, % white: D1: 87.8 D2: 90.1 | Mean disease duration, yrs: D1: 10.2 (9.6) D2: 10.7 (9.5) TJC, mean: D1: 22.6 (14.7) D2: 22.6 (14.5) SJC, mean: D1: 18.8 (11.9) D2: 18.3 (11.7) DMARD use excluding MTX, and TNF inhibitors %: D1: 47.7 D2: 47.7 Corticosteroid use, %: D1: 57 D2: 60.8 MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR MTX use: D1: 51.9 D2: 59.4 | • 6 mos-injection site reactions, AKA vs. placebo. (72.6% v. 32.9%) P-value NR • 13.4% AKA withdrew due to AE vs, 9.2% placebo (P = 0.057); overall discontinuation rates (21.6% vs. 18.7%) • Serious infections AKA vs. placebo (2.1% v. 0.4%), may be clinically significant. (P = 0.068) • Comorbid conditions, serious infectious events (2.5% vs. 0.0%; P = NR). • Trend towards increased risk of serious infectious events with AKA in pts with pulmonary comorbidities vs. placebo (3.4% v. 1.6%), P = NS • From 0–3 yrs rates per 100 yrs of patient exposure • ISRs (122.26 events), • Rheumatoid arthritis progression (67.80 events) • URTIs(26.09 events) • Concomitant use of corticosteroids vs. not serious infection (7.13 events/100 PY v 2.87 events/100 PY). pneumonia (1.5 events/100 PY v 0.96 events/100 PY) • Cellulitis (1.2 events/100 PY v 0.21 events/100 PY) | Overall: D1: 92 D2: 92.2 D3: 96 SAEs: D1: 7.7 D2: 7.8 D3: 27 Infections: D1: 41.2 D2: 43.5 Serious Infections: D1: 2.1 D2: 0.4 D3: 8 Infusion or injection reaction: D1: 72.6 D2: 32.9 URTI: D1: 13.3 D2: 18.4 UTI: D1: 4.6 D2: 5.3 Adherence: AKA vs. placebo: 100% adherent with use of study drug: 43.8% vs. 47.8; <70% adherent: 0.8% vs. 1.7%>40% missed no injections and >90% received at least 90% of intended doses | Overall Attrition Rate, %: 21 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Flendrie et al., 2003 Country, Setting: Netherlands. University medical centre (Nijmegen) Funding: Not reported Research Objective: To determine the drug survival during treatment of RA pts with TNF blocking agents Study Design: Retrospective cohort study Overall N: 230 Study Duration: About 6 yrs. (maximum follow up times for 3 groups were 69, 35, and 30 mos) | Inclusion Criteria: • Age: adult • Diagnosed with RA according to ACR criteria1) started treatment with ADA, INF, or ETA prior to January 1 2003 at department of rheumatology of University Medical Centre Nijmegen. 2) pts receiving ADA had been treated in phase 1, 2, and 3 clinical trials. ADA was given in different dosages subcutaneously or intravenously. The pts then entered an open label extension study. 3) INF and ETA pts were treated in daily clinical practice and fulfilled the Dutch criteria for TNF blocking therapy; had moderate to high disease activity, and high dosage MTX and at least one other DMARD had failed Exclusion Criteria: NR | Interventions: D1: ADA D2: INF D3: ETA N: D1: 94 D2: 120 D3: 16 Mean age (yrs): D1: 55.2 D2: 56.4 D3: 50.6 : 55.5 Sex, % female: D1: 63 D2: 72 D3: 63 Race, % white: NR Mean disease duration, yrs: D1: 11.4 D2: 11.9 D3: 10.1 TJC, mean: NR SJC, mean: NR DMARD use, %: D1: previous DMARD use, mean 4.5 D2: 4.1 D3: 3.3 Corticosteroid use, %: D1: 51 D2: 24 D3: 19 MTX naive, %: NR Treatment resistant %: NR Patients with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 6.4 D2: 5.9 D3: 5.8 RF positive: D1: 93% D2: 82% D3: 88% | About 70% of pts were still receiving TNF blocking agents after the first yr. One yr. drug survival percentages (percentage of pts still taking the drug) were 73% for ADA, 66% for INF, and 74% for ETA group. No significant differences between groups | Overall: D1: 12 D2: 30 D3: 7 Serious AEs: NR Infections: D1: 2 D2: 6 D3: 0 Serious Infections: D1: 6.4 D2: 7.2 D3: 0 Infusion or injection reaction: D1: 3 D2: 14 D3: 0 Malignancies: D1: 2 D2: 0 D3: 0 | Overall Attrition Rate, %: 17 ITT Analysis: NA Quality Rating: Fair
Author, yr: Flendrie et al., 2005 Country, Setting: Netherlands, Hospital rheumatology clinic Funding: NR Research Objective: Whether dermatological conditions after TNF-alpha- blocking therapy are a significant and clinically important problem in RA pts receiving TNF- alpha -blocking therapy. Study Design: Prospective cohort study with historic control Overall N: 578 Study Duration: 911PY | Inclusion Criteria: • Previous use of DMARDs: failure or intolerability of at least 2 DMARDS, including MTX, in adequate dosage regimens • Control pts selected from Nijmegen inception cohort • Pts required to meet Dutch guidelines for biological therapies: a moderate to high DAS score (DAS28 > 3.2) • Besides therapy with registrated TNF-alpha- blocking agents -INF, ETA, and ADA -some pts were treated in clinical trials with lenercept Exclusion Criteria: NR | Interventions, dose: D1: TNF-apha blockers D2: Control N: NR Mean age at diagnosis, yrs: D1: 44.5 D2: 54.6 Sex, % female: D1: 69 D2: 62 Race, % white: NR | Median disease duration, yrs: D1: 9.2 D2: 6.2 TJC, mean: NR SJC, mean: NR DMARD use, %: NR PNL at baseline (%)D1: 39 D2: 7 MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 5.9 D2: 3.6 | • Dermatological events recorded in 72/289 (25%) of RA pts receiving TNF- alpha-blocking therapy and in 37 (13%) of control group • OR of TNF-alpha- blocking therapy for dermatological referral was 2.26 (95% CI, 1.46 to 3.50, P < 0.0005) • 128 dermatological events were recorded during follow-up in RA pts on TNF-alpha-blocking therapy (0.14 event per PY) | Overall: D1: 25 D2: 13 Infections (skin): D1: 9.3 | Overall Attrition Rate, %: NR ITT Analysis: NA Quality Rating: Fair
Author, yr: Furst, 2003 STAR Trial Country, Setting: US and Canada, multicenter (69 sites) Funding: Abbott Laboratories, Abbott Park II Research Objective: To evaluate the safety and efficacy of ADA when given with standard anti- rheumatic therapy in pts with active RA not adequately responding to standard therapies Study Design: RCT Overall N: 636 Study Duration: 24 wks | Inclusion Criteria: • Age: 18+ • Diagnosed with RA (ACR criteria) • Continued txt with standard anti- rheumatic therapy which included traditional DMARD, Cs, NSAID, or analgesics Exclusion Criteria: • Prior txt with Anti- CD4 therapy or biologic DMARD • Participated in other trials biolgic DMARD in RA • History of active: inflammatory arthritide other than RA or active listeriosis or mycobacterial infection • Major infection requiring hospitalization • Txt with IV antibiotics within 30 ds • Oral antibiotics within 14 ds • Any uncontrolled medical condition | Interventions, dose: D1: ADA (40mg s.c. eavery other week) D2: placebo N: D1: 318 D2: 318 Mean age, yrs: D1: 55 D2: 55.8 Sex, % female: D1: 79.6 D2: 79.2 Race, % white: D1: 89 D2: 85.8 | Mean disease duration, yrs: D1: 9.3 D2: 11.5 TJC, mean: D1: 27.3 D2: 27.6 SJC, mean: D1: 20.9 D2: 21.3 DMARD use, %: NR Corticosteroid use, %: D1: 50.9 D2: 54.4 MTX naive, %: D1: 20.9 (11) D2: 21.3 (11.2) Txt resistant %: NR Pts with Early RA (≤3 yrs): D1: 50.9 D2: 54.4 Baseline patient DAS (mean): D1: 53.9 D2: 52.9 Baseline physician DAS (mean): D1: 59.9 D2: 59.6 | Health Outcome Measures: • At endpoint, significantly more ADA (28.9%) pts achieved an ACR50 response than placebo pts (11.3%) (P < 0.001) • At endpoint, significantly more ADA (14.8%) pts achieved an ACR70 response than placebo pts (3.5%) (P < 0.001) Intermediate Outcome Measures: • At endpoint, significantly more ADA (52.8%) pts achieved an ACR20 response than placebo pts (34.9%) (P < 0.001) | Overall: D1: 86.5 D2: 82.7 SAEs: D1: 5.3 D2: 6.9 Infections: D1: 52.2 D2: 49.4 Serious Infections: D1: 1.3 D2: 1.9 Rash: D1: 10.7 D2: 6.0 Infusion or injection reaction: D1: 19.5 D2: 11.6 URTI: D1: 19.8 D2: 15.1 UTI: D1: 9.1 D2: 5.7 Back pain: D1: 5.3 D2: 1.6 | Overall Attrition Rate, %: 9.1 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Geborek et al., 2005 Country, Setting: Sweden, rheumatology centers Funding: Österlund and Kock Foundations, King Gustav V, and Reumatiker-förbundet Research Objective: To determine whether TNF blockers increase tumour risk in pts with RA Study Design: Retrospective cohort study Overall N: 1557 Study Duration: Median duration of anti-TNF txt was 1.7 yrs (5,571 PY) | Inclusion Criteria: • ACR criteria were fulfilled by 98% of cohort • Pts with RA treated with ETA or INF from South Swedish Arthritis Txt Group (SSATG), which includes pts from 8 rheumatologic centers • For comparison group, pts with RA not treated with anti-TNF drugs from a community based cohort in Malmo, a city from the SSATG catchment area. • Controls recruited from Malmo University outpatient rheumatology clinic and from 4 rheumatologists in private practice Exclusion Criteria: • Tumor diagnosis prior to study | Interventions, dose: D1: Anti-TNF txt D2: Comparison ETA: varied INF: varied N: D1: 757 D2: 800 Median age, yrs: D1: 56 D2: 64 Sex, % female: D1: 76 D2: 73 Race, % white: NR | Mean disease duration, yrs: D1: 12 D2: 11 TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR % with HAQ quartile > = 3: D1: 61 D2: 41 Median number of previous DMARDS: D1: 3 D2: 1 | Anti-TNF vs. Control: • All tumors: SIR 1.1 (95% CI, 0.6–1.8) vs. 1.4 (95% CI, 1.1–1.8) • Lymphomas: SIR 11.5 (95% CI, 3.7 to 26.9) vs. 1.3 (95% CI, 0.2 to 4.5) • All tumors excluding lymphomas: SIR 0.79 (95% CI, 0.4–1.42) vs. 1.39 (95% CI, 1.08–1.76) • Hazard ratio indicates a higher risk of lymphoma for anti-TNF drugs than for controls (RR: 4.9; 95% CI, 0.9–26.1) | NA | Overall Attrition Rate, %: NA ITT Analysis: NA Quality Rating: Fair
Author, yr: Genovese et al., 2002 Country, Setting: US, NR Funding: Immunex Research Objective: To compare the clinical and radiographic outcomes in pts with RAwho received monotherapy with either ETA or MTX (MTX) for 2 yrs and to assess the safety of this therapy. After 2 yrs all pts received 25 mg of ETA for 3 additional yrs Study Design: Open-label extension of RCT Overall N: 632 (512) Study Duration: 2 yrs | Inclusion Criteria: • Age ≥ 18; duration of condition: no more than 3 yrs • At least 3 bone erosions of hands, wrists, feet • At least 10 swolllen joints • At least 12 tender or painful joints • ESR 28 or higher • CRP more than 2 • Morning stiffness at least 45 minutes Exclusion Criteria: • Prior txt with: MTX | Interventions, dose: D1: MTX (ext) D2: ETA 10mg (ext) D3: ETA 25mg (ext) N: D1: 217(169) D2: 208(166) D3: 207(177) Mean age, yrs: D1: 49(49) D2: 50(50) D3: 51(50) Sex, % female: D1: 75(75) D2: 75(75) D3: 74(74) Race, % white: D1: 88(88) D2: 84(86) D3: 86(86) | Mean disease duration, yrs: D1: 12 mos (12) D2: 11 mos (11) D3: 12 mos (12) TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: D1: 41 (46) D2: 42 (37) D3: 39 (36) MTX naive, %: NR Txt resistant %: NR Patients with Early RA (≤3 yrs): NR Erosion (mean): D1: 7.5 (6.9) D2: 6.1 (5.7) D3: 6.4 (5.7) Sharp (mean): D1: 12.9 (11.3) D2: 11.2 (9.7) D3: 12.4 (10.8) JSN (mean):<br>D1: 5.4 (4.4)<br>D2: 5.0 (4.0)<br>D3: 6.0 (5.1) | • Radiographic mean outcome changes at 2 yrs- • Mean changes in total Sharp score ETA25 1.3 vs. MTX 3.2 P = 0.001 • Erosion score ETA25 0.66 units vs. MTX 1.86 units P = 0.001 • No increase in total Sharp score ETA25 63% vrsus MTX 51% (P = 0.017) • No increase in erosions ETA25 70% vs. MTX 58% (P = 0.012) • Incidence of adverse events remained constant over time | SAEs: D1: (16.1) D2: (21.2) D3: (20.6) Serious Infections: D1: 4.1 (4.9) D2: 2.4 (6.3) D3: 3.4 (8.7) Infusion or injection reaction: D1: 9 D2: 32 D3: 39 Abdominal Pain: D1: 15 D2: 13 D3: 13 Dizziness: D1: 12 D2: 7 D3: 15 Headache: D1: 28 D2: 27 D3: 25 Malignancies: D1: (per p-y 0.003) D2: (per p-y 0.008) D3: (per p-y 0.014) Nausea: D1: 31 D2: 14 D3: 20 | Overall Attrition Rate, %: 34.5% at two yrs and 54.7% at 5 yrs ITT Analysis: Yes Quality Rating: Fair
Author, yr: Gomez-Reino, 2003 Country, Setting: Spain 71 Centers Funding: Agencia Española del Medicamento (Ministerio de Sanidad y Consumo) Research Objective: Long-term safety of INF and ETA, in rheumatic diseases based on a national active-surveillance Study Design: Retrospective cohort study Overall N: 1,540 (1578 txts) Study Duration: Mean 1.1 yrs | Inclusion Criteria: • Pts with rheumatic diseases being treated with biologic response modifiers registered in BIOBADASER Exclusion Criteria: NA | Interventions, dose: D1: INF/ETA ETA: varies INF: varies N: D1: 1540 (1578 txts) Mean age, yrs: D1: 51 Sex, % female: D1: 72 Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR PsA: D1: 5.8 AS: D1: 4.9 | • Background TB incidence in Spain in 2000 was 21/100,000 • 1,893 cases of TB per 100,000 pts in yr 2000 and 1,113 cases per 100,000 pts in yr 2001 in pts treated with TNF • RR of TNF pts compared general population 90.1 (95% CI, 58.8–146.0) in yr 2000 and 53.0 (95% CI, 34.5–89.0) in yr 2001 • Estimated annual incidence of TB among RA pts not exposed to TNF inhibitors was 95/100,000 • RR in RA pts who did not receive TNF of TB (adjusted for age and sex) was 4.13 (95% CI, 2.59–6.83) relative to background rate • RR of TB in INF-treated RA pts vs. RA pts not exposed to this therapy was 19.9 (95% CI, 16.2–24.8) in yr 2000 and 11.7 (95% CI, 9.5–14.6) in yr 2001 • 15 pts with TB were diagnosed as having RA, and 2 additional pts with TB had PsA; all pts with active TB were being treated with INF; 59% were diagnosed with TB within 3 mos of txt initiation | Infections: D1: 7.7 Infusion or injection reaction: D1: 2 (INF) URTI: D1: 9 UTI: D1: 11 | Overall Attrition Rate, %: NA ITT Analysis: NA Quality Rating: Fair
Author, yr: Harley, 2003 Country, Setting: US, Health Plan Data Funding: Centocor Research Objective: To examine txt compliance and dosage administration with MTX, ETC and INF therapy for RA Study Design: Observational-retrospective data analysis Overall N: 2662 Study Duration: 30 mos | Inclusion Criteria: • Commercial or Medicare enrollees Exclusion Criteria: • MTX, ETA or INF within 182 days of index date | Interventions: D1: INF D2: ETA D3: INF N: D1: 141 D2: 853 D3: 1668 Mean age (yrs): D1: 56.3 D2: 47.4 D3: 53.3 Sex, % female: D1: 27 D2: 26.3 D3: 26.9 Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: D1: 34 D2: 41 D3: 37.9 Corticosteroid use, %: NR MTX naive, %: NR Treatment resistant %: NR Patients with Early RA (≤3 yrs): NR Baseline DAS, mean: NR | Compliance with at least 80% of expected dosages: • ETA: 68.4; OR 0.462; 95 CI, 0.290–0736 • MTX: 63.7; OR 0.385; 95 CI, 0.245–0604 • INF: 80.9 • OR =Reference • P < 0.05 Dosage Increases: • MTX: 61.6% • INF: 37.4% • ETA: 7.4% | NR | Overall Attrition Rate, %: NA ITT Analysis: Not applicable Quality Rating: Fair
Author, yr: Genovese, 2004 Country, Setting: US, multicenter, specialty clinic Funding: Amgen, Inc., Thousand Oaks, CA Research Objective: To determine potential for additive or synergistic effects of combination therapy with selective anti-TNF-alpha agent ETA and anti-IL1 agent AKA Study Design: RCT Overall N: 242 Study Duration: 24 wks | Inclusion Criteria: • Age > 18 • RA according to ACR criteria • Duration of condition: > 6 mos • 6+ swollen joints • 9+ tender/painful joints • At least 2 of: morning stiffness lasting 45 or more minutes, serum CRP of > 1.5 mg/dl, or ESR > 28 mm/hr; and, MTX > 16 wks, stable dose of 10–25 mg/wk > 8 wks; continued txt with stable doses of MTX and other stable medications, such as corticosteroids Exclusion Criteria: • Any DMARD other than MTX within past 4 wks • Txt with AKA or any protein-based TNF-alpha inhibitor • Received any intraarticular or systemic corticosteroid injections within past 4 wks • Recent history of significant infection or other important concurrent illness | Interventions, dose: D1: ETA (25 mg twice wkly) D2: ETA (12.5 mg once wkly) + AKA (100 mg/d) D3: ETA (25 mg twice wkly) + AKA (100 mg/d) N: D1: 80 D2: 81 D3: 81 Mean age, yrs: D1: 54.4 D2: 53.8 D3: 55.7 Sex, % female: D1: 82.5 D2: 71.6 D3: 77.8 Race, % white: D1: 86.3 D2: 77.8 D3: 75.3 | Mean disease duration, yrs: D1: 9.7 D2: 9.5 D3: 10.6 TJC, mean: D1: 31 D2: 31 D3: 35.9 SJC, mean: D1: 21.4 D2: 19.8 D3: 23.4 DMARD use, %: NR Corticosteroid use, % D1: 48.8 D2: 54.3 D3: 44.4 MTX naive, %: Overall: 0 Txt resistant, %: Overall: 100 Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR MTX use, %: Overall: 100 HAQ: D1: 1.5 D2: 1.5 D3: 1.6 | At week 24 ACR20, %: D1: 68 D2: 51 D3: 62 D1 vs. D2 (P = 0.037) All others NS ACR50, %: D1: 41 D2: 39 D3: 31(P = 0.914) OR (ETA + AKA vs. ETA alone) 0.64 (90% CI, 0.37–1.09); sensitivity analysis yielded similar results ACR70, %: D1: 21 D2: 24 D3: 14 (P = NR) Sustained ACR20 response: Between 43% and 54% of subjects in each group (specifics NR) EULAR response, %: D1: 79 D2: 66 D3: 73 (P = NR) Mean % reduction in DAS: D1: 39 D2: 41 D3: 40 (P = NR) | Overall: D1: 90 D2: 95.1 D3: 93.8 SAEs: D1: 2.5 D2: 4.9 D3: 14.8 Infections: D1: 40 D2: 37 D3: 46.9 Serious Infections: D1: 0 D2: 3.7 D3: 7.4 Infusion or injection reaction: D1: 40 D2: 67.9 D3: 70.4 URTI: D1: 20 D2: 11.1 D3: 13.6 | Overall Attrition Rate, %: 15.7 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Goekoop-Ruiterman et al., 2005 BeST Study Country, Setting: The Netherlands, 18 peripheral and 2 university hospitals Funding: Schering-Plough BV and Centocor Inc Dutch College of Health Insurances Research Objective: To compare clinical and radiographic outcomes of 4 different txt strategies in pts with early RA Study Design: RCT Overall N: 508 Study Duration: 12 mos | Inclusion Criteria: • Age > 18 yrs • RA according to ACR criteria • Duration of condition < 2 yrs • Active disease with at least 6 of 66 swollen joints • At least 6 of 68 tender joints • ESR > 28 mm/hr OR global health score greater than or equal to 20mm on 0 to 100 VAS • Concomittant NSAIDS and intraarticular steroids Exclusion Criteria: • Pregnant • Prior txt with: DMARDS other than antimalarials • Impaired renal or hepatic system • concomittant txt with an experimental drug • bone marrow hypoplasia • diabetes • alcohol or drug abuse • wish to conceive • inadequate contraception | Interventions, dose: D1: sequential monotherapy D2: step-up combination therapy D3: initial combination with PRE D4: initial combination with INF D5: NR Overall: Totals N: D1: 126 D2: 121 D3: 133 D4: 128 Overall: 508 Mean age, yrs: D1: 54 D2: 54 D3: 55 D4: 54 Overall: 54 Sex, % female: D1: 86 D2: 86 D3: 86 D4: 85 Overall: 86 Race, % white: NR | Mean disease duration, yrs: D1: 23 wks D2: 26 wks D3: 23 wks D4: 23 wks TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, % NR MTX naive, %: Overall: 100 Txt resistant, %: NR Pts with Early RA (≤3 yrs): Overall: 100 Baseline DAS, mean: D1: 4.5 +/− 0.9 D2: 4.5 +/− 0.8 D3: 4.4 +/− 0.9 D4: 4.3 +/− 0.9 D-HAQ (0 to 3 scale): D1: 1.4 +/−0.7 D2: 1.4 +/−0.6 D3: 1.4 +/−0.7 D4: 1.4 +/−0.7 | At 12 months Mean D-HAQ scores: D1: 0.7 +/− 0.7 D2: 0.7 +/− 0.6 D3: 0.5 +/− 0.5 D4: 0.5 +/− 0.5 (D1 vs. D3; P< 0.05) (D3 vs. D4; P = NS) All others NR Median total SHS increases (0 to 448 scale) from baseline: D1: 2.0 D2: 2.5 D3: 1.0 D4: 0.5 (D1 vs. D3; P = 0.003) (D1 vs. D4; P< 0.001) (D2 vs. D3; P = 0.007) (D2 vs. D4; P < 0.001) Progression of total SHS, %: D1: 67 D2: 73 D3: 87 D4: 93 (D1 vs. D3 and D4; P = 0.001) (D1 vs. D4; P < 0.001) (D2 vs. D3; P = 0.010) (D2 vs. D4; P < 0.001) Sharp van der Heijde median increase: D1: 2.0 D2: 2.5 D3: 1.0 D4: 0.5 (P < 0.001) Sustain DAS44 2.4, %: D1: 53 D2: 64 D3: 71 D4: 74 (D1 vs. D3; P = 0.004) (D1 vs. D4; P < 0.001) (P = NS and NR for others) Patients who progressed to erosive from nonerosive disease at baseline, % D1: 29 (9/31) D2: 53 (18/34) D3: 38 (14/37) D4: 15 (5/34) D1 vs D2, P = 0.050 D2 vs D4, P = 0.028 D3 vs D4, P =NS, NR | Overall: D1: 43 D2: 47 D3: 37 D4: 39 SAEs: D1: 6.3 D2: 7.4 D3: 12.8 D4: 4.7 Infections: D1: 4 D2: 7 D3: 8 D4: 8 Serious Infections: D1: 2.4 (pneumonia, HSV encephalitis, and fever) D2: 0.8 (diffuse peritonitis) D3: 0.8 (oral HSV) D4: 2.3 (pneumonia, pneumonitis, and septic arthritis) Infusion or injection reaction: D4: (10/128) = 7.8% Cardiovascular Events: D1: 2 (hypertension, TIA, PE) D2: 2 (peripheral bypass, pacemaker implantation) D3: 6 (3 MIs, heart failure D4: 2 (TIA, PE, peripheral vascular disease) Malignancies: D2: N:1 bladder D3: N:2 breast, lymphoma Adherence 24 (5%) non-adherent | Overall Attrition Rate, %: 3.3% (17/508) ITT Analysis: Yes Quality Rating: Good
Author, yr: Haagsma, 1997 Country, Setting: Netherlands, 1 academic and 6 peripheral clinics Funding: Pharmachemie BV; Pharmacia AB Research Objective: Compare efficacy and safety of SSZ, MTX, and combination of both in pts with early RA Study Design: RCT Overall N: 105 Study Duration: 52 wks | Inclusion Criteria: • Age: ≥ 18 • Diagnosed with RA according to ACR criteria: ACR criteria • RF positive and/or HLA-DR4 positive and/or HLA DR1 positive • Functional class of: DAS ≥ 3.0 • Duration of condition:< 12 mos • Analgesica and NSAIDS allowed Exclusion Criteria: • Prior txt with: DMARDS other than analgesics and NSAIDS • Other: contraindications to SSZ or MTX | Interventions, dose: D1: SSZ (1 g/day; max 3 g/day) D2: MTX (7.5 mg/wk; max 15 mg/wk) D3: MTX (7.5 mg/wk; max 15 mg/wk) + SSZ (1 g/day; max 3 g/day) N: D1: 34 D2: 35 D3: 36 Mean age, yrs: D1: 56.8 D2: 54.9 D3: 57.0 Sex, % female: D1: 61.8 D2: 65.7 D3: 66.7 Race, % white: NR | Mean disease duration, yrs: D1: 3.1 mos D2: 3.0 mos D3: 2.6 mos TJC, mean: D1: 20.8 D2: 20.6 D3: 24.8 SJC, mean: D1: 17.0 D2: 19.9 D3: 20.8 DMARD use, %: Overall: 0 Corticosteroid use, % Overall: 0 MTX naive, %: NR Txt resistant, %: NR Pts with Early RA (≤3 yrs): Overall: 100 Baseline DAS, mean: D1: 4.6 D2: 4.7 D3: 5.0 HAQ: D1: 0.97 D2: 0.92 D3: 1.20 | No significant differences in efficacy between combination (MTX, SSZ) and single therapy (MTX or SSZ), only a trend favoring combination therapy, MTX and SSZ were comparable At 52 weeks DAS mean change: D1: −1.6 (95% CI, −2.0 to − 1.2) D2: −1.7 (95% CI, −2.0 to −1.4) D3: −1.9 (95% CI, −2.2 to − 2.3) Ritchie mean change: D1: −8.6 (95% CI, −10.7 to − 6.5) D2: −8.2 (95% CI, −10.1 to − 6.4) D3: −9.4 (95% CI, −11.1 to − 7.7) Swollen joints mean change: D1: SSZ −7.9 (95% CI, −10.1 to −5.7) D2: −10.2 (95% CI, −12.5 to − 8.0) D3: −11.3 (95% CI, −13.5 to − 9.2) HAQ change from baseline: D1: −0.32 (95% CI, −0.53 to − 0.10) D2: −0.46 (95% CI, −0.68 to −0.25) D3: −0.51 (95% CI, −0.76 to − 0.26) Number of pts with a response according to ACR criteria at end of study: D1: 25 D2: 25 D3: 28 Number of pts with good response according to EULAR definition: D1: 14 D2: 15 D3: 14 | Overall: D1: 88.2 D2: 77.1 D3: 88.9 SAEs: D1: 8.8 D2: 0 D3: 0 Abdominal Pain: D1: 26.5 D2: 20 D3: 36 Cardiovascular Events (Dyspnea): D1: 5.9 D2: 0 D3: 5.6 Dizziness: D1: 17.6 D2: 8.6 D3: 27.8 Headache: D1: 17.6 D2: 11.4 D3: 11.1 Nausea: D1: 29.4 D2: 25.7 D3: 63.9 URTI D1: 17.6 D2: 20.0 D3: 27.8 | Overall Attrition Rate, %: 19 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Hyrich et al., 2006 Country, Setting: Great Britain, multiclinic Funding: Schering Plough, Wyeth, Abbott, A mgen British Society for Rheumatology Biologics Register Research Objective: Compare outcome at 6 mos in unselected real-world RA pts treated with ETA or INF alone or with MTX or another DMARD Study Design: Prospective cohort study Overall N: 2711 Study Duration: 6 mos | Inclusion Criteria: • Age > 16 yrs • Diagnosed with RA according to 1987 ACR criteria; starting either ETA or INF as first biologic drug • Other meds were allowed Exclusion Criteria: NR | Interventions, dose: D1: ETA (25 mg 2x wk) D2: ETA + DMARD D3: ETA + MTX D4: INF (3 mg/kg wks 0,2,6 then every 8wks) D5: INF + DMARD D6: INF + MTX Some doses NR N: D1: 763 D2: 245 D3: 250 D4: 128 D5: 121 D6: 1204 Mean age, yrs: D1: 58 D2: 55 D3: 54 D4: 59 D5: 58 D6: 55 Sex, % female: D1: 80 D2: 79 D3: 76 D4: 79 D5: 74 D6: 77 Race, % white: NR | Mean disease duration, yrs: D1: 16 D2: 15 D3: 13 D4: 16 D5: 14 D6: 14 TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, % D1: 54 D2: 51 D3: 44 D4: 69 D5: 59 D6: 48 MTX naive, %: NR Treatment resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean:<br>D1: 6.8 D2: 6.6 D3: 6.6 D4: 6.8 D5: 6.8 D6: 6.7 | At 6 months EULAR response: D3 vs. D1: (OR 1.98, 95% CI, 1.45–2.71) D2 vs. D1 (OR 1.20, 95% CI, 0.89–1.61) D3 vs D2 (OR 1.66, 95% CI, 1.14–2.42) A better EULAR response in both MTX (OR 1.35 [95% CI, 0.92–2.00]) and DMARD (OR 1.26 [95% CI, 0.75–2.13]) subgroups as compared with INF monotherapy DAS28: D1: 4.8 +/−.4 D2: 4.6 +/− 1.5 D3: 4.3 +/− 1.5 D4: 5.0 +/− 1.6 D5: 4.9 +/− 1.6 D6: 4.6 +/− 1.6 | Adherence: Drug survival at 6 mos: ETA 20% INF 21% ETA subgroups (22% mono, 16% MTX co-therapy, 19% DMARD co-therapy) INF subgroups (30% vs. 21% MTX co-therapy, vs. 22% DMARD co-therapy) | Overall Attrition Rate, %: 21 ITT Analysis: N/A Quality; Rating: Good
Author, yr: Klareskog, 2004 with van der Heijde, 2006 TEMPO study Country, Setting: Multinational (Europe), multicenter Funding: Wyeth Research Research Objective: To compare safety and efficacy of combination of ETA and MTX with monotherapies in pts with RA who had failed previous DMARD txt Study Design: RCT Overall N: 686 (2 yr results: 503) Study Duration: 52 wks (2 yrs, 100 wks) | Inclusion Criteria: • Age ≥ 18 • Diagnosed according to ACR criteria • Functional class I–III • Less than satisfactory response to at least 1 DMARD other than MTX • Duration 6 mos to 20 yrs • RA defined as > 10 swollen and > 12 painful joints and at least one of: ESR > 28 mm/h, CRP > 20 mg/L, or morning stiffness for > 45 minutes • Folic acid 5 mg twice per wk • NSAIDs Exclusion Criteria: • TNF antagonist, any immuno-suppressive drugs w/in 6 mos • Any investigational drug or biologic agent w/in 3 mos DMARD or css injection w/in 4 mos • Previous txt with MTX if pt experienced clinically toxic side effects or had no response | Interventions, dose: D1: MTX (20 mg/wk) D2: ETA (25 mg 2x wkly) D3: ETA (25 mg 2x wkly) + MTX (7.5 titrated to 20 mg/wk) N: D1: 228 (152) D2: 223 (163) D3: 231 (188) Overall (at 2yrs): 503 Mean age, yrs: D1: 53 D2: 53.2 D3: 52.5 Overall (at 2yrs): 52.1 Sex, % female: D1: 79 D2: 77 D3: 74 Overall (at 2yrs): 76 Race, % white: D1: 98 D2: 99 D3: 98 Overall (at 2yrs): 99 | Mean disease duration, yrs: D1: 6.8 D2: 6.3 D3: 6.8 TJC, mean: D1: 33.1 D2: 35 D3: 34.2 SJC, mean: D1: 22.6 D2: 23 D3: 22.1 DMARD use, %: NR Corticosteroid use, % D1: 64 D2: 57 D3: 62 MTX naive, %: D1: 58 D2: 58 D3: 56 Txt resistant, %: Overall: 100 Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 5.5 D2: 5.7 D3: 5.5 Sharp: D1: 26.8 D2: 21.8 D3: 21.8 JSN: D1: 13.3 D2: 11.5 D3: 10.3 | At 24 weeks AUC of ACR-N, %-yrs: D1: 12.2 D2: 14.7 D3: 18.3 (P< 0.0001) ACR20, %: D1: 75 D2: 76 D3: 85 (P = 0.0151) ACR50, %: D1: 43 D2: 48 D3: 69 (P< 0.0001) ACR70, %: D1: 19 D2: 24 D3: 43 (P< 0.0001) At 52 weeks DAS< 1.6 remission, %: D1: 13 D2: 16 D3: 35 (D3 vs. D2: P<0.0001; D2 vs. D1: P =0.5031) HAQ, decline: D1: 0.65 D2: 0.7 D3: 1.0 (P< 0.05) D3 therapy significantly more likely to attain HAQ DI similar to population norms (< 0.5) than monotherapy Radiograhic outcomes Total Sharp Score change: D1: 0.28 D2: 0.52 D3: −0.54; D3 vs D2; P = 0.0006 D2 vs D1; P =0.047 Erosion score change: D1: 1.68 D2: 0.21 D3: −0.30; D3 vs D2; P = 0.0001 D2 vs D1; P =0.008 JSN score change: D2: 0.32 D3: −0.23; P = 0.0007 At 2 years Total Sharp score change: D1: 1.12 D2: 1.10 D3: −0.56; P = 0.05 D3 vs D2; P = 0.05 D2 vs D1; P = NR Erosion score change D2: 0.36 D3: −0.76 P < 0.05 JSN score change D2: 0.74 D3: 0.20; P = NS, NR | Overall: D1: 81 (87) D2: 86 (92) D3: 81 (86) Infections: D1: 64 (75) D2: 59 (71) D3: 67 (76) Serious Infections: D1: 4 (7) D2: 4 (6) D3: 4 (6) Infusion or injection reaction: D1: 2 (2) D2: 21 (21) D3: 10 (11) Abdominal Pain: D1: 18 D2: 12 D3: 18 Hypertension: D1: 5 D2: 13 D3: 9 Headache: D1: 14 D2: 15 D3: 15 Nausea: D1: 32 (39) D2: 10 (13) D3: 24 (29) | Overall Attrition Rate, %: 52 wks: 23.5 2 Yrs: 38.4 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Jacobsson et al., 2005 Country, Setting: Sweden, population-based (2 Swedish registers) Funding: NR Research Objective: Risk of cardiovascular disease (CVD) in pts with RA treated with TNF inhibitors, compared to a standard RA population Study Design: Retrospective cohort study Overall N: 983 (combined cohort) Study Duration: NR | Inclusion Criteria: • Age-: 20–79 yrs • Diagnosed according to 1987 ACR criteria • Case cohort • South Swedish Arthritis Txt Group (SSATG): pts with RA treated with anti-TNF agents and included in SSATG register between 2/1/99 and 12/31/01 Exclusion Criteria: • Previous hospital discharge due to CVD | Interventions, dose: D1: Anti-TNF exposed D2: Not Anti-TNF exposed N: D1: 531 D2: 452 Median age, yrs: D1: 55 D2: 61 Sex, % female: D1: 78 D2: 75 Race, % white: NR | Median disease duration, yrs: D1: 12 D2: 11 TJC, mean: NR SJC, mean: NR Median # of previous DMARDs used (IQR): D1: 4 (2–5) D2: 2 (1–4) PNL use, %: D1: 75 D2: 22 MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR Median HAQ: D1: 1.50 D2: 1.13 VAS patient global assessment median: D1: 69 D2: 48 | • Decreased incidence and RR for the development of first-time CVD event when controlling for disease severity in pts with RA treated with TNF blocking therapy • Controlling for disability (HAQ), age-sex adjusted rate ratio was 0.46 (95% CI, 0.25–0.85; P = 0.013) in anti-TNF treated vs. not treated • Anti-TNF group, 13 CVD events (in 656 PY at risk); age-adjusted incidence rate = 14 events/1000 PY • Unexposed comparison group, 85 CVD events (in 2056 PY at risk); age-adjusted incidence rate = 35.4 events/1000 PY • Relative risk = 0.62 (95% CI, 0.34 to 1.12; P = 0.111) • SMR revealed increased risk of new onset CVD in those not treated with TNF blockers in relation to background population of Malmo (SMR = 228, 95% CI, 179 to 277) TNF blockers, risk of new onset CVD was lower, with CIs enclosing unity with background population (SMR = 157, 95% CI, 72–242) | Cardiovascular Events: D1: n =13 (6 MI, 4 cerebrovascular disease, and 3 other) D2: n =85 (33 MIs, 15 cerebrovascular disease, 12 CHF, 2 ruptured aortic aneurysm, and 23 other) | Overall Attrition Rate, %: NA ITT Analysis: NA Quality Rating: Fair
Author, yr: Keane, 2001 Country, Setting: Multinational, NA NA Funding: National Heart, Lung and Blood Institute; Massachusetts Thoracic Society; American Lung Association of Massachusetts Research Objective: To explore relationship between INF and tuberculosis based on data from MedWatch Study Design: Database analysis; AERS Overall N: 70 cases 47 Crohn’s: 18 other: 5 Study Duration: 1–52 wks | Inclusion Criteria: • If during or after txt with INF, patient received diagnosis of TB on basis of clinical, radiologic, and laboratory findings Exclusion Criteria: NR | Interventions, dose: D1: TB pts INF: varies N: D1: 57 Median age, yrs: D1: 57 Sex, % female: D1: 64 Race, % white: D1: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: D1: 20 MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR | • Estimated incidence for pts with RA who have been treated with INF during previous is 24.4 cases per 100.000 per yr (95% CI, 0.6 to 34.0); background incidence in US for pts with RA not exposed to TIM therapy: 6.2 cases per 100,000 per yr • Median interval from start of INF txt until development of TB = 12 wks; 68.6% developed TB after 3 or fewer INF infusions; reported frequency of TB in association with INF was much higher than reported frequency of other opportunistic infections associated with this drug | NR | Overall Attrition Rate, %: NA ITT Analysis: NA Quality Rating: Fair
Author, yr: Kremer, 2002 Country, Setting: US and Canada, multicenter (20 outpatient practice centers) Funding: Aventis Pharmaceuticals Research Objective: To evaluate efficacy and safety of LEF vs. Placebo when added to ongoing stable dose MTX therapy in pts with persistently active RA Study Design: RCT Overall N: 263 Study Duration: 24 wks | Inclusion Criteria: • Age: 18 or 75 • Diagnosed with RA according to ACR criteria: Active:>9 tender joints, >6 sollen joints, >45 mornign stiffness • Previous use of DMARDs: Failed in 11 pts • Other (Please include concomitant drugs that are allowed)? MTX (15–20mg/wk or 10–15mg/wk if max tolerated dose) for at least 6 mos, AND stable dosing for at least 8 wks Exclusion Criteria: • Pregnant or lactating • Prior txt with: prohibited DMARDs in past 30 ds • Impaired renal or hepatic system: Hep B or C, 3 or more elevations of AST or ALT, elevated SrCR • Psoriatic Arthritis or other acute inflammatory joint disease not RA | Interventions, dose: D1: MTX + LEF D2: MTX + Placebo Methotrexate: 15–20 mg/wk or 10–15 mg/wk if toleration problems Leflunomide: 100 mg 2 ds then 10mg/d or 10mg/every other d if adverse effects Placebo: Folate 1 mg/d for ALL N: D1: 130 D2: 133 Mean age, yrs: D1: 55.6 D2: 56.6 Sex, % female: D1: 76.2 D2: 80.5 Race, % white: D1: 90.8 D2: 87.2 | Mean disease duration, yrs: D1: 10.5 D2: 12.7 TJC, mean: D1: 26.9 D2: 26.4 SJC, mean: D1: 17.3 D2: 18.7 DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Patients with Early RA (≤3 yrs): NR Baseline DAS, mean: NR HAQDI: D1: 1.6 D2: 1.5 | ACR20: • LEF 46.2%; Placebo 19.5% P <0.001 HAQ: • LEF −0.42 • Placebo −0.09 P < 0.001 • SF-36: LEf + 6.8 Placebo + 0.3 P < 0.001 | Overall: D1: 89.2 D2: 89.5 Infections: D1: 40.8 D2: 51.9 Dizziness: D1: 7.7 D2: 5.3 Headache: D1: 10 D2: 8.3 Nausea: D1: 16.2 D2: 11.3 URTI: D1: 22.3 D2: 24.1 Adherence: Overall, 98% adherent Mean adherence Adherence: • Rates 80 120% • Lef 87.7% • Placebo 90.2% | Overall Attrition Rate, %: Discontinuation Rates: LEF 23.1 Placebo 24.8% ITT Analysis: Yes Quality Rating: Fair
Author, yr: Kristensen et al., 2006 Country, Setting: Sweden, multicenter Funding: Osterlund and Kock Foundations, 80-yr Fund of King Gustav V, and Reumatikerfor-bundet Research Objective: LUNDEX index to compare long-term efficacy and tolerability of biologic therapies in RA pts treated in clinical practice Study Design: Prospective cohort study Overall N: 949 Study Duration: Varied (results reported for 3 yrs) | Inclusion Criteria: • Unsuccessful txt with 2 DMARDS including MTX • Pts diagnosed with RA according to clinical judgment of treating physician • Treated at 8 centers in Southern Sweden during March 1999 through January 2004 • Meds allowed, NR Exclusion Criteria: • Prior txt with biologic therapy | Interventions, dose: D1: ETA (25 mg s.c. twice wkly) D2: INF (≥3 mg/kg at 0, 2, 6, and 12 wks and then every 8 wks) N: D1: 309 D2: 640 Mean age, yrs: D1: 55.1 D2: 56.2 Sex, % female: D1: 82 D2: 75 Race, % white: NR | Mean disease duration, yrs: D1: 14.7 D2: 12.7 TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, % NR MTX naive, %: NR Txt resistant, %: Overall: 100 Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 5.9 D2: 5.6 MTX use, %: D1: 31 D2:73 HAQ: D1: 1.6 D2: 1.4 | At 3 months D1: 63 D2: 45 (P < 0.001) At 6 months D1: 61 D2: 47 (P = NS) At 12 months LUNDEX values (index of drug efficacy in clinical practice): D1: ~ 55% (~ 4 0% at 3 yrs) D2: ~ 45% (~ 30% at 3 yrs) ACR20, %: D1: 69 D2: 53 (P = 0.001) At 24 months ACR20, %: D1: 65 D2: 56 (P = NS) At 36 months ACR20, %: D1: 63 D2: 61 (P = NS) ACR50, %: D1: 39 D2: 39 (P = NS) ACR 70, %: D1: 16 D2: 18 (P = NS) EULAR (moderate), %: D1: 46 D2: 29 (P = NS) EULAR (good), %: D1: 36 D2: 45 (P = NS) Intermediate Outcome Measures: INF had significantly lower adherence compared to ETA (P < 0.001) | NR | Overall Attrition Rate, %: NR ITT Analysis: N/A Quality Rating: Fair
Author, yr: Kwon, 2003 Country, Setting: USA, Multicenter (FDA’s MedWatch program) Funding: US Food and Drug Administration Research Objective: To describe adverse event reports of heart failure after TNF antagonist therapy Study Design: Database analysis; AERS Overall N: 47 cases Study Duration: long-term therapy | Inclusion Criteria: • Pts who reported heart failure as an adverse event while taking ETA or INF therapy in US since licensure of drugs until February 2002 • New onset failure and exacerbation of preexisting heart failure included Exclusion Criteria: • Heart failure reports temporally associated with other heart failure-inciting events (such as myocardial infarction) were excluded | Interventions, dose: D1: New Onset Heart Failure without risk factors D2: New Onset Heart Failure with risk factors D3: Heart failure exacerbation ETA: any INF: any N: NR Mean age, yrs: D1: 59 D2: 67 D3: 70 Sex, % female: D1: 74 D2: 42 D3: 44 Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: D1: 8 D2: 10 MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR %ETA: D1: 12 D2: 14 D3: 3 %INF: D1: 7 D2: 5 D3: 6 | • 38 pts (81%) developed new-onset heart failure • 9 (19%) experienced heart failure exacerbation of which: 19 pts had no documented risk factors, 10 pts were under age 50 • Of pts under 50, after cessation of TNF antagonist therapy 3 pts experienced complete resolution of heart failure, 6 pts showed improvement, and 1 patient died | NR | Overall Attrition Rate, %: NA ITT Analysis: NA Quality Rating: Fair
Author, yr: Langer, 2003 Country, Setting: Germany, multiple sites, daily clinical practice Funding: Amgen Research Objective: To assess the response rate, time to response, efficacy and safety of anakinra during 52 wks of therapy after launch in daily clinical practice in Germany and to gain knowledge of the routine application of anakinra in RA pts under special conditions (RA pts who failed TNF-blocking drugs) Study Design: Case series; postmarketing surveillance Overall N: 454 Study Duration: 52 wks | Inclusion Criteria: • Age: adult • Patients who fell within approved indication for anakinra • Pts with RA who had been ineffectively treated with at least 2 DMARDs including MTX Exclusion Criteria: NR | Interventions: D1: AKA, all pts D2: AKA, TNF-blocker naive D3: AKA, TNF-blocker pretreated Anakinra N: D1: 166 D2: 105 D3: 61 Mean age (yrs): D1: 53.7 D2: 54.7 D3: 51.9 Sex, % female: D1: 78.9 D2: 78.1 D3: 80.3 Race, % white: NR Mean disease duration, yrs: D1: 12.3 D2: 12.0 D3: 12.8 TJC, mean: D1: 12.8 D2: 12.4 D3: 13.4 SJC, mean: D1: 10.5 D2: 10.4 D3: 10.8 DMARD use, %: D1: on MTX: 66.3 D2: 72.4 D3: 55.7 Corticosteroid use, %: D1: 84.9 D2: 81.9 D3: 90.1 MTX naive, %: NR Treatment resistant %: NR Patients with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 5.8 D2: 5.6 D3: 6.1 D1: morning stiffness (minutes) 112.5 D2: 104.1 D3: 126.6 D1: # of previous DMARDs: 3.6 D2: 3.0 D3: 4.4 | • Pts responded well to AKA therapy; 67.5% had good (21.0%) or moderate (46.5%) EULAR response after 6 mos. of therapy • DAS decreased by 44% for all pts • Tender joint count decreased by 53%, swollen joint count by 49%, pain by 31%, and global health by 28% • Response to AKA was rapid, within 1 mo; shown in figures • Data suggest AKA is effective in pts who have failed anti-TNF therapy with comparable results to anti-TNF naive pts • 69.4% of TNF-blocker pretreated pts had a good or moderate EULAR response at 6 mos. compared to 66.3% of TNF-blocker naive pts • Disease activity decreased by 39% and 47% respectively • Pain decreased by 35% and 29% respectively • Tender joint count by 49% vs. 55% • Swollen joint count 44% vs. 52% • Global health by 33% vs. 26% | See adverse events | Overall: D1: 41.2 Serious AEs: D1: 4.2 Infections: D1: 6.6 Serious Infections: D1: 1.5 Infusion or injection reaction: D1: 20.7 Abdominal Pain: NR Cardiovascular Events: NR Dizziness: NR Headache: D1: 2 Hepatotoxicity: NR Malignancies: NR Nausea: NR URTI: NR UTI: NR | Overall Attrition Rate, %: NR ITT Analysis: NA Quality Rating: Fair
Author, yr: Lebwohl, 2005 Country, Setting: US, clinical trial participants receiving ETA from private and institutional practices Funding: Amgen Inc. Research Objective: Incidence of cutaneous SCC in pts with rheumatoid arthritis receiving ETA for up to 5 yrs Study Design: Postmarketing database review Overall N: 1,442 (4257 PY) Study Duration: Mean 3.7 yrs | Inclusion Criteria: • Participant in 1 of various studies* of ETA in pts with rheumatoid arthritis • Pts had active RA; and, received 10 to 50 mg ETA subcutaneously twice weekly for majority of time they received study drug. Specific inclusion criteria varied by included study Exclusion Criteria: NR | Interventions, dose: D1: ETA N: D1: 1442 Mean age, yrs: D1: 49.9 Sex, % female: D1: 76.5 Race, % white: D1: 87.4 | Mean disease duration, yrs: D1: 7.1 TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR | Health Outcome Measures: • Total # of cases of SCC reported from post- marketing database population: 4 cases Age and sex-matched expected incident cases based on: • From Arizona general population-based incidence study: 13.1 cases • From Minnesota general population-based incidence study: 5.9 cases • Number of cases of SCC per PY of exposure to ETA In clinical trial population: 0.9/1000 PY • From post-marketing surveillance data: .01/1000 PY Summary Statement: The incidence of SCC among pts taking ETA is likely no different from that of the general population. | NR | Overall Attrition Rate, %: NA ITT Analysis: NA Quality Rating: Fair:
Author, yr: Lee, 2002 Country, Setting: US, clinics Funding: NR Research Objective: To identify post-licensure cases of opportunistic histoplasmosis in pts treated with INF and ETA Study Design: Database analysis; AERS Overall N: 10 cases (from FDA passive surveillance database for monitoring postlicensure AEs) Study Duration: varied | Inclusion Criteria: • Any report of histoplasmosis in a patient receiving ETA or INF had been received by AERS by July 2001 Exclusion Criteria: NR | Interventions, dose: D1: ETA D2: INF D3: Overall ETA: varied INF: varied N: D1: 9 D2: 1 D3: 10 Mean age, yrs: D1: 11–78 (range) D3: median: 43.5 Sex, % female: D1: 4/9 (44.4%) D2: 0/1 (0% ) D3: 40 Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR Concomitant immunosuppressive: D1: 100 D2: 100 | • 9 cases among pts receiving INF • 1 case among pts receiving ETA Through August 2001, number of pts treated • With INF: ~150,000 • With ETA: ~96,500 Histoplasmosis case rates per 100,000 pts receiving drug • INF: ~6/100,000 • ETA: ~1/100,000 Deaths due to histoplasmosis • INF: 1/10 • ETA 0/1 Summary: More cases of histoplasmosis were reported to AERS by July 2001 among pts receiving INF than those receiving ETA. When accounting for actual number of pts taking each of drug, histoplasmosis case rate was ~6 times higher among pts receiving INF than among those receiving ETA | NR | Overall Attrition Rate, %: NA ITT Analysis: NA Quality Rating: Fair
Author, yr: Listing et al., 2005 Country, Setting: Germany, population-based Funding: Joint grant from Essex, Wyeth, Amgen, and Abbott Research Objective: Incidence rates of serious and non-serious infections in pts with RA who start txt with a biologic agent, and to compare these rates with those in pts with RA who receive conventional txt Study Design: Prospective cohort study Overall N: 1529 Study Duration: Up to 12 mos | Inclusion Criteria: • Age: 18 to 75 • Diagnosed according to ACR criteria new txt with ETA, INF, or AKA • Controls: pts started on DMARD therapy after failure of > 1 other DMARD, or with additional DMARD added to existing DMARD Exclusion Criteria: • NR | Interventions, dose: D1: ETA D2: INF D3: AKA D4: DMARDS (control) N: D1: 512 D2: 346 D3: 70 D4: 601 Mean age, yrs: D1: 53.7 D2: 53.6 D3: 54.3 D4: 56.5 Sex, % female: D1: 78.1 D2: 70.8 D3: 77.1 D4: 82.7 Race, % white: NR | Mean disease duration, yrs: D1: 9 D2: 8 D3: 13 D4: 6 TJC, mean: D1: 13.3 D2: 12.7 D3: 12.6 D4: 10 SJC, mean: D1: 10.5 D2: 10.8 D3: 10.2 D4: 7.7 DMARD use, %: D1: 51.6 D2: 89.6 D3: 71.4 D4: 0 Glucocorticoids use, %: D1: 87.4 D2: 85.2 D3: 87 D4: 77.2 MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 6.1 D2: 6.0 D3: 6.1 D4: 5.4 MTX use: D1: 33 D2: 64.5 D3: 61.4 D4: 20.1 | See AEs | Overall: D1: 22.6 per 100 PY D2: 28.3 per 100 PY D3: 17.5 per 100 PY (95% CI,8.8–31.2) D4: 6.8 per 100 PY SAEs: D1: 6.4 per 100 PY D2: 6.2 per 100 PY D3: 3.2 per 100 PY (95% CI,0.4–11.5) D4: 2.3 per 100 PY Infections: D1: 15 D2: 21 D4: 6 Serious Infections: D1: 6.4 per 100 PY D2: 6.2 per 100 PY Drug 3D4: 2.3 per 100 PY URTI: D1: 7.0 D2: 11.4 D3: 1.8 | Overall Attrition Rate, %: 11.1 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Maini et al. 2004 Country, Setting: Multinational Multicenter Funding: Centocor Research Objective: Efficacy and safety of repeated administration of infliximab plus MTX over a 2-yr period in pts with RA Study Design: RCT plus extension Overall N: 428 (259 in extension) Study Duration: 54 wks plus additional yr of follow-up | Inclusion Criteria: • Age 18–75 • Active RA despite MTX Exclusion Criteria: • NR | Interventions, dose: D1: INF D2: Placebo Mean age, yrs: Overall: 54 Sex, % female: Overall: 78 Race, % white: NR | Mean disease duration, yrs: D1: TJC, mean: Overall: 31 SJC, mean: Overall: 20 DMARD use, %: NR Corticosteroid use, %: NR MTX naïve, %: NR DMARD Txt resistant, %: NR Patients with Early RA (≤ 3 yrs): NR | The incidence of serious adverse events remained constant over time | • Serious adverse events were reported by similar proportions of pts who received MTX only (33%) and infliximab plus MTX (29%) • Number of observed cancer cases vs. number expected Placebo 0 vs. 1.02 INF 5 vs. 5.15 | Overall Attrition Rate, %: • At 52 wks 27% • At 2 yrs 17% of those that continued into extension ITT Analysis: Yes Quality Rating: Fair
Author, yr: Mohan et al, 2001 Country, Setting: US, NA Medwatch, AERS Funding: NR Research Objective: To review occurrence of neurologic events suggestive of demylenation during anti TNF alpha therapy for inflammatory arthritides Study Design: Database analysis; AERS Overall N: 20 cases Study Duration: 4 mos | Inclusion Criteria: • Pts with refractory RA who developed confusion and difficulty walking • Other meds allowed: MTX, prednisone, amlodipine, estradiol, zolpidem, dexamethasone , a;prasolam, hydrocodone, naproxen sodium, acyclovir, metronidazole, ceftriaxone, ranitidine, atenolol, fluoxetine, piroxicam Exclusion Criteria: NA | Interventions, dose: NR N: NR Mean age, yrs: NR Sex, % female: NR Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA ( 3 yrs): NR Baseline DAS, mean: NR NR | In addition to 1 case reported of suspected demyelination, 17 cases of demyelination after ETA and 2 cases after INF txt were detected in MedWatch | NR | Overall Attrition Rate, %: NA ITT Analysis: NA Quality Rating: Fair
Author, yr: Mohan et al., 2004 Country, Setting: Multinational, population-based Funding: NR Research Objective: To summarize all cases of TB following use of ETA reported to AERS from November 1998 through March 2002 Study Design: Database analysis; AERS Overall N: 25 cases Study Duration: NA | Inclusion Criteria: • All pts receiving ETA and reported to have active TB Exclusion Criteria: NR | Interventions, dose: D1: ETA N: D1: 25 cases Mean age at diagnosis, yrs: D1: 59 Sex, % female: D1: 72 Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA ( 3 yrs): NR Baseline DAS, mean: NR | • As of April 2002, a total of 25 reports of TB associated with ETA therapy reported to FDA from 11/1998 through 3/2002 • 17 cases (68%) were reported from US, 7 (28%) from Europe, and 1 (4%) from India • 46% of 24 pts with a reported clinical manifestation had pulmonary TB • 2 deaths occurred among 25 pts • 17 US cases of TB have been reported to the FDA • According to ETA manufacturer, 113,238 pts treated with ETA in US between 11/1998 and 5/2002, with estimated 172,212 PY of exposure; thus reporting rate of TB among pts in US receiving ETA is ~10 cases / 100,000 PY of exposure | NR | Overall Attrition Rate, %: NA ITT Analysis: NA Quality Rating: Fair
Author, yr: Moreland et al., 2006 Country, Setting: Multinational, pooled retrospective analysis Funding: NR Research Objective: To evaluate safety and efficacy of long-term etanercept treatment in pts with DMARD refractory RA Study Design: RCT Overall N: 714 safety and 581 efficacy Study Duration: Up to 7 yrs | Inclusion Criteria: • Adult pts with DMARD- refractory RA involved in included Initial clinical trials and extension (7 trials, 3 of placebo- controlled, randomized, double-blind phase 2 or 3 trials; 2 were phase 1 randomized dose-finding trials, and 2 were open- label) Exclusion Criteria: NR | Interventions: D1: All pts D2: Patients in extension N: D1: 714 D2: 581 Mean age yrs: D1: 53 D2: 52 Sex, % female: D1: 79 D2: 80 Race, % white: D1: 90 D2: 90 | Mean disease duration, yrs: D1: 12 D2: 12 TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: D1: 65 D2: 65 MTX naive, %: NR Treatment resistant %: NR Patients with Early RA ( 3 yrs): NR Baseline DAS, mean: NR | • Overall rate of SAEs was 14.8/100 patient-yrs compared to initial trial rates 8 pts out of 152 reported SAE in placebo group (20.0 events/100 PY; 40 PY), and 17 pts out • of 349 reported SAE in etanercept group (15.0 events/100 patient yrs; 117 PY). Incidence rates stayed the same over time • Serious adverse events overall rate = 14.8 events/100 PY • Serious infections overall rate = 4.2 events/100 PY); cancer (overall rate = 1.0 events/100 PY); deaths (overall rate = 0.7 events/100 PY) • Overall 13.7% withdrew because of AEs | See health outcomes | Overall Attrition Rate, %: 52% ITT Analysis: Not Quality Rating: Fair for AEs
Author, yr: Mottonen, 1999; Korpela, 2004; Puolakka, 2004 FIN-RACo Study Country, Setting: Finland, NR Funding: Finnish Society for Rheumatology and Medical Research Foundation of Turku University Central Hospital Research Objective: Efficacy and tolerability of combo of DMARDs vs. a single DMARD Study Design: RCT Overall N: 199 randomized, 187 completed 2 yrs, 160 at 5 yrs Study Duration: 24 mos (5 yr followup) | Inclusion Criteria: • Age: 18 to 65 • Diagnosed with RA according to ACR criteria: active disease, 1987 criteria Duration of condition: < 2 yrs Exclusion Criteria: • Previous use of DMARDs • Underwent glucocorticoid glucocorticoid therapy within the previous • 2 weeks • serious comorbidity • suspected inabilty to • comply with the protocol • hypersensitivity to any study medication • history of cancer • pregnant women • women of childbearing age who were not using reliable methods of contraception | Interventions, dose: D1: Combo: MTX + HCQ + SSZ + PNL D2: Single DMARD (SSZ could be changed to MTX or 3^rd^ DMARD) ± PNL PNL: 5 to 10 mg/day MTX: 7.5 to 10 mg/wk SSZ: 2 g/day Combo: 500 mg/2xd Single: 1000 mg 2xd w/ or w/out PNL HCQ: 300 mg/d Combo: if patient reaches remission in first year, patietn could be tapered and PNL could be discontinued at 9 and 18 months N: D1: 97 D2: 98 Mean age, yrs: D1: 45 D2: 46 Sex, % female: D1: 58 D2: 66 Race, % white: NR | Mean disease duration, yrs: D1: 7.3 mos D2: 8.6 mos TJC, mean: D1: 18 D2: 20 SJC, mean: D1: 14 D2: 14 DMARD use, %: NR Corticosteroid use, % NR MTX naive, %: NR Txt resistant, %: NR Pts with Early RA ( 3 yrs): NR Baseline DAS, mean: NR Larsen Score: D1: 0 D2: 2 | At 2 years Eroded joints, number: D1: 2 D2: 3 (P = 0.006) btw groups Progression of radiological joint damage lower in combination versus monotherapy Larsen Erosion Score improvement: D1: 2 D2: 10 (P = 0.002) Median increase in Larsen Score: D1: 1.5 D2: 2.0 (P < 0.001) Clinical remission, %: D1: 37.9 D2: 18.4 (P = 0.011) ACR50, %: D1: 71 D2: 58 (P = 0.058) Median work disability per pt-observation yr, days: D1: 12.4 D2: 32.2 (P = 0.008) At 5 years Eroded joints, number: D1: 3 D2: 6 Larsen Erosion Score: D1:11 D2: 24 (P = 0.001) Median increase in Larsen Score: D1: 1.5 D2: 2.0 (P < 0.001) 5 year Remiission D1: 28 D2: 22 (P = NS) Increase in Larsen score D1: lower than (P =0.004) | Overall: D1: 70 D2: 71 SAEs: D1: 3 D2: 5 Cardiovascular Events: D1: 1 MI D2: 2 MIs Malignancies: 1 prostate cancer; 1 multiple myeloma URTI: 1 pneumonia | Overall Attrition Rate, %: 195 started txt (97/98) 178 completed 2 yrs (87/91); 160 at 5 yrs (78/82) ITT Analysis: Yes Quality Rating: Fair
Author, yr: Nuki et al. 2002 Country, Setting: Multinational multicenter Funding: Amgen Research Objective: Long-term efficacy of anakinra, in pts with RA Study Design: RCT plus extension Overall N: 472 (309 enrolled in 54 wk extension) Study Duration: 76 wks | Inclusion Criteria: • ACR criteria • Disease duration of > 12 mos < 8.5 yrs Exclusion Criteria: NR is this article | Interventions, dose: D1: Anakinra D2: Placebo N: D1: 351 D2: 121 Mean age, yrs: D1: 53.4 D2: 52.2 Sex, % female: D1: 76.6 D2: 70.2 Race, % white: NR | Mean disease duration, yrs: D1: 4.1 D2: 3.7 TJC, mean: D1: 34.8 D2: 32.8 SJC, mean: D1: 26.3 D2: 25.6 DMARD use, %: D1: 73.5 D2: 80.0 Corticosteroid use, % D1: 43.6 D2: 39.7 MTX naïve, %: NR DMARD Txt resistant, %: NR Patients with Early RA ( 3 yrs): NR | See AEs | Number of occurrences per subject-yr of exposure n for safety = D1: 427 D2: 121 ISRs: D1: 2.00 D2: 0.82 Frequency of injection site reactions (ISRs) was 0.82 per patient-yr of exposure in placebo group (first 24 wks) and 1.01, 2.43, and 3.73 for 30-mg, 75-mg, and 150-mg doses over 72 wks | Overall Attrition Rate, %: At 24 wks 27% At 76 wks 32% of those that continued into extension ITT Analysis: Yes Quality Rating: Fair
Author, yr: O’Dell et al 2006 Country, Setting: US, multicenter Funding: NR Research Objective: Determine safety and efficacy of ETA in combination with SSZ, hydroxychloroquine, IM Gold over 48 wks Study Design: Observational Overall N: 119 Study Duration: 48 wks | Inclusion Criteria: • Age: 19–75 • Diagnosed according to ACR criteria; stable SSZ or HCQ doses; 10mg or less/d steroids > 4wks • Active disease with 6 or more swollen and tender joints Exclusion Criteria: • Pregnant or lactating • ETA • Biologics in past 4 wks • Impaired renal or hepatic system • Antibody to TNFalpha • Anti CD4 antibody • Diphterial interleukin 2 fusion protein • Active or chronic infections | Interventions, dose: D1: ETA (25mg sc twice weekly) + SSZ D2: ETA (25mg sc twice weekly) + HCQ D3: (Gold + ETA) N: D1: 50 D2: 50 D3: 19 Mean age, yrs: D1: 47 D2: 49.7 Sex, % female: D1: 78 D2: 76 Race, % white: D1: 88 D2: 92 | Mean disease duration, yrs: D1: 8.1 D2: 8.7 TJC, mean: D1: 16.5 D2: 16.4 SJC, mean: D1: 17.7 D2: 17.1 DMARD use, %: NR Corticosteroid use, %: D1: 58 D2: 68 MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR HAQ: D1: 1.32 D2: 1.33 | • Pts in each ETA combination showed significant improvement at 24 and 48 wks • No significant differences for ACR20/50 BETWEEN combination groups at 24 or 48 wks (NR). At 24 and 48 wks, ETA/SSZ combo showed highest ACR70 response (NR) • At 24 wks change in HAQ SSZ −0.56+/−0.77 HCQ − 0.71+/−0.65 P = NR | NR | Overall Attrition Rate, %: 30% ITT Analysis: Yes Quality Rating: Fair
Author, yr: Saag et al., 1994 Country, Setting: US, multicenter Funding: General Clinical Research Program, NIH and Halifax Clinical Research Center Research Objective: To determine whether low dose steroids in txt of RA independently cause an increased E-179 incidence of steroid-associated SAEs Study Design: Observational Overall N: 224 Study Duration: At least one yr (4.9 +/−3.9 yrs of txt). | Inclusion Criteria: • Age > 16 • Diagnosed according to ACR criteria • On low-dose steroids ≥ 1 yr; matched for age, sex, race, and duration of disease prior to study inception; allowed occasional intraarticular or parenteral steroids or oral steroid pulses to certain defined limits. • SAARDs were allowed Exclusion Criteria: • CXT, chlorambucil, nitrogen mustard, or experimental antirheumatic drugs • Impaired renal or hepatic system • Concurrent or alternative rheumatic disorder • Bedridden status • Referral 2nd to a steroid complication | Interventions, dose: D1: Treated (with low dose long-term corticosteroids) D2: Untreated (with low dose long-term corticosteroids) Prednisone: corticosteroids, less than or equal to 15mg/d of PRE (or equivalent dose of an alternative steroid) N: D1: 112 D2: 112 Mean age, yrs: D1: 51.8 D2: 51.7 Sex, % female: D1: 75 D2: 75 Race, % white: D1: 98.2 D2: 98.2 | Mean disease duration, yrs: D1: 4.9 +/−6.3 D2: 4.9 +/−6.7 TJC, mean: NR SJC, mean: NR Average no of SAARDs: D1: 0.47 +/−0.82 D2: 0.13 +/−0.37 Corticosteroid use, %: D1: 100 D2: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR RF: D1: 77.7 D2: 58.0 ESR: D1: 50 +/−29.7 D2: 36.4 +/−30.5 Extra-articular disease D1: 16.1% D2: 6.3% | • n for Treated and Untreated groups respectively: Fracture 21 and 8; GI bleed or ulcer 11 and 4; cataracts 17 and 5; diabetic complications 8 and 3; herpes zoster 8 and 1; glaucoma 1 and 1; death 2 and 0. • OR of 32.3 (95% CI,4.6, 220) (P = 0.0004) for pts treated with > 10 up to 15mg/d PRE equivalent; OR of 4.5 (95% CI,2.1, 9.6) (P = 0.0001) for pts treated with 5–10mg/d; Prednisone dose <5mg/d did not show a significant increase in risk of having an AE compared to the untreated group; • *Although PRE average dose and cumulative dose had small but significant emsitmated relative risks (OR 1.21, 95%CI,1.0–1.5 for both), PRE use (yes/no) was most highly linked to infection (OR 8.0, 95% CI,1.0–64.0, P < 0.05) • Fracture (OR 3.9, 95% CI,0.8–18.1, P < 0.09) • First GI event: OR 3.3 (95% CI,0.9–12.1, P < 0.07) | Overall: D1: n =92 AEs D2: n =31 Serious Infections: D1: n =14 D2: n =4 Cardiovascular Events: D1: n =10 (4 myocardial infarctions, 6 strokes) D2: n =5 (4 myocardial infarction, 1 stroke) | Overall Attrition Rate, %: NA ITT Analysis: Yes Quality Rating: Fair
Author, yr: Salliot et al., 2006 Country, Setting: France, tertiary care Funding: NR Research Objective: To evaluate rate of infections in rheumatic pts treated with TNF-alpha blockers in daily practice and to determine potential risk factors of infections Study Design: Case series Overall N: 709 w/ follow-up at least once and 623 w/ with a control period Study Duration: NR | Inclusion Criteria: • Pts receiving a TNF-alpha blocker and with a follow-up • Those with control period before txt initiation Exclusion Criteria: NA | Interventions, dose: D1: Follow up D2: Follow up and control N: D1: 709 D2: 623 Mean age, yrs: D1: 45.9 D2: 46.5 Sex, % female: D1: 60.4 D2: 60.4 Race, % white: NR | Mean disease duration, yrs: D1: 11.8 D2: 12.1 TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: D1: 58.5 D2: 58.3 MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR MTX use: D1: 43.7 D2: 43.6 | • 34.5% experienced infection during course of txt; Incidence rate: 48.2 per 100 PY • 6.2 percent experienced a serious infection; incidence rate: 10.4 per 100 PY • Infections by txt: • Any: INF 69.8 ETA 44.1 Adalimumab 37.3 per 100 PY • Serious: INF 10.2 ETA 12.3 Adalimumab 5.3 per 100 PY | Infections: D1: 50.5 D2: 34.2 D3: 15.3 URTI: D1: 13.4 D2: 9.4 D3: 9.9 UTI: D1: 5.1 D2: 1.1 D3: 1.6 | Overall Attrition Rate, %: NA ITT Analysis: NA Quality Rating: Fair
Author, yr: Schaible et al., 2000 Country, Setting: US; safety database of efficacy trials Funding: Centocor Research Objective: Long term safety of infliximab Study Design: Observational Overall N: 963 Study Duration: Up to 3 yrs | Inclusion Criteria: 12 clinical trials Exclusion Criteria: NR | Interventions: Infliximab N:963 Mean age, yrs: NR Sex, % female: NR Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Treatment resistant %: NR Patients with Early RA (≤3 yrs): NR Baseline DAS, mean: NR | • Acute infusion reactions (headache, fever, chills, urticaria, chest pain: infliximab 17% versus placebo 7%; P = NR • 0.5% of infliximab pts had severe infusion reactions • Less than 2% discontinued treatment because of infusion reactions Infections: • Infliximab 26% over 27 wks of follow-up versus placebo 16% over 20 wks of follow-up) • Incidence of serious infections per patient-yr infliximab 0.064 versus placebo 0.114 | See outcomes | Overall Attrition Rate, %: ITT Analysis: Not applicable Quality Rating: Fair
Author, yr: Schiff et al., 2006 Country, Setting: Mulitnational, multicenter Funding: Abbott Labs Research Objective: To assess safety of adalimumab in global clinical trials and postmarketing surveillance among pts with rheumatoid arthritis Study Design: Retrospective cohort study; postmarketing surveillance Overall N: 10,050 (12506 PY) Study Duration: Varied | Inclusion Criteria: • Pts from RCTs, open label extensions, and two phase IIIb open label trials were and post-marketing spontaneous reports of adverse events in US Exclusion Criteria: NA | Interventions, dose: NR N: 10,050 Mean age, yrs: NR Sex, % female: NR Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR | Rates per 100 PY: • TB: 0.27 • Histoplasmosis: 0.03 • Demyelinating diseases: • 0.08 • Lymphoma: 0.12 • SLE/lupus-like syndrome: 0.10 • Congestive heart failure: 0.28 | NA | Overall Attrition Rate, %: NA ITT Analysis: NA Quality Rating: Fair
Author, yr: Setoguchi et al., 2006 Country, Setting: US and Canada, 3 databases Funding: Novartis and NIH Research Objective: To estimate association between treatment with biologic DMARDs and development of cancer in pts with RA Study Design: Observational Overall N: 7,830 Study Duration: 1994 to 2004 in US 1996 to 2003 in Canada | Inclusion Criteria: • Age ≥ 65 • 1 claim with a diagnosis of RA and who were dispensed at least 1 prescription of any DMARD or corticosteroid after first RA diagnosis Exclusion Criteria: • Diagnosis of any cancer (except nonmelanoma skin cancer) or human immuno-deficiency virus infection | Interventions: D1: Biologic DMARD D2: MTX N: D1: 1152 D2: 7306 Mean age (yrs): D1: 71.4 D2: 73.4 Sex, % female: D1: 75.3 D2: 73.1 Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: D1: 51.3 D2: 41.5 MTX naive, %: NR Treatment resistant %: NR Patients with Early RA (≤3 yrs): NR Baseline DAS, mean: NR | • RA pts vs. overall population • Non-Hodgkin’s lymphoma-PY 33,335.0 Observed 58 Expected 26.0 SIR 2.2 95% CI, 1.71–2.87 • Multiple myeloma-PY yrs 33,410.0 Observed 19 Expected 9.3 SIR 2.0 95% CI, 1.26–3.12 • Melanoma-PY 33,377.7 Observed 29 Expected 12.8 SIR 2.3 95% CI, 1.55–3.22 • Colorectal cancer-PY 32,844.9 Observed 118 Expected 97.3 SIR 1.2 95% CI, 1.01–1.45 • Lung cancer-PY 31,532.8 Observed 169 Expected 95.6 SIR 1.8 95% CI, 1.52–2.05 • Urinary tract/bladder cancer-PY 33,367.0 Observed 54 Expected 26.4 SIR 2.0 95% CI, 1.55–2.65 • Biologics vs. MTX • Unadjusted Lymphoproliferative HR 1.20 (95% CI, 0.57–2.51) Hematologic HR 1.45 (95% CI, 0.76–2.74) Solid HR 0.91 (95% CI, 0.66–1.25)Overall HR 1.00 (95% CI, 0.75–1.33) | See health outcomes | Overall Attrition Rate, %: NA ITT Analysis: Not applicable Observational study Quality Rating: Good
Author, yr: Shin et al 2006 Country, Setting: US Funding: NR Research Objective: Review occurrence and clinical features of Guillan Barre syndrome and Miller Fisher Syndrome during TNF alpha antagonist therapy Study Design: Database analysis; AERS Overall N: 16 cases Study Duration: NR | Inclusion Criteria: • TNF alpha antagonist therapy in AERS database Exclusion Criteria: NA | Interventions, dose: NR ETA INF N: NR Mean age, yrs: NR Sex, % female: NR Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR | • Guillain-Barre was temporally associated with INF in 10 pts, ETA in 5 pts. This compares to an annual incidence of Guillain Barre Syndrome of 1–3/100,000 population | NR | Overall Attrition Rate, %: NR ITT Analysis: NA Quality Rating: Fair
Author, yr: Slifman, 2003 Country, Setting: Multinational, multicenter Funding: NR Research Objective: To evaluate postlicensure cases of opportunistic infection, including Listeria monocytogenes, in pts treated with TNFs Study Design: Database analysis; AERS Overall N: 15 cases Study Duration: Varied | Inclusion Criteria: • Age: 17 to 80 • Pts with Listeria monocytogenes treated with ETA or INF for RA or Crohn’s disease • Concurrent use of immuno-suppressant drugs allowed Exclusion Criteria: • NA | Interventions, dose: D1: INF or ETA ETA: varied INF: varied N: D1: 15 Median age, yrs: D1: 69.5 Sex, % female: D1: 53.3 Race, % white: D1: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR RA: D1: 64% | • For all ages and indications, the estimated rate of cases (reporting rates) of listeriosis reported to FDA within first yr of starting txt with inf was 43 cases per 1,000,000 persons (8/186,500) • RA pts treated with inf (US cases only), estimated rate of cases of listeriosis reported to FDA was 61 cases per 1,000,000 persons (5/82,000) • In 2000, annual incidence of listeriosis in US for all ages was estimated to be 3 cases per 1,000,000 • 6 deaths reported (5 INF, 1 ETA) • Among reports from US only, this series included 8 cases of Listeria infection, all of which were associated with INF txt | NR | Overall Attrition Rate, %: NA ITT Analysis: NA Quality Rating: Fair
Author, year: Smolen et al., 1999; Larsen 2001; Scott 2001 Country, Setting: Multinational, multicenter Funding: Hoechst Marion Roussel Research Objective: Efficacy and safety of novel DMARD leflunomide was compared to placebo and sulfasalazine Study Design: RCT Overall N: 266 (358 including placebo arm) Study Duration: 24 wks (12 and 24 month followup) | Inclusion Criteria: • Age: ≥ 18 • Active RA defined by: ≥ 6 tender and swollen joints, based on a 28-joint count, physician and pt global assessments of RA activity of “fair, poor, or very poor”, CRP > 2.0 mg/dL or ESR > 28 mm/h • Functional class I – III • Other DMARDs discontinued ≥ 4 wks • Stable doses of NSAIDS permitted -acetylsalicylic acid, oral steroids (prednisolone ≤ 10 mg/day), and up to 3 intra-articular steroid injections, not exceeding 60 mg triamcinolone • Intra-articular steroid injections not permitted during first 6 mos Exclusion Criteria: • Pregnant or lactating | Interventions: D1: LEF D2: SSZ N: D1: 133 D2: 133 Mean age, yrs: D1: 58.3 D2: 58.9 Sex, % female: D1: 75.9 D2: 69.2 Race, % white: NR | Mean disease duration, yrs: D1: 7.6 D2: 7.4 TJC, mean: NR SJC, mean: NR DMARD use, %: D1: 60.2 D2: 48.9 Corticosteroid use, %: D1: 28.6 D2: 27.8 MTX naive, %: NR Treatment resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR RF positive: D1: 79% D2: 80% | At 24 weeks ACR 20, %: D1: 55 D2: 56 ACR 50, %: D1: 33 D2: 30 Improving HAQ scores, change (%): D1: −0.50 (45) D2: −0.29 (29) (P = 0.0086) Change in Sharp; number, change (SD): D1: 87 1.23 (2.85) D2: 84 2.32 (10.11) Larsen score change: D1: 0.01 D2: 0.01 (P = NS) At 1 year Change in Sharp; number, change (SD): D1: 60 0.97 (6.11) D2: 53 1.38 (2.88) Larsen score change: D1: 0.02 D2: 0.02 (P = NS) At 2 years Larsen score change: D1: −0.07 D2: −0.02 (P = NS) Similar ACR20 response rates D1: 48; D2: 44; P=NR | SAEs: D1: 5 D2: 7 Headache: D1: 7 D2: 11 Nausea: D1: 10 D2: 17 URTI: D1: 14 D2: 15 Diarrhea: D1: 17 D2: 9 Alopecia: D1: 8 D2: 5 Rash: D1: 10 D2: 9 Withdrawal due to AEs: D1: 14 D2: 19 2 cases of reversible agranulocytosis in SSZ | Overall Attrition Rate, %: 33% at 24 wks ITT Analysis: Yes Quality Rating: Fair
Author, yr: St. Clair, 2004; Smolen, 2006 ASPIRE Trial Country, Setting: Multinational, university hospitals Funding: Centocor Research Objective: To compare benefits of initiating txt with MTX and anti-TNFá with those of MTX txt alone in pts with RA of < 3 yrs duration Study Design: RCT Overall N: 1049 Study Duration: 54 wks | Inclusion Criteria: • Age: 18 to 75 • Diagnosed according to 1987 ACR criteria • Persistent synovitis for > 3 mos and < 3 yrs • > 10 swollen joints, and > 12 tender joints • 1 or more of following: a positive test result for serum RF, radiographic erosions of hands or feet, or a serum C-reactive protein level of > 2.0 mg/dl Oral corticosteroids; NSAIDS • 20 mg MTX (required) Exclusion Criteria: • Prior txt with: MTX, received other DMARDs within 4 wks of entry • Used ETA, INF, ADA or other anti-TNF-á agent • History of TB; HIV, hepatitis B or C virus, CHF, or lymphoma or other malignancy within past 5 yrs (excluding excised skin cancers) | Interventions, dose: D1: MTX (20 mg/wk) + placebo D2: MTX + INF (3 mg/kg/wk) D3: MTX + INF (6 mg/kg/wk) N: D1: 282 D2: 359 D3: 363 Mean age, yrs: D1: 50 D2: 51 D3: 50 Sex, % female: D1: 75 D2: 71 D3: 68 Race, % white: NR | Mean disease duration, yrs: D1: 0.9 D2: 0.8 D3: 0.9 TJC, mean: D1: 34 D2: 32 D3: 33 SJC, mean: D1: 22 D2: 21 D3: 22 DMARD use, %: D1: 35 D2: 29 D3: 32 Corticosteroid use, % NR MTX naive, %: Overall: 100 Txt resistant, %: NR Pts with Early RA (≤3 yrs): Overall: 100 Baseline DAS, mean: NR JSN: D1: 3.0 D2: 2.9 D3: 2.9 HAQ: D1: 1.5 D2: 1.5 D3: 1.5 | At weeks 30 to 54 HAQ: D1: 0.68 D2: 0.80 D3: 0.88; (D2 vs. D1; P = 0.03) (D3 vs. D1; P < 0.001) At 54 weeks HAQ > 0.22, %: D1: 65.2 D2: 76.0 D3: 75.5 (D2 vs. D1; P = 0.003) (D3 vs. D1; P < 0.004) ACR20, %: D1: 53.6 D2: 62.4 D3: 66.2 (D2 vs. D1; P = 0.028) (D3 vs. D1; P < 0.001) ACR50, %: D1: 32.1 D2: 45.6 D3: 50.4 (D2 vs. D1; P = 0.001) (D3 vs. D1; P < 0.001) ACR70, %: D1: 21.2 D2: 32.5 D3: 37.2 (D2 vs. D1; P = 0.002) (D3 vs. D1; P < 0.001) ACR-N, %: D1: 26.4 D2: 38.9 D3: 46.7 (P < 0.001) Modified Sharp: D1: 3.7 D2: 0.4 D3: 0.5 (P < 0.001) Increase in radiographic score, %: INF: 39 vs. MTX 61 (P < 0.001) Employability: INF+MTX (OR 2.4, P < 0.001) MTX (P = 0.56) Combo has higher probability of improvement than MTX alone Net increase in employability: MTX+INF: 8% MTX-only: 2% Employability status changed from employable to unemployable, %: INF: 8 MTX-only: 14 (P = 0.05) SF-36 Physical component summary scores D1: 11.7 D2: 13.2 D3: 10.1 D3 vs. D1, P =0.10 D3 vs. D2; P =0.003 Modified Sharp/van der Heijde Score change: D1: 3.7 D2: 0.4 D3: 0.5 P < 0.001 Erosion Score change: D1: 3.0 D2: 0.3 D3: 0.1 P < 0.001 JSN Score change: D1: 0.6 D2: 0.1 D3: 0.2 P < 0.001 | SAEs: D1: 11 D2: 14 D3: 14 Serious Infections: D1: 2.1 D2: 5.6 D3: 5.0 Infusion or injection reaction: D1: 7 D2: 21 D3: 15 TB: D1: 0 D2: 0.8 D3: 0.3 Nausea: D1: 18 D2: 20 D3: 17 URTI: D1: 21 D2: 25 D3: 28 | Overall Attrition Rate, %: 14.9 ITT Analysis: Yes Quality Rating: Fair
Author, year: Strand et al., 1999; Cohen 2001; Strand, Tagwell 1999 Country, Setting: US and Canada, multicenter (47 university & private rheumatology practices) Funding: Hoescht Marion Roussel Research Objective: Efficacy and safety of LEF with placebo and MTX in active RA Study Design: RCT Overall N: 482 (active arms- 364) Study Duration: 12 mos (w/ 1 year followup) | Inclusion Criteria: • Age: 18 or older • Diagnosed according to ACR criteria; DMARDs discontinued at least 30 days prior • Duration of condition at least 6 mos • 10 mg stable prednisone (or equivalent) • NSAIDs if dosages stable at least 30 days prior to enrollment Exclusion Criteria: • Pregnant or lactating • Prior treatment with: MTX • Inflammatory joint disease not caused by RA, • History of clinically significant drug or alcohol abuse, or admitted to consumption of more than 1 alcoholic drink per day | Interventions: D1: LEF (20 mg/week) D2: MTX (7.5 to 15 mg/week) N: D1: 182 D2: 182 Mean age, yrs: D1: 54.1 D2: 53.3 Sex, % female: D1: 72.5 D2: 75.3 Race, % white: NR | Mean disease duration, yrs: D1: 7.0 D2: 6.5 TJC, mean: D1: 15.5 D2: 15.8 SJC, mean: D1: 13.7 D2: 13.0 DMARD use, %: D1: 55.5 D2: 56.0 Corticosteroid use, %: D1: 53.8 D2: 52.7 MTX naive, %: Both groups 100 Treatment resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR RF positive: D1: 64.8 D2: 59.4 MHAQ: D1: 0.8 D2: 0.8 | At 12 mos ACR 20, % D1: 52 D2: 46 ACR 50, % D1: 34 D2: 23 ACR 70, % D1: 20 D2: 9 MHAQ mean change D1: −0.3 D2: −0.2 Sharp score change D1: 0.53 (n:131) D2: 0.88 (n= 138) (P = 0.05) Mean change HAQ-DI D1: −0.45 (n= 164) D2: −0,26 (n= 168) (P ≤ 0.01) Mean change SF-36 physical component D1: 7.6 (n= 157) D2: 4.6 (n=162) Work productivity mean change D1: 9.8 (n= 138) D2: 7.5 (n= 148) Discontinuation rate, %: D1: 22 D2: 10.4 (P = NR) At 2 yrs ACR 20, % D1: 79 D2: 67 (P = 0.049) ACR 50, % D1: 34 D2: 28 ACR70, % D1: 17 D2: 12 Sharp score change D1: 1.6 (n= 71) D2: 1.2 (n= 66) HAQ DI change D1: −0.6 (n= 97) D2: 0.37 (n=101) Discontinuation rate, %: D1: 27 D2: 17 | SAEs: D1: 1.1 D2: 2.7 Infections: D1: 56.6 D2: 59.9 Abdominal Pain: D1: 13.7 D2: 15.4 Nausea: D1: 20.9 D2: 19.2 Back pain: D1: 8 D2: 2 Diarrhea: D1: 36.8 D2: 21.6 Oral Ulcers: D1: 6.8 D2: 10.5 GI Events: D1: 5.5 D2: 1.7 Elevated Transaminases: D1: 7.1 D2: 4.4 Adherence: Non-adherence as the reason for reason for withdrawal D1: 1 D2: 1 At 24 months SAEs, %: D1: 18.9 D2: 18.9 | Overall Attrition Rate, %: 51% at 1 year ITT Analysis: Yes Quality Rating: Fair
Author, yr: Suissa et al., 2004 Country, Setting: US, 2 large databases Funding: Aventis Research Objective: Assess risk of hepatic events associated with the use of LEF and other DMARDS compared to MTX Study Design: Observational Overall N: 41,885 Study Duration: 3 yrs | Inclusion Criteria: • Age: 18 and older • Previous use of DMARDs: after 9/1/98 • ICD 9 code for RA Exclusion Criteria: • < 3 mos eligibility in health insurance plan • Pts with outcome 3 mos before cohort study | Interventions, dose: NR N: NR Mean age, yrs: NR Sex, % female: NR Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR | • When compared to MTX, No increased risk with LEF(rate ratio 0.9, 95% CI, 0.2–4.9), or with traditional DMARDS (RR 2.3; 95% CI, 0.8–6.5) • There is an increased risk with biologic DMARDS (RR =5.5; 95% CI, 1.2–24.6) • Rate of nonserious hepatic events was also increased with biologic DMARDS (RR 1.5; 95% CI, 1.0–2.3), but not LEF (RR =0.9; 95% CI, 0.7–1.3) and traditional DMARDS (RR 1.1; 95% CI, 0.8–1.4) | NR | Overall Attrition Rate, %: NR ITT Analysis: NA: cohort Quality Rating: Fair
Author, yr: Suissa et al. 2006 Country, Setting: Canada, PharMetrics claims database Funding: Sanofi-Aventis; Canadian Institutes of Health Research Research Objective: To assess risk of ILD in pts with RA treated with LEF. Study Design: Observational Overall N: 62,734 Study Duration: Sept 1, 1998 through Dec 31, 2003 | Inclusion Criteria: • Age: 18 or older • DMARD-treated cohort defined as all subjects who received at least 1 prescription for a DMARD on or after September 1, 1998, mo LEF was approved in US Exclusion Criteria: • No DMARD prescription • Subjects with outcome of interest during 1-yr period prior to cohort entry | Interventions, dose: D1: Cases of ILD D2: Controls N: D1: 74 D2: 7400 Mean age, yrs: D1: 62 D2: 61 Sex, % female: D1: 70 D2: 74 Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR | • Risk of ILD in pts treated with LEF compared with those not treated with LEF; adjusted OR 1.9, 95% CI,1.1–3.6 (all ORs reported here were adjusted for the concurrent use of the other DMARDs, the other anti-RA drugs, as well as sex and comorbid conditions) • Increase was less and was not significant with use of MTX (OR 1.4; 95% CI,0.8–2.3) • No increase in risk of ILD with LEF among pts who had no previous MTX use and no interstitial lung disease prior to cohort entry (37 cases and 4,259 controls); OR 1.2; 95% CI,0.4–3.1. This group did have an increased risk of ILD with MTX treatment (OR 3.1; 95% CI,1.5–6.4). Among those who had previously taken MTX or who had a previous diagnosis of ILD (37 cases and 3,141 controls), the risk of ILD was elevated with LEF treatment (OR 2.6; 95% CI,1.2–5.6) but was decreased with MTX treatment (OR 0.4; 95% CI,0.2–0.9) | NR | Overall Attrition Rate, %: NA ITT Analysis: NA: nested case control design Quality Rating: Fair
Author, yr: Svennsson et al., 2003 Country, Setting: Sweden, multicenter (5 rheumatologic units covering both urban and rural districts) Funding: Swedish Rheumatism Association and Vardal Foundation Research Objective: To study and compare outcomes of 2 different DMARD/corticost eroid options in txt of early RA in clinical practice Study Design: RCT Overall N: 245 Study Duration: 2 yrs | Inclusion Criteria: • Diagnosed according 1987 revised ACR • Duration of condition: less than 2 yrs • Considered to be in need of Css or DMARDS by treating physician’s judgment • NSAIDS and analgesics allowed Exclusion Criteria: • Prior txt with: DMARDS or Cxs • Per authors-- regarded as not suitable for various medical or non-medical reasons | Interventions: D1: PNL + MTX D2: SSZ + PNL at lowest possible dose Overall: PNL: 7.5 to 15 mg daily for 1 to 3 mos. with subsequent reduction to lowest possible dose MTX: 5 to 15 mg per wk SSZ: 2 to 3 grams daily N: D1: 113 D2: 108 Mean age (yrs): D1: median 54 D2: median 52 Sex, % female: D1: 59 D2: 67 Race, % white: NR Mean disease duration, yrs: D1: 6 mos. D2: 7 mos | TJC, mean: NR SJC, mean: NR DMARD use, %: D1: 0 D2: 0 Corticosteroid use, %: D1: 0 D2: 0 MTX naive, %: NR Treatment resistant %: NR Patients with Early RA (≤3 yrs): NR DAS28 median: D1: 5 D2: 4.9 Larsen: D1: 5 D2: 3 HAQ: D1: 0.9 D2: 0.9 RF +: D1: 71 D2: 39 | No significant differences between txt groups for individual response, remission, function, or radiologic progression Response (EULAR individual response criteria for good/moderate/no response, %) D1: 30/40/30. D2: 33/30/37% (P = 0.319) Remission, % D1: 29 D2: 19 (P = 0.095) Mean change in HAQ D1: 0.35 D2: −0.38 (P = 0.752) Mean change in Larsen score 6.2 vs. 4.1 (P = 0.298) Completers, % D1: 81% D2: 53% Survival analysis between 2 groups (using withdrawals due to AEs or inefficacy as terminal event) showed a highly significant difference in survival times between 2 groups (P = 0.0005) | Overall: D1: 9.9 D2: 31.6 | Overall Attrition Rate, %: 39.6 ITT Analysis: No another type of analysis was used (define): Although they state it was an ITT analysis, statistical analysis based on 221 of the 245 pts with available data for clinical outcomes and for about 72% of the cases for Larsen score (based on available Quality Rating: Poor for efficacy, fair for adverse events
Author, yr: van Riel et al., 2006 Country, Setting: Multinational, multicenter Funding: Wyeth Research Objective: Evaluate efficacy and safety of ETA monotherapy vs. ETA + MTX in RA pts with inadequate response to MTX Study Design: RCT, open-label Overall N: 315 Study Duration: 16 wks | Inclusion Criteria: • Age: ≥ 18 • Diagnosed according to ACR criteria • Functional class of: I–III • Previous use of DMARDs • Inadequal control of RA symptoms on MTX ≥12.5 mg/wk for ≥3 mos Exclusion Criteria: • DMARDS other than MTX within 12 wks of screening; prednison ≥10 mg/d • Corticosteroid injections within 6 wks • ‘Significant’ concurrent medical illness | Interventions, dose: D1: ETA (25 mg s.c. twice wkly) D2: ETA (25 mg s.c. twice wkly) + MTX (≥12.5 mg/wk) N: D1: 159 D2: 155 Mean age, yrs: D1: 53 D2: 54 Sex, % female: D1: 79.2 D2: 76.8 Race, % white: D1: 99.4 D2: 98.7 | Mean disease duration, yrs: D1: 10.0 D2: 9.8 TJC, mean: D1: 14.6 D2: 14.7 SJC, mean: D1: 11.2 D2: 11.9 DMARD use, %: NR Corticosteroid use, % D1: 49.1 D2: 55.5 MTX naive, %: Overall: 0 Txt resistant, %: Overall: 100 Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 6.2 D2: 6.3 HAQ: D1: 1.6 D2: 1 | DAS28 improvement of > 1.2 units, %: D1: 72.8 D2: 75.2 Difference −2.3 (95% CI, −13.1–8.2; P = 0.658) EULAR response maintained, %: D1: 80.0 D2: 82.4 (P = NR) ACR 20, %: D1: 71.0 D2: 67.1 Difference 3.9 (95% CI, −6.4–14,2; P = 0.46) ACR 50, %: D1: 41.9 D2: 40.1 Difference 1.8,(95% CI, −9.2–12.8; P = 0.75) ACR 70, %: D1: 17.4 D2: 18.4 Difference −1.0 (95% CI, −9.6–7.6; P = 0.82) | Overall: D1: 62.9 D2: 70.3 SAEs: D1: 5.0 D2: 4.5 Infections: D1: 24.5 D2: 32.3 Serious Infections: D1: 0.6 D2: 0.3 Infusion or injection reaction: D1: 6.3 D2: 6.5 Dizziness: D1: 0.6% D2: 0 Headache: D1: 8.8 D2: 6.5 URTI: D1: 8.2 D2: 12.9 | Overall Attrition Rate, %: 17.2 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Wallis et al., 2004 Country, Setting: Multinational, multicenter Funding: NR Research Objective: The relationship between the use of tumor necrosis factor antagonists and onset of granulomatous infection was examined Study Design: Database analysis;AERS Overall N: 649 cases Study Duration: various | Inclusion Criteria: • All pts treated with INF or ETA • Other meds allowed • Concurrent use of immuno- suppressant drugs Exclusion Criteria: • NA | Interventions, dose: D1: INF (various) D2: ETA (various) N: D1: 566 cases (>233,000 treated) D2: 83 cases (>113,000 treated) Mean age, yrs: D1: 60 D2: 58 Sex, % female: D1: 66 D2: 59 Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: D1: 41 D2: 66 MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR MTX use: D1: 43 D2: 41 | Granulomatous infections, rate per 100,000 D1: 239 D2: 74 (P < .001) D1 risk of granulomatous infection was 3.25-fold greater among pts than D2. Tuberculosis infections, rate per 100,000 D1: 144 D2: 35 (P < .001) | NR | Overall Attrition Rate, %: NA ITT Analysis: NA Quality Rating: Fair
Author, yr: Wasserman et al., 2004 Country, Setting: Canada, Quaternary care center Funding: Schering- Plough Research Objective: Description of infusion-related reactions to INF (during or within 1 hour of infusion) in pts with active rheumatoid arthritis Study Design: Case series Overall N: 113 pts, 1,183 infusions Study Duration: Mean 60.6 wks | Inclusion Criteria: • Age: 18 to 75 • Diagnosed according to ACR; failed at least 3 DMARDs • Active disease; stable doses of corticosteroids (10 mg/d) and/or NSAIDs Exclusion Criteria: • Biologically- based therapies • Current signs and symptoms of severe, progressive, or uncontrolled renal, hepatic, hematological, GI, endocrine, pulmonary, cardiac, neurological, or cerebral disease • History of lymphopro- liferative disease • Any known malignant disease • Screened for TB | Interventions, dose: D1: INF INF: 3 mg/kg wks 0,2,6 then every 8, dose could be increased to 5 mg/kg at wk 14 based on clinical grounds N: D1: 113 pts; 1,183 infusions Mean age, yrs: D1: 45.7 Sex, % female: D1: 87 Race, % white: NR | Mean disease duration, yrs: D1: 13.6 TJC, mean: D1: 21.3 SJC, mean: D1: 10.8 DMARD use, %: NR PRE use, %: D1: 59 MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR MTX use: D1: 100 | • 104 infusion-related reactions out of 1183 infusions performed (8.8%) and 60 of 113 pts (53%) experienced at least one reaction during course of txt • Infusion related reactions; Allergic-45 (3.8%); Cardiopulmonary-35 (3.0%); Misc.-24 (2.0%) • Reactions following pretxt or not with diphenhydramine at infusions 3 and 4 • Pretreated 14.7% vs. Not pretreated 14.3% | Overall: D1: 8.8 Headache: D1: 9 | Overall Attrition Rate, %: ITT Analysis: NA Quality Rating: Fair
Author, yr: Weaver et al., 2006 Country, Setting: US, Rheumatology practices (509) Funding: Immunex Corporation Research Objective: To evaluate effectiveness of select biologics, MTX (MTX), and other DMARDs in management of adult RA in routine clinical practice Study Design: Prospective cohort study Overall N: 5,397 Study Duration: 12 mos | Inclusion Criteria: • Age: 18 or older • Diagnosed with RA according to ACR criteria: 1987 ACR • Pts requiring a change in RA txt Exclusion Criteria: • Pregnant or lactating • Active infection, • Concurrent enrollment in a clinical trial | Interventions, dose: D1: MTX (10 to 15 mg/wk) D2: ETA (50 mg/wk) D3: ETA (50 mg/wk) +MTX D4: INF (3.8 mg/8wks) D5: INF (3.8 mg/8wks) + MTX (15 mg/wk) D6: LEF (20 mg/d) D7: LEF (20 mg/d) +MTX (15 mg/wk) D8: MTX (15 mg/wk) +HCQ (400 mg/d) D9: MTX (15 mg/wk) +HCQ (400 mg/d) +SSZ (2000 mg/d) N: D1: 941 D2: 1251 D3: 1783 D4: 120 D5: 540 D6: 204 D7: 191 D8: 325 D9: 42 Mean age, yrs: D1: 56.8 D2: 53.2 D3: 52.6 D4: 60.2 D5: 58.5 D6: 57.7 D7: 55.5 D8: 53.8 D9: 47.8 Sex (% female D1: 75 D2: 75 D3: 79 D4: 71 D5: 77 D6: 76 D7: 78 D8: 80 D9: 79 Race, % white: D1: 77 D2: 81 D3: 81 D4: 78 D5: 81 D6: 78 D7: 82 D8: 83 D9: 79 | Mean disease duration, yrs: D1: 3.5 D2: 9.2 D3: 7.7 D4: 10.6 D5: 9.5 D6: 10.1 D7: 7.4 D8: 4.6 D9: 7.2 TJC, mean: D1: 13 D2: 13.4 D3: 13.3 D4: 14.8 D5: 3.9 D6: 12.8 D7: 12.2 D8: 11.8 D9: 10.1 SJC, mean: D1: 11.3 D2: 11.1 D3: 11.5 D4: 13.9 D5: 12.0 D6: 11.8 D7: 11.4 D8: 9.2 D9: 10.2 DMARD use, %: D1: 25 D2: 75 D3: 96 D4: 85 D5: 96 D6: 75 D7: 95 D8: 78 D9: 88 Corticosteroid use, % D1: 53 D2: 48 D3: 51 D4: 63 D5: 57 D6: 48 D7: 56 D8: 50 D9: 48 MTX naive, %: NR Treatment resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR RF factor positive: D1: 72 D2: 65 D3: 69 D4: 68 D5: 69 D6: 75 D7: 73 D8: 71 D9: 71 | mACR20, %: D1: 37 D2: 41 D3: 43 D4: 26 D5: 35 Adjusting for baseline covariates D3: vs. D1(OR 1.29, 95% CI, 1.09–1.52; P < 0.01) D2 vs. D1 (OR 1.23, 95% CI, 1.02–1.47; P < 0.05) D1 vs. D5 (OR 0.96 CI 0.76–1.21 p = 0.72) D1 vs. D4 (OR 0.66, 95% CI, 0.43–1.02; P = 0.06) Mean change HAQ improvement, % D1: 7 D2: 17 (P < 0.001) D3: 17 (P < 0.001) mACR20 response D5 vs. D1: (OR 0.68, 95% CI, 0.48–0.96; P < 0.05) D6 vs. D1 (OR 0.76, 95% CI, 0.54–1.06; P = 0.11) D8 vs, D1: (OR 0.94, 95% CI, 0.72–1.23; P = 0.64) D9 vs. D1: (OR 0.57, 95% CI, 0.27–1.18; P = 0.13) SJC % improvement D1 vs D1: 34 (N/A) D2 vs. D1: 53 (P < 0.0001) D4 vs. D1: 29 (P = NS) D3 vs. D1: 55 (P < 0.0001) D5 vs D1:48 (P < 0.01) TJC % improvement D1: 34 (N/A) D2 vs. D1: 53% (P < 0.001) D4 vs D1: 29% (P = NS) D3 vs D1: 55% (P < 0.0001) D5 vs D1: 48% (P = NS) HAQ % improvement amongst pts < 65 yrs D2: 22 D4: 4 (P = NR) | NR | Overall Attrition Rate, %: 33.2 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Weinblatt et al., 2006 Country, Setting: NR Funding: Abbott Labs Research Objective: To evaluate efficacy and safety of adalimumab plus MTX (MTX) given for up to 4 yrs in pts with active, longstanding rheumatoid arthritis Study Design: Uncontrolled open-label extension of ARMADA trial Overall N: 262 in extension Study Duration: up to 4 yrs (6 mos blinded) | Inclusion Criteria: • Age: ≥ 18 yrs • Diagnosed with RA according to ACR criteria • Previous use of DMARDs • MTX for at least 6 mos • 9 tender and 6 swollen joints Exclusion Criteria: NR | Interventions, dose: Adalimumab + MTX N: Overall: 262 Mean age, yrs: Overall: 55 Sex, % female: Overall: 76 Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤ 3 yrs): NR Baseline DAS, mean: NR NR | • Serious infections occurring during open label txt and blinded period were similar (2.03 vs. 2.30 events per 100 PY, respectively) • Rates of all other adverse events were similar between blinded and extension phases | Serious Infections: D1: 2.03/100 pts CHF: D1: 0.11/100 pts Malignancies: D1: 19 cancers: • 5 non-melanoma skin • 4 GI • 2 prostate | Overall Attrition Rate, %: • 38% • 162/262 used for analysis with a mean txt time of 3.4 yrs however 147 completed 4 yrs of txt ITT Analysis: NA Quality Rating: Fair
Author, yr: Weinblatt et al., 2006 Country, Setting: Multinational Multicenter ASSURE Trial Funding: Bristol-Myers Squibb Research Objective: To assess safety of ABA in pts with active RA who had been receiving 1 traditional nonbiologic and/or biologic DMARDs Study Design: RCT Overall N: 1456 Study Duration: One yr | Inclusion Criteria: • Age: ≥ 18 • Diagnosed according to ACR criteria • I class I–IV • DMARDs • Stable, low-dose oral Css and/or stable doses of NSAIDs • Stable CHF, asthma, COPD, and DM Exclusion Criteria: • Pregnant or lactating • History of TB • Impaired renal or hepatic system • Mycophenolate mofetil, CYP, other calcineurin inhibitors, D- penicillamine, cyclophos- phamide, apheresis unstable or uncontrolled diseases, or any autoimmune disorder as the main diagnosis • Bacterial infections • Active herpes zoster < 2 mos, hepatitis B or C | Interventions, dose: D1: Non-bio and ABA D2: Non-bio and placebo D3: Bio and ABA D4: Bio and placebo ABA: 500 mg a body weight <60 kg, 750 mg for 60–100 kg, and 1 gram for >100 kg N: D1: 856 D2: 418 D3: 103 D4: 64 Mean age, yrs: D1: 52.2 D2: 52.0 D3: 54.6 D4: 52.8 Sex, % female: D1: 83.1 D2: 83.7 D3: 75.7 D4: 75.0 Race, % white: D1: 83.9 D2: 83.3 D3: 97.1 D4: 92.2 | Mean disease duration, yrs: D1: 9.5 D2: 9.5 D3: 11.3 D4: 11.3 TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR HAQ: D1: 1.5 D2: 1.5 D3: 1.5 D4: 1.6 | • ABA and placebo groups exhibited similar frequencies of adverse events (90% and 87%, respectively), serious adverse events (13% and 12%, respectively), and discontinuations due to adverse events (5% and 4%, respectively) • Serious infections were more frequent in the ABA group than in the placebo group (2.9% vs. 1.9%) • Serious adverse events occurred more frequently in the subgroup receiving ABA plus a biologic agent (22.3%) than in other subgroups (11.7–12.5%) • Sub analysis of Pts w/COPD and DM (placebo vs. ABA)(%) COPD • Overall AEs 88.2 vs.97.3 • Respiratory oriented 23.5 vs. 23.5 • SAEs 5.9 vs. 27 DM • Overall AEs 90.3 vs. 93.8 • Infections 58.1 vs. 50.8 • SAEs 12.9 vs. 21.5 Change in HAQ from baseline • Placebo −0.25 vs. ABA- 0.46 (P < 0.001) | Overall: D1: 89.7 D2: 86.1 D3: 95.1 D4: 89.1 SAEs: D1: 11.7 D2: 12.2 D3: 22.3 D4: 12.5 Infections: D1: 54.9 D2: 53.6 D3: 65.0 D4: 57.8 Serious Infections: D1: 2.6 D2: 1.7 D3: 5.8 D4: 1.6 Malignancies: D1: 3.2 D2: 3.8 D3: 6.8 D4: 1.6 | Overall Attrition Rate, %: 15 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Westhovens et al., 2006 START Trial Country, Setting: Multinational, multicenter Funding: Centocor Research Objective: The risk of serious infections in INF therapy, and safety in combination with background txts during 1 yr in pts with RA with various comorbidities Study Design: RCT Overall N: 1084 Study Duration: 54 wks of which 22 wks wast RCT then open label extension | Inclusion Criteria: • Adults w/RA according to ACR criteria • MTX ≥ 3 mos Chloroquine, AZA, penicillamine, oral or intramuscular gold • HCQ, SSZ, LEF, CYP, oral Css, or NSAIDS Exclusion Criteria: • TB • Opportunistic or serious infections, HIV, lympho-proliferative disease or malignancy • CHF investigational drug (3 mos or 5 half-lives, whichever was greater), with cyclophosphamide, nitrogen mustard, chlorambucil, or other alkylating agents more than 5 mg/kg cyclosporine, or biologic | Interventions, dose: D1: Placebo + MTX (up to 25 mg/wk) D2: INF 3 mg/kg (at wks 0, 2, 6, and 14) + MTX (up to 25 mg/wk) D3: INF 10 mg/kg (at wks 0, 2, 6, and 14) + MTX (up to 25 mg/wk) D4: D2 + D3 N: D1: 363 D2: 360 D3: 361 Mean age, yrs: D1: median 52 D2: 53 D3: 52 Sex, % female: D1: 83.2 D2: 80.0 D3: 77.8 Race, % white: NR | Median disease duration, yrs: D1: 8.4 D2: 7.8 D3: 6.3 TJC, mean: D1: 22 D2: 22 D3: 22 SJC, mean: D1: 15 D2: 15 D3: 15 DMARD use, %: D1: 70 D2: 70.8 D3: 69.8 Corticosteroid use, %: D1: 59.2 D2: 59.2 D3: 59 MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR Median HAQ score: D1: 1.5 D2: 1.5 D3: 1.5 % RF positive: D1: 80.7 D2: 82.8 D3: 76.8 | At week 22 ACR20 response, % D1: 26 D2: 58 D3: 61 (P < 0.0001) ACR50 response, % D1: 9.7 D2: 32.1 D3: 35.4 (P < 0.0001) ACR70 response, % D1: 4.7 D2: 14.0 D3: 16.1 (P < 0.0001) DAS28, (+/−) D1: 4.4 (1.4) D2 and D3: 3.4 (1.3) (P < 0.001) Remission, % D1: 14 D2: 31 D3: 32 (P < 0.0001) | Overall: D1: 66.2 D2: 69.7 D3: 72.3 D4: 71.0 SAEs: D1: 7.5 D2: 7.8 D3: 7.5 D4: 7.8 Serious Infections: D1: 1.7 D2: 1.7 D3: 5.0 D4: 3.3 Cardiovascular Events: D1: 3.3 D2: 4.5 D3: 5.9 D4: 5.2 Headache: D1: 6.1 D2: 9.7 D3: 10.2 D4: 10.0 Hepatotoxicity (ALT increase): D1: 2.8 D2: 3.6 D3: 5.3 D4: 4.4 Malignancies: D1: 1.7 D2: 4.2 Nausea: D1: 8.0 D2: 6.4 D3: 6.4 D4: 6.4 URTI: D1: 10.5 D2: 9.7 D3: 11.9 D4: 10.8 UTI: D1: 0 D2: 0 D3: 0.6 D4: 0.3 | Overall Attrition Rate, %: 17.1 ITT Analysis: Yes Quality Rating: Good
Author, yr: Wolfe and Michaud, 2004 Country, Setting: US, 908 practices Funding: National Data Bank for Rheumatic Diseases (US) funded by pharma Research Objective: The rate of and standardized incidence ratio for lymphoma in pts with RA and in RA patient subsets by txt group Study Design: Prospective cohort study Overall N: 18,572 Study Duration: Up to 3 yrs | Inclusion Criteria: • Participants in National Data Bank for Rheumatic Diseases (NDB) long-term study of outcomes of RA • • Cases were identified from this group as those who developed lymphoma during the 2 ½ yr observational period Exclusion Criteria: • • Cases were rejected if not enough information could be obtained to verify patient’s lymphoma | Interventions, dose: D1: INF (varied) D2: ETA (varied) D3: MTX (varied) D4: No MTX/No Biologics N: D1: 6433 D2: 2729 D3: 5593 D4: 4474 Mean age, yrs: D1: 60.7 D2: 56.4 D3: 61.2 D4: 60.4 Sex, % female: D1: 77.3 D2: 79.3 D3: 75.7 D4: 75.7 Race, % white: NR | Mean disease duration, yrs: D1: 13.7 D2: 14.1 D3: 13.5 D4: 13.5 TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 1.2 D2: 1.2 D3: 1.1 D4: 1.0 VAS QoL: D1: 65.8 D2: 64.3 D3: 66.7 D4: 65.9 Pain: D1: 4.2 D2: 4.3 D3: 3.7 D4: 3.9 | • SIR for whole population regardless of txt was 1.9 (95%CI, 1.3–2.7); indicating a greater risk for lymphoma in pts with RA • • SIR for pts taking biologics (INF or ETA) was 2.9 (95%CI, 1.7–4.9). • • No significant differences were observed between txt groups • • Only 233 pts received AKA and no lymphomas occurred in this group • • Overall, lymphoma incidence rate per 100,000 PY was 99 (95%CI,69–142); for various durations of RA, rates were: 0–5 yrs: 171 (95%CI,82–360), 5–10 yrs: 70 (95%CI,29–168), 10–15 yrs: 20 (95%CI,3– 145), >15 yrs: 121 (95% CI, 74–198) | NR | Overall Attrition Rate, %: NA ITT Analysis: NA Quality Rating: Fair
Author, yr: Wolfe and Michaud, 2004 Country, Setting: US, multicenter (National Data Bank for Rheumatic Diseases) Funding: Centocor, Inc Research Objective: To determine frequency of heart failure in pts with RA, and to determine its predictors, particularly use of anti-TNF therapy Study Design: Retrospective cohort study Overall N: 15,739 (RA plus OA subjects) Study Duration: | Inclusion Criteria: • • Participation in National Data Bank for Rheumatic Diseases study of outcomes of arthritis; patient at participating rheumatology clinic Exclusion Criteria: • • NR | Interventions, dose: D1: Any Anti-TNF D2: INF D3: ETA D4: No anti-TNF D5: Total Population Overall N: NR Mean age, yrs: D1: 60 D2: 61.5 D3: 56.7 D4: 61.5 D5: 51 Sex, % female: D1: 78 D2: 77 D3: 80 D4: 76 D5: 77 Race, % white: D1: 95 D2: 96 D3: 92 D4: 92 D5: 94 | Mean disease duration, yrs: D1: 14.2 D2: 13.8 D3: 15.2 D4: 15.5 D5: 14.9 TJC, mean: NR SJC, mean: NR DMARD use, %: Overall: 86 PRE use (%) D1: 47 D2: 49 D3: 39 D4: 33 D5: 39 MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 3.7 D2: 3.7 D3: 3.6 D4: 3.5 D5: 3.6 MTX use: D1: 67 D2: 76 D3: 44 D4: 47 D5: 56 | Heart Failure • • 461 cases in 13,171 pts with RA (overall risk of 3.5%); after adjusting for demographic characteristics; Risk: 3.9% (95% CI,= 3.4% to 4.3%) • • Among all cases of heart failure, pts receiving anti- TNF therapy were less likely to have heart failure than those not receiving anti-TNF therapy (−1.2%; 95% CI,−1.9 --0.5%) • • Overall, adjusted frequency of heart failure was 2.8% in those treated with anti-TNF vs. 3.9% in remaining pts (P = 0.03) • • Frequency of heart failure was 5.2% in men and 3.0% in women • • In examining incident cases of heart failure in pts under age 50, no increase was found (0/1569 pts using anti- TNF vs. 3/1401 not using anti-TNF therapy) | NR | Overall Attrition Rate, %: NR ITT Analysis: NA Quality Rating: Fair
Author, yr: Wolfe et al., 2006 Country, Setting: US, Rheumatology Clinics Funding: Bristol-Meyers- Squibb Research Objective: To evaluate txt of RA and risk of hospitalization for pneumonia Study Design: Prospective cohort study Overall N: 16,788 Study Duration: 3.5 yrs | Inclusion Criteria: • Participants in NDB longitudinal study of RA outcomes including 5,317 enrolled as part of an INF safety registry and 1,852 as part of a LEF safety registry • Other meds allowed Exclusion Criteria: • • NA | Interventions, dose: D1: Cohort Prednisone MTX LEF SSZ Hydroxychlorquine ETA INF Adalimumab Other various RA txts N: NR Mean age, yrs: D1: 62 Sex, % female: D1: 77.2 Race, % white: D1: 89.7% white, 4.8% black, 3.0% Hispanic, 1.0 Asian/Pacific Islander, 1.1% American Indian or Alaskan native, 0.5% Other | Mean disease duration, yrs: D1: 16.3 TJC, mean: NR SJC, mean: NR DMARD use mean (lifetime #): D1: 3.3 Corticosteroid use, %: D1: 38.1 MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR | • Effect of txt variables on risk of pneumonia (adjusted for demographic variables- age, sex, smoking, education, and enrollment) • Prednisone HR 1.7 [95% CI, 1.5–2.1]) • LEF HR 1.3 [95% CI, 1.0–1.5], P = 0.036) • SSZ HR 0.7 [95% CI, 0.4–1.0], P = 0.053) • ETA HR 0.8 [95% CI, 0.6–1.0], P = 0.051) • INF HR 1.1 [95% CI, 0.9–1.4], P = 0.322) • Adalimumab HR 1.1 [95% CI, 0.6–1.9], P = 0.747) • MTX HR 1.0 [95% CI, 0.8–1.2], P = 0.927) • Hydroxychloroquine HR 0.9 [95% CI, 0.7–1.2], P = 0.481) | NR | Overall Attrition Rate, %: NA ITT Analysis: NA Quality Rating: Fair
Author, yr: Wolfe, 2004 Country, Setting: Multinational, multicenter Funding: Centocor, Inc Research Objective: To determine baseline rate of TB in RA prior to introduction of INF and to determine rate of TB among those currently receiving INF Study Design: Prospective cohort study with historic control Overall N: 17,242 Study 1: 10,782 Study 2: 6,460 Study Duration: 3 yrs | Inclusion Criteria: • • Diagnosed with RA according to • ACR criteria • Use of INF Exclusion Criteria: • • NA | Interventions, dose: D1: Study 1 D2: Study 2 INF: varied N: D1: 10782 D2: 6640 Mean age, yrs: D1: 59.8 D2: 61.4 Sex, % female: D1: 76.9 D2: 73.5 Race, % white: D1: 90.9 D2: 94.4 | Mean disease duration, yrs: D1: 13.2 D2: 14 TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: D1: 54.6 D2: 50.4 MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR MTX: D1: 47.9 D2: 74.6 | • • In pre-INF group, 1 case of TB developed during 16,173 PY of follow-up, yielding a rate of 6.2 cases (95% CI,1.6–34.4) per 100,000 patient yrs • In INF-group, TB incidence rate among pts was 61.9 cases per 100,000 patient yrs • None of TB pts had undergone a TB skin test and no cases of TB occurred in 44-59% that had received test | NR | Overall Attrition Rate, %: NA ITT Analysis: NA Quality Rating: Fair
Author, yr: Zink, 2005 Country, Setting: Germany, clincal Funding: Essex Pharma, Wyeth Pharma, Amgen, and Abbott Research Objective: To compare drug continuation rates in pts. with RA who start on a biological agent or on a DMARD after previous DMARD failure Study Design: Retrospective cohort study Overall N: 1,523 Study Duration: 1 yr | Inclusion Criteria: • • Age: 18 to 75 • • Diagnosed with RA according to ACR criteria • Previous use of DMARDs: at least 2 Exclusion Criteria: NR | Interventions (dose): D1: ETA D2: INF D3: AKA D4: Total Control Group D5: LEF D6: LEF + MTX Dosages NR N: D1: 511 D2: 343 D3: 70 D4: 599 D5: 120 D6: 141 Mean age, yrs: D1: 53.7 D2: 53.6 D3: 54.3 D4: 56.5 D5: 58 D6: 57.4 Sex, % female: D1: 77.9 D2: 71.1 D3: 77.1 D4: 82.8 D5: 85.8 D6: 78.0 Race, % white: NR | Mean disease duration (yrs): D1: 9 D2: 8.5 D3: 13 D4: 6 D5: 9 D6: 7 TJC, mean: D1: 13.3 D2: 12.6 D3: 12.6 D4: 10 D5: 10.6 D6: 10.9 SJC, mean: D1: 10.4 D2: 10.7 D3: 10.2 D4: 7.7 D5: 7.4 D6: 8.5 DMARD use (#): D1: 3.9 D2: 3.7 D3: 4.2 D4: 2.1 D5: 2.4 D6: 2.2 Corticosteroid use, %: NR MTX naive, %: NR Txt resistant, %: NR Pts. with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 6.1 D2: 6 D3: 6.1 D4: 5.4 D5: 5.5 D6: 5.6 MTX use: D1: 91.2 D2: 92.1 D3: 78.6 D4: 68.7 D5: 94.2 D6: 90.7 | Continuation rates D1 and D2 similar D3 significantly lower Txt continuation at 1 yr, % D1: 68.6 ETA+ MTX: 71.6 D2: 65.4 D6: 66.2 D3: 59 AKA vs. ETA; P = 0.004; ANA vs. INF; P = 0.03 Txt discontinuation because of adverse events, %: D1: 12.6% ETA+MTX 13.3 D2: 18.7 INF+MTX: 18.2 D3: 16.3 Txt discontinuation because of lack of efficacy, %: D1: 19.9 ETA + MTX:16.9; D2: 45 INF+MTX: 17.9 D3: 29.6 | NR | Overall Attrition Rate, %: N/A ITT Analysis: N/A: registry Quality Rating: Good
Author, yr: Schaible et al., 2000 Country, Setting: US, safety database of efficacy trials Funding: Centocor Research Objective: Long term safety of infliximab Study Design: Observational Overall N: 963 Study Duration: Up to 3 yrs | Inclusion Criteria: 12 clinical trials Exclusion Criteria: NR | Interventions: Infliximab N:963 Mean age, yrs: NR Sex, % female: NR Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Treatment resistant %: NR Patients with Early RA (≤3 yrs): NR Baseline DAS, mean: NR | • Acute infusion reactions (headache, fever, chills, urticaria, chest pain: infliximab 17% versus placebo 7%; P = NR • 0.5% of infliximab pts had severe infusion reactions • Less than 2% discontinued treatment because of infusion reactions Infections: • Infliximab 26% over 27 wks of follow-up versus placebo 16% over 20 wks of follow-up) • Incidence of serious infections per patient-yr infliximab 0.064 versus placebo 0.114 | See outcomes | Overall Attrition Rate, %: ITT Analysis: Not applicable Quality Rating: Fair
Author, yr: Schiff et al., 2006 Country, Setting: mulitnational Multicenter Funding: Abbott Labs Research Objective: To assess safety of adalimumab in global clinical trials and postmarketing surveillance among pts with rheumatoid arthritis Study Design: Retrospective cohort study; postmarketing surveillance Overall N: 10,050 (12506 PY) Study Duration: Varied | Inclusion Criteria: • Pts from RCTs, open label extensions, and two phase IIIb open label trials were and post-marketing spontaneous reports of adverse events in US Exclusion Criteria: NA | Interventions, dose: NR N: 10,050 Mean age, yrs: NR Sex, % female: NR Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR | Rates per 100 PY: • TB: 0.27 • Histoplasmosis: 0.03 • Demyelinating diseases: 0.08 • Lymphoma: 0.12 • SLE/lupus-like syndrome: 0.10 • Congestive heart failure: 0.28 | NA | Overall Attrition Rate, %: NA ITT Analysis: NA Quality Rating: Fair

Evidence Table 9

KQ3. Rheumatoid arthritis systematic reviews: harms, tolerability, adverse effects, or adherence

Study Characteristics | Inclusion and Exclusion Criteria | Characteristics and Interventions | Baseline Disease and Treatment Characteristics | Health Outcomes | Adverse Events, % | Analysis and Quality Rating
Author, year, country, funding: Bongartz, 2006, multinational, Mayo foundation, Abbott & Centocor Study Design: Systematic literature search with meta-analysis Aims of the Review: • To assess extent to which anti-TNF antibody therapy may increase risk of serious infection and malignancies in pts with RA by performing a meta-analysis • To derive estimates of sparse harmful events occurring in randomized trials of anti-TNF therapy Number of Pts: 5014 (9 trials) | Studies included: • Keystone (2004) • St Clair (2004) • Furst (2003) • Lipsky (2000) • van de Putte (2003) • Weinblatt (2003) • Maini (1998) • van de Putte (2004) • Westhovens (2004) Characteristics of included studies: • RCTs of INF and ADA in which pts had ACR-diagnosed RA and were randomized to anti-TNF vs. placebo (or anti-TNF antibody + traditional DMARD vs. placebo + traditional DMARD) • Both pt and observer were masked • Trial had to be at least 12 wks in duration Characteristics of included populations: • Pts with an ACR diagnosis of RA who were randomized to receive Anti-TNF or placebo Characteristics of interventions: Anti-TNF (dosing varied) or Control | • In pts with RA, anti-TNF treatment leads to increased risk of serious infections and a dose-dependent increased risk of malignancies. Serious infections reported in 126 anti-TNF- treated pts vs. 26 control group pts (OR, 2.0; 95% CI, 1.3–3.1) • Malignancies reported in 24/3493 (0.8%) pts who received > 1 dose of anti-TNF vs. 2/1512 (0.2%) pts on control • Pooled OR for malignancies in anti-TNF group vs. placebo group = 3.3 (95% CI, 1.2–9.1) • Number needed to harm was 154 (95% CI 91–500) for 1 additional malignancy within a treatment period of 6 to 12 months. For serious infections, the number needed to harm was 59 (39–125) within a treatment period of 3 to 12 months | Overall AEs reported: • Malignancy: Anti-TNF (23/3192) Control (3/1428) OR = 3.3 (95% CI 1.2 – 9.1) • Serious Infections: Anti-TNF (126/3493) Control (26/1512) OR = 2.0 (1.3–3.1) | Publication Bias Assessed: Not reported Heterogeneity Assessed: Yes Standard Method of Study Appraisals: Yes Comprehensive Search Strategy: Yes - briefly describe in box: EMBASE, MEDLINE, Cochrane Library, and electronic abstracts of the annual scientific meetings both the European League Against Rheumatism and the American College of Rheumatology – through December 2005 Quality Rating: Fair
Author, year, country, funding: Gartlehner et al., 2006 US Study Design: Metaanalysis (random effects model); systematic review Aims of the Review: To assess comparative efficacy and safety of biologic agents for RA Number of Patients: ADA: 2,354 ETA: 1,151 INF: 704 AKA:1,039 (#’s refer to 17 sudies used for adjusted indirect comparisons of efficacy) | Studies included: • 26 controlled trials • 18 additional studies assessed safety Characteristics of included studies: • Often limited to 1 year of follow-up • Reported on DAS-28 • Radiographic progression, functional capacity, and QOL Characteristics of included populations: • Narrowly defined populations • Mean age 53.4 • 76% female • 89% caucasion Characteristics of interventions: • All efficacy studies except 1 were funded by the pharmaceutical industry • All 12 weeks plus of duration (for observational studies it was 3 months or greater and 100 or more patients) | • Adjusted indirect comparison indicate no significant differences in efficacy between antiTNF drugs • Anti-TNF drugs appear to be more efficacious than AKA but do not differ among each other. Inddirect comparisons of INF and of anti-TNF drugs as a class compared to AKA yielded a statistically significant greater efficacy on ACR 20 [RR 0.58 (95%CI 0.38–0.90) and RR 0.61 (95% CI 0.39–0.96), respectively], but not ACR 50 • Few studies assessed longterm radiographic outcomes. In general, rate of radiographic progression was significantly lower in patients treated with biologics than in placebo-treated patients, regardless of concomitant DMARD therapy. Similarly, QoL improved significantly for patients treated with biologics | • Because of lack of sound long-term safety data, evidence is insufficient to draw firm conclusions about comparative safety of biologics • Higher rates of injection site reactions for AKA than ADA and ETA (56% vs. 19% vs. 25%) | Publication Bias Assessed: Yes Heterogeneity Assessed: Yes Standard Method of Study Appraisals: Yes Comprehensive Search Strategy: Yes - briefly describe in box: Searched Medline, Embase, Cochrane and International Pharmaceutical Abstracts from 1980–2006. Also explored CDER database. Quality Rating: Good
Author, year, country, funding: Osiri et al., 2002 Multinational Cochrane Collaboration Study Design: Systematic review of RCTs and CCTs Aims of the Review: • To determine efficacy and toxicity of LEF compared to placebo or other DMARDs in txt of RA • Meta-analysis stratified comparison between LEF and Placebo or other DMARDs by outcomes at different length of txts Number of Pts: 1,144 LEF 312 to Placebo 680 to MTX 132 to SSZ Only 920 used in meta-analysis 2 yr extension: LEF:158 SSZ: 60 MTX 101 | Studies included: • 6 trials Characteristics of included studies: • Randomized, double-blind, placebo and/or active controlled Characteristics of included populations: • All with active RA Characteristics of interventions: • 5,10 or 25 mg/d vs placebo or MTX or SSZ | • LEF significantly better than placebo at 6,12 and 24 mos. • LEF vs. MTX • ACR 20: Significantly more responders for MTX than LEF at 12 mos; OR: 1.43 (1.15–1.77) • No significant differences at 2 yrs but more responders with MTX than with LEF; OR 1.28 (0.98–1.67) • ACR 50, ACR 70: differences in ACR 50/70 repsonses between LEF and MTX were NS | • Total withdrawals lower in LEF group (10% greater than Placebo (70/416 vs 18/311)); LEF not diff in efficacy and tolerability than MTX and SSZ, except that LEF was more efficaious than SSZ at 24 mos; AEs+ GI sympotms, elevated liver funcitn tests, alopecia, and infections | Publication Bias Assessed: NR Heterogeneity Assessed: Yes Standard Method of Study Appraisals: Yes Comprehensive Search Strategy: Yes Quality Rating: Good

Evidence Table 10

KQ3. Psoriatic arthritis trials: Harms, tolerability, adverse effects, or adherence

Study Characteristics | Inclusion and Exclusion Criteria | Characteristics and Interventions | Baseline Disease and Treatment Characteristics | Health Outcomes | Adverse Events, % | Analysis and Quality Rating
Author, yr: Antoni et al., 2005; Kavanaugh et al., 2006 IMPACT Study Country, Setting: Multinational 9 clinical sites Funding: NIH; Centocor, Inc.; Schering-Plough Research Institute; Competence Network Research Objective: Efficacy and tolerability of INF for the articular and dermatologic manifestations of active PsA Study Design: RCT Overall N: 104 Study Duration: 50 wks (1–16 wks RCT 16–50 open, all treated with INF) | Inclusion Criteria: • Age ≥ 18 • Failure of 1 or more DMARD • Active peripheral polyarticular arthritis • MTX ≥ 15 mg/wk w/folic acid supplementation • LEF, SSZ, HCQ, intramusculargold, penicillamine, or azathioprinestable for 4 wks • oral corticosteroids (dosage of 10 mg PRE equivalent/d or less) • NSAIDs stable for at least 2 wks Exclusion Criteria: • Monoclonal antibody or fusion protein • History of TB: positive tests for RF or latent TB investigational drug within 3 mos | Interventions: D1: Placebo D2: INF (5mg/kg at wks 0,2,6,14, then every 8 wks) N: D1: 52 D2: 52 Mean age, yrs: D1: 45.2 D2: 45.7 Sex, % female: D1: 42.3 D2: 42.3 Race, % white: NR | Mean disease duration, yrs: D1: 11 D2: 11.7 TJC, mean: D1: 20.4 D2: 23.7 SJC, mean: D1: 14.7 D2: 14.6 DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Txt resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 5.4 D2: 5.5 | ACR50 D1: 0/52 (0.0%) D2: 24/52 (46.2%) ACR70 D1: 0/52 (0.0%) D2: 15/52 (28.8%) Tender joints, number D1: −23.6 D2: 55.2 Swollen joints, number D1: −1.8 D2: 59.9 DAS D1: 2.8 D2: 45.5 P < 0.001 HAQ D1: −1.6 D2: 49.8 P < 0.001 PsARC, % D1: −12 D2: +86 P < 0.001 At week 16 ACR20 D1: 5/52 (9.6%) D2: 34/52 (65.4%) P < 0.001 PsARC, % D1: 21 D2: 75 P < 0.001 PASI75, % D1: 0 D2: 68 P < 0.001 At 50 weeks Total modified vdH-S score sowing no worsening D1: 85% (Placebo/INF) D2: 84% (INF/INF) Change in erosion scores D1: 0.536 (Placebo/INF) D2: 0.921 (INF/INF) (P = 0.780) Change in JSN D1: −0.47 D2: −0.51 (P = 0.211 | Overall: D1: 65 D2: 73 D3: 84 Headache: D1: 3 D2: 4 URTI: D1: 5 D2: 1 | Overall Attrition Rate (%): 5 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Antoni, 2005; Kavanaugh et al., 2006 Country, Setting: Multinational 36 sites in clinics IMPACT2 Study Funding: Centocor Inc and Schering-Plough Research Objective: Efficacy, health related quality of life and physical function in pts with PsA Study Design: RCT Overall N: 200 Study Duration: 14 to 24 wks (pts with inadequate response entered early escape at wk 16) | Inclusion Criteria: • Diagnosed with PsA • Diagnosed at least 6 mos before first infusion of study drug • Inadequate response to current or previous DMARDs or NSAIDs • Pts had to have active plaque psoriasis with at least 1 qualifying target lesion at least 2 cm in diameter • Negative test for RF in their serum • Stable doses of MTX, oral corticosteroids, NSAIDs Exclusion Criteria: • TNF α inhibitors; active or latent TB • Chronic or clinically significant infection, malignancy, or CHF | Interventions: D1: Placebo D2: INF (5 mg/kg at wks 0, 2, 6, 14, 22) N: D1: 100 D2: 100 Mean age, yrs: D1: 46.5 D2: 47.1 Sex, % female: D1: 49 D2: 29 Race, % white: NR | Mean disease duration, yrs: D1: 7.5 D2: 8.4 TJC, mean: D1: 25.1 D2: 24.6 SJC, mean: D1: 14.4 D2: 13.9 DMARD use, %: NR Corticosteroid use, %: D1: 10 D2: 15 MTX naive, %: NR Txt resistant, %: Overall 100 Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR MTX use, %: D1: 45 D2: 47 PASI: D1: 10.2 D2: 11.4 | • Placebo vs. INF (%): • ACR 50 at wk 14 3 vs. 36 (P < 0.001) and wk 24 4 vs. 41 (P < 0.001) • ACR70 at wk 14 1 vs. 15 (P < 0.001) and wk 24 2 vs. 27 (P < 0.001) • PsARC at wk 14 27 vs. 77 (P < 0.001) and wk 24 32 vs. 70 (P < 0.001) • •HAQ improvement at wk 14 – 18.4 vs. 48.6 (P < 0.001) and wk 24 −19.4 vs. 46 (P < 0.001) • •SF-36 (change from baseline) • Physical wk 14 1.1 vs. 9.1 (P < 0.001) and wk 24 1.3 vs. 7.7 (P < 0.001) • Mental wk 14-1.2 vs. 3.8 (P = 0.001) and wk 24 0.4 vs. 3.9 (P = 0.047) • ACR20 at Wk 14 11 vs. 58 (P < 0.001) and Wk 24 16 vs. 54 (P < 0.001) • PASI 50: wk 14: 9 vs. 82 (P <0.01), wk 24: 8 vs. 75 (P <75 (P<0.01); PASI 75 wk 14: 2 vs. 64 (P < 0.01), wk 24: 1 vs. 50 (P < 0.01); • improvement wk 14: 0 vs. 41 (P < 0.01), wk 24: 0 vs. 39 (P < 0.01) • median productivity at 14 wks 9.2% vs. 67.5% (P < 0.0001) • missed workdays at 14 wks 13% vs. 3.7% (P = 0.138) | Overall: D1: 67 D2: 67 SAEs: D1: 6 D2: 9 Infusion or injection reaction: D1: 6 D2: 7 Dizziness: D1: 5 D2: 4 Headache: D1: 5 D2: 6 URTI: D1: 14 D2: 10 | Overall: Attrition Rate (%): Wk 14: NR Wk 24: 7.5 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Kaltwasser et al., 2004 and Nash et al., 2006 Country, Setting: Multinational Multi-center (31) Funding: Aventis Research Objective: Efficacy and safety of LEF versus placebo in pts with PsA and psoriasis Study Design: RCT Overall: N: 190 (ITT = 186) Study Duration: 24 wks | Inclusion Criteria: • Age 18 to 70 • Diagnosed with PsA • NSAIDs or Css (prednisone dose of 10 mg/day or steroid equivalent administered orally) • Discontinue DMARDs, biologics and systemic antipsoriatic txt 28 days Exclusion Criteria: • Pregnant or lactating; leflunomide • Impaired renal or hepatic system • Nonpsoriatic inflammatory joint disease or arthritis onset < 16 yrs • RH factor +, rheumatoid nodules, serious infections, malignancy, or CVD, HIV, hepatitis B or C antigen positivity, guttate, pustular, or erythrodermic forms of psoriasis, body weight <45 kg • Impaired bone marrow function; history of drug or alcohol abuse | Interventions: D1: Placebo D2: LEF N: D1: 91 D2: 95 Mean age, yrs: Drug 1: 46.9 Drug 2: 48.6 Overall Sex, % female: D1: 37.4 D2: 42.1 Race, % white: D1: 95.6 D2: 97.9 | Mean disease duration, yrs: D1: 10 D2: 11 TJC, mean: NR SJC, mean: NR DMARD use, %: D1: 49.5 D2: 61.1 Corticosteroid use, %: D1: 9.9 D2: 15.8 DMARD naive, %: D1: e 50.5 D2: 38.9 Txt resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR | • 56 of 95 leflunomide-treated pts (58.9%; 95% CI, 48.4–68.9) and 27 of 91 placebo-treated pts (29.7% [95% CI, 20.6–40.2]) were classified as responders by PsARC (P < 0.0001) Change in HAQ total score • Placebo (N:90) −0.05 ± 0.46 (P = 0.0267) • Leflunomide (N:94) −0.19 ± 0.51 Change in PASI score • Placebo (N:90) −0.6 ± 6.1 P = 0.0030 • Leflunomide (N:92) −2.1 ± 5.9 Change in DLQI total score • Placebo (N:89) −0.2 ± 5.1 P = 0.0173 • Leflunomide (N:90) −1.9 ± 5.1 | Overall: D1: 76.1 D2: 85.4 SAEs: D1: 5.4 D2: 13.5 Serious Infections: D1: 0 D2: 0 Diarrhea: D1: 13.0 D2: 24.0 Headache: D1: 7.6 D2: 11.5 Nausea: D1: 8.7 D2: 9.4 | Overall Attrition Rate (%): 47.9% ITT Analysis: Yes Quality Rating: Fair
Author, yr: Mease et al., 2000 Country, Setting: US, single center in Seattle Funding: Immunex Corp. Research Objective: To study efficacy and safety of etanercept in pts with psoriatic arthritis and psoriasis Study Design: RCT Overall N: 60 Study Duration: 12 wks | Inclusion Criteria: • Age 18 to 70 • Diagnosed with PsA according to: ≥ 3 swollen, tender, or painful joints • Inadequate response to NSAIDs • Hepatic transasminase concentrations no greater than 2x upper limit of normal • Hemoglobin 85 g/L or higher • Platelet count 125,000 per mL or more and serum creatinine 152-4 mmol/L or below • MTX ≤ 25 mg/wk and stable for 4 wks • Corticosteriods if the dose ≤ 10 mg/d of PRE, stable for at least 2 wks and maintained at a constant dose throughout study Exclusion Criteria: • Evidence of skin conditions other than psoriasis | Interventions: D1: Placebo D2: ETA (25mg 2x wkly) N: D1: 30 D2: 30 Mean age, yrs: D1: 43.5 D2: 46 Sex, % female: D1: 40 D2: 47 Race, % white: D1: 83 D2: 90 | Mean disease duration, yrs: D1: 9.5 D2: 9 TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: D1: 40 D2: 20 MTX naive, %: NR Txt resistant, %: Overall 100 Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR MTX: D1: 47 D2: 47 | • PsARC ETA 26 (87%) vs. Placebo 7 (23%) P < 0.0001 95% CI, 44–83; ACR50 ETA 15 (50%) vs. Placebo 1 (3%) P = 0.0001 95% CI, 28–66; • ACR70 ETA 4 (13%) vs. Placebo 0 (0%) P = 0.0403 95% CI, 1–26; • HAQ ETA 0.1 (0,1) vs. Placebo 1.3 (0.9,1.6) P < 0.001 • •ACR20 was achieved by 73% ETA treated pts compared with 13% placebo treated pts (P < 0.0001) • Median % improvements in tender and swollen joint counts at 12 wks ETA 75% and 72% respectively vs. placebo 5% worsening and 19% improvement; disability according to HAQ significantly more improved in ETA than placebo (83% vs. 3%, P < 0.0001) • 26% of ETA vs. 0 of placebo pts achieved 75% improvement in PASI at 12 wks (P = 0.0154); similar differences between ETA and placebo also seen at 25% and 50% improvements in PASI | SAEs: D1: 0 D2: 3.3 Infusion or injection reaction: D1: 20 D2: 3 Headache: D1: 13 D2: 10 URTI: D1: 57 D2: 57 | Overall Attrition Rate (%): 6.6% ITT Analysis: Yes Quality Rating: Fair
Author, yr: Mease et al., 2004; Mease et al., 2006 Country, Setting: US 17 sites Funding: Immunex Research Objective: Safety, efficacy, and effect on radiographic progression of ETA in pts with PsA Study Design: RCT Overall N: 205 Study Duration: 24 wks (with 48 wk open-label phase) | Inclusion Criteria: • Age 18 70 • Diagnosed with PsA ≥3 swollen and 3 tender joimts • Inadequate response to NSAID • At least one of PsA subtypes: distal interphalangeal joint involvement, polyarticular arthritis, arthritis mutilans, asymmetric peripheral arthritis, or ankylosing spondylitis-like arthritis • Stable plaque psoriasis with a qualifying lesion • MTX therapy (stable 2 mo ≤ 25 mg/wk) • Css (stable 4 wks ≤ 10 mg/d of prednisone) Exclusion Criteria: • Oral retinoids, topical vitamin A or D analog preparations, and anthralin | Interventions: D1: placebo D2: ETA (25 mg 2x wkly) N: D1: 104 D2: 101 Mean age, yrs: D1: 47.3 D2: 47.6 Sex, % female: D1: 55 D2: 43 Race, % white: D1: 91 D2: 90 | Mean disease duration, yrs: D1: 9.2 D2: 9 TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: D1: 15 D2: 19 MTX naive, %: NR Txt resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR MTX use, %: D1: 41 D2: 42 Sharp: D1: 18.3 D2: 25.89 | • At 12 wks, 59% of ETA pts met ACR20 criteria compared with 15% placebo pts (P < 0.0001) • 23% of ETA pts eligible for psoriasis evaluation achieved at least 75% improvement in psoriasis area and severity index, compared with 3% of placebo pts (P = 0.001) • 12 mos; the mean annualized rate of change over one yr of txt in modified Sharp score was −0.03 unit, compared with 1.00 unit in the placebo (P = 0.0001) • HAQ- improvement from baseline in ETA group 54% vs. 6% of placebo group (P < 0.0001) • 72% & 70% of ETA achieved PsARC at 12 and 24 wks, respectively, compared with 31% and 23% of placebo pts | SAEs: D1: 3.9 D2: 4 Infusion or injection reaction: D1: 9 D2: 36 Headache: D1: 5 D2: 8 URTI: D1: 23 D2: 21 UTI: D1: 6 D2: 6 | Overall Attrition Rate (%): 19.5 ITT Analysis: Yes Quality Rating: Fair
Author, yr: Mease et al., 2005 Country, Setting: Multinational, multi-clinic (50) ADEPT Study Funding: Abbott Laboratories Research Objective: Safety and efficacy of ADA compared with placebo in txt of active psoriatic arthritis Study Design: RCT Overall N: 313 Study Duration: 24 wks | Inclusion Criteria: • Age ≥ 18 • Moderate to severe PsA • Active psoriatic skin lesions or a documented history of psoriasis • Inadequate response or intolerance to NSAIDs • MTX ≥ 3 mos with stable dose 4 wks Exclusion Criteria: • CYP, tacrolimus, DMARDs, or oral retinoids (4 wks) • Topical txts for psoriasis within 2 wks, other than medicated shampoos or low-potency topical steroids • Anti-TNF • History of TB • Central nervous system demyelinating disease • Listeriosis, or severe infection within 30 ds or oral antibiotics within 14 ds | Interventions: D1: placebo D2: ADA (40mg every other wk) N: D1: 162 D2: 151 Mean age, yrs: D1: 49.2 D2: 48.6 Sex, % female: D1: 45.1 D2: 43.7 Race, % white: D1: 93.8 D2: 97.4 | Mean disease duration, yrs: D1: 9.2 D2: 9.8 TJC, mean: D1: 25.8 D2: 23.9 SJC, mean: D1: 14.3 D2: 14.3 Mean number previous DMARDS: D1: 1.5 D2: 1.5 Corticosteroid use, %: NR MTX naive, %: NR Txt resistant, %: NR Pts with Early RA (≤3 yrs): NR Baseline PASI (mean): D1: 8.3 D2: 7.4 MTX use: D1: 50 D2: 51 Baseline HAQ: D1: 1.0 D2: 1.0 | • PsARC ADA 60% wk. vs.placebo 23% • ACR50 ADA, 39% vs. placebo, 6% (P < 0.001) • ACR70 ADA, 23% vs. placebo, 1% (P < 0.001) • The PASI75 ADA 59% vs. placebo 1% (P < 0.001) (N:69 per group). • HAQ DI change placebo −0.1 ± 0.4 vs. ADA −0.4 ± 0.5 (P < 0.001) • ACR20 ADA 57% vs. placebo 15% (between-group difference 42%, 95% CI, 31–52%; P < 0.001). • Mmean change in modified total Sharp was −0.2 for ADA versus placebo (P < 0.001) • Erosion scores (mean change ADA 0.0 vs. placebo 0.6) and JSN scores (mean change ADA −0.2 vs. placebo 0.4) (P < 0.001 for both) • SF-36: SF-36 PCS; change in baseline to wk 12 for placebo vs ADA; 1.4 vs 9.3 (P < 0.001) • Change in baseline to wk 24; 1.4 vs 9.3 (P < 0.001) • SF-36 MCS • Change in baseline to wk 12; 1.2 vs 1.6 (P NS) • Change in baseline to wk 12; 0.6 vs 1.8 (P NS) | Infusion or injection reaction: D1: 3.1 D2: 6.6 Headache: D1: 8.6 D2: 6.0 URTI: D1: 14.8 D2: 12.6 UTI: NR | Overall Attrition Rate (%): 7.6 ITT Analysis: Yes Quality Rating: Fair.

Evidence Table 11

KQ4. Rheumatoid arthritis trials: benefits and harms for selected subpopulations

Study Characteristics | Inclusion and Exclusion Criteria | Characteristics and Interventions | Baseline Disease and Treatment Characteristics | Health Outcomes | Adverse Events, % | Analysis and Quality Rating
Author, year: Chakravarty et al., 2003 Country, Setting: US, Rheumatology practices (175) Funding: Not reported Research Objective: To describe prescribing practices of rheumatologists with respect to treatment of RA in women of childbearing age and pregnancy outcomes Study Design: Case reports from Mail Survey to Rheumatologists Overall N: 175 (29%) physicians returned survey Study Duration: NR | Inclusion Criteria: • Age • Childbearing age • Women Exclusion Criteria: | Interventions: NR Methotrexate Leflunomide EtanerceptInfliximab N: NR Mean age, yrs: NR Sex, % female: NR Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: NR MTX naive, %: NR Treatment resistant, %): NR Patients with Early RA (≤3 years): NR Baseline DAS, mean: NR Other: NR | • 39 MTX • 10 LEF • 13 ETA • 2 INF MTX: • 21 full term healthy infants • 7 spontaneous abortions, including one in which fetus had congenital malformation • 8 elective abortions • 3 resulted in congenital malformations (2 live, 1 spontaneous abortion) • All attributed to MTX exposure Of 10 with LEF2 had been prescribed cholestyramine 6 with known outcomes: • 2 fullterm, healthy infants • 1 preterm delivery • 2 underwent elective abortions upon recommendation by their rheumatologist • 1 miscarriage 15 with ETA: Of 8 with known outcomes • 6 fullterm healthy infants, • 1 terminated • 1 patient took both ETA and MTX had a spontaneous abortion • Only 2 pregnancies reported in patients taking INF for RA-1 a fullterm healthy baby • Outcome of other not stated • Combined rate of congenital abnormalities in women on MTX was 17% according to answered questionaires compared to an average of 2 to 3% from a California cohort of 1.6 million infants | NR | Overall Attrition Rate, %: N/A ITT Analysis: N/A: Observational study Quality Rating: Poor
Author, yr: Jacobsson et al., 2005 Country, Setting: Sweden, population-based (2 Swedish registers) Funding: NR Research Objective: The risk of cardiovascular disease (CVD) in pts with RA treated with TNF inhibitors, compared to a standard RA population Study Design: Retrospective cohort study Overall N: 983 (combined cohort) Study Duration: NR | Inclusion Criteria: • Age-: 20 to 79 yrs • Diagnosed according to 1987 ACR criteria • Case cohort • South Swedish Arthritis Txt Group (SSATG): pts with RA treated with anti-TNF agents and included in SSATG register between 2/1/99 and 12/31/01 Exclusion Criteria: • Previous hospital discharge due to CVD | Interventions, dose: D1: Anti-TNF exposed D2: Not Anti-TNF exposed N: D1: 531 D2: 452 Median age, yrs: D1: 55 D2: 61 Sex, % female: D1: 78 D2: 75 Race, % white: NR | Median disease duration, yrs: D1: 12 D2: 11 TJC, mean: NR SJC, mean: NR Median # of previous DMARDs used (IQR): D1: 4 (2-5) D2: 2 (1-4) PNL use, %: D1: 75 D2: 22 MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR Median HAQ: D1: 1.50 D2: 1.13 VAS patient global assessment median: D1: 69 D2: 48 | • Decreased incidence and RR for the development of first-time CVD event when controlling for disease severity in pts with RA treated with TNF blocking therapy • Controlling for disability (HAQ), age-sex adjusted rate ratio was 0.46 (95% CI,0.25 –0.85; P = 0.013) in anti-TNF treated vs. not treated • Anti-TNF group, 13 CVD events (in 656 PY at risk); age-adjusted incidence rate = 14 events/1000 PY • Unexposed comparison group, 85 CVD events (in 2056 PY at risk); age-adjusted incidence rate = 35.4 events/1000 PY • Relative risk = 0.62 (95% CI, 0.34 to 1.12; P = 0.111) • SMR revealed increased risk of new onset CVD in those not treated with TNF blockers in relation to background population of Malmo (SMR = 228, 95% CI,179 to 277) TNF blockers, risk of new onset CVD was lower, with CIs enclosing unity with background population (SMR = 157, 95% CI,72 –242) | Cardiovascular Events: D1: n =13 (6 MI, 4 cerebrovascular disease, and 3 other) D2: n =85 (33 MIs, 15 cerebrovascular disease, 12 CHF, 2 ruptured aortic aneurysm, and 23 other) | Overall Attrition Rate, %: NA ITT Analysis: NA Quality Rating: Fair
Author, yr: Katz et al., 2004 Country, Setting: US and Europe, safety database Funding: NR- but data came from manufacturer Research Objective: To report first large evaluation of INF exposure during pregnancy Study Design: AERS database analaysis Overall N: 131 direct and 15 indirect exposure (partner) Study Duration: From 1 to 9 infusions | Inclusion Criteria: • Pts either were treated with INF or their partners • Other meds allowed: 5-aminosalicylate 6-mercaptopurine/azathioprine, corticosteroids, metronidazole • MTX • Ciprofloxacin • NSAIDs • Proton pump inhibitors • H2 antagonists • Narcotics • Cyclosporine Exclusion Criteria: • NA | Interventions, dose: D1: INF direct D2: INF indirect N: D1: 131 D2: 15 Mean age, yrs: D1: 33 D2: 33 Sex, % female: D1: 100 D2: 100 Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: D1: 31 D2: 40 MTX naive, %: NR Txt resistant, %: NR Pts. with Early RA (≤3 yrs): NR Baseline DAS, mean: NR MTX use: D1: 8 D2: 20 | • INF exposure during pregnancy results in outcomes which are not different than US population of pregnant women. No increase in adverse events was detected • Comparing the general population with INF treated, there is no statistical difference • Direct exposure- 67% (64/96) live births (95% CI: 56.3, 76.0), 15% (14/96) miscarriages (95% CI: 8.2, 23.2), and 19% (18/96) therapeutic terminations (95% CI: 11.5, 28.0) among the 96 women. (General population rates live births occurred in 67%, miscarriages in 17%, and therapeutic termination in 16%) • Indirect exposure resulted in 90% live births (9/10) and 10% miscarriage (1/10) | NR | Overall Attrition Rate, %: 27 ITT Analysis: N/A Quality Rating: Fair
Author, yr: Kwon, 2003 Country, Setting: USA, multicenter (FDA’s MedWatch program) Funding: US Food and Drug Administration Research Objective: To describe adverse event reports of heart failure after TNF antagonist therapy Study Design: Database analysis; AERS Overall N: 47 cases Study Duration: long-term therapy | Inclusion Criteria: • Pts who reported heart failure as an adverse event while taking ETA or INF therapy in US since licensure of drugs until February 2002 • New onset failure and exacerbation of preexisting heart failure included Exclusion Criteria: • Heart failure reports temporally associated with other heart failure-inciting events (such as myocardial infarction) were excluded | Interventions, dose: D1: New Onset Heart Failure without risk factors D2: New Onset Heart Failure with risk factors D3: Heart failure exacerbation ETA: any INF: any N: NR Mean age, yrs: D1: 59 D2: 67 D3: 70 Sex, % female: D1: 74 D2: 42 D3: 44 Race, % white: NR | Mean disease duration, yrs: NR TJC, mean: NR SJC, mean: NR DMARD use, %: NR Corticosteroid use, %: D1: 8 D2: 10 MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: NR %ETA: D1: 12 D2: 14 D3: 3 %INF: D1: 7 D2: 5 D3: 6 | • 38 pts (81%) developed new-onset heart failure • 9 (19%) experienced heart failure exacerbation of which: 19 pts had no documented risk factors, 10 pts were under age 50 • Of pts under 50, after cessation of TNF antagonist therapy 3 pts experienced complete resolution of heart failure, 6 pts showed improvement, and 1 patient died | NR | Overall Attrition Rate, %: NA ITT Analysis: NA Quality Rating: Fair
Author, yr: Wolfe and Michaud, 2004 Country, Setting: US, Multicenter (National Data Bank for Rheumatic Diseases) Funding: Centocor, Inc Research Objective: To determine frequency of heart failure in pts with RA, and to determine its predictors, particularly use of anti-TNF therapy Study Design: Retrospective cohort study Overall N: 15,739 (RA plus OA subjects) Study Duration: 2 years | Inclusion Criteria: • Participation in National Data Bank for Rheumatic Diseases study of outcomes of arthritis; patient at participating rheumatology clinic Exclusion Criteria: • NR | Interventions, dose: D1: Any Anti-TNF D2: INF D3: ETA D4: No anti-TNF D5: Total Population Overall ETA INF N: NR Mean age, yrs: D1: 60 D2: 61.5 D3: 56.7 D4: 61.5 D5: 51 Sex, % female: D1: 78 D2: 77 D3: 80 D4: 76 D5: 77 Race, % white: D1: 95 D2: 96 D3: 92 D4: 92 D5: 94 | Mean disease duration, yrs: D1: 14.2 D2: 13.8 D3: 15.2 D4: 15.5 D5: 14.9 TJC, mean: NR SJC, mean: NR DMARD use, %: Overall: 86 PRE use (%) D1: 47 D2: 49 D3: 39 D4: 33 D5: 39 MTX naive, %: NR Txt resistant %: NR Pts with Early RA (≤3 yrs): NR Baseline DAS, mean: D1: 3.7 D2: 3.7 D3: 3.6 D4: 3.5 D5: 3.6 MTX use: D1: 67 D2: 76 D3: 44 D4: 47 D5: 56 | • 461 cases of heart failure in 13,171 pts with RA (overall risk of 3.5%); after adjusting for demographic characteristics the risk was 3.9% (95% CI,= 3.4% to 4.3%) • Among all cases of heart failure, pts receiving anti-TNF therapy were less likely to have heart failure than those not receiving anti-TNF therapy (−1.2%; 95% CI, −1.9 --0.5%) • Overall, adjusted frequency of heart failure was 2.8% in those treated with anti-TNF vs. 3.9% in remaining pts (P = 0.03) • Frequency of heart failure was 5.2% in men and 3.0% in women • In examining incident cases of heart failure in pts under age 50, no increase was found (0/1569 pts using anti- TNF vs. 3/1401 not using anti-TNF therapy) | NR | Overall Attrition Rate, %: NR ITT Analysis: NA Quality Rating: Fair

Evidence Table 12

KQ4. Rheumatoid arthritis systematic reviews: benefits and harms for selected subpopulations

Study Characteristics | Inclusion and Exclusion Criteria | Characteristics and Interventions | Baseline Disease and Treatment Characteristics | Health Outcomes | Adverse Events, % | Analysis and Quality Rating
Author, yr, country, funding: Bathon et al., 2006 United States, supported by Immunex Corporation, wholly owned subsidiary of Amgen, Inc., and by Wyeth, Collegeville, PA, USA Study Design: Pooled analysis Aims of the Review: To evaluate safety and efficacy of ETA treatment in elderly (age 65 yrs) and younger adult subjects (age < 65 yrs ) with RA Number of Pts: 1,353 2 longterm extensions (N = 1, 049) | Studies included: • RCTs • Weinblatt et al., 1999 • Moreland et al., 1999 • Bathon et al., 2000 • Keystone et al., 2004 Characteristics of included studies: • 4 RCTs and 2 long-term observational extensions • Dosing arms included ETA 25 mg twice weekly vs placebo, MTX • Studies 1 and 2 were LRA extensions and conducted in DMARD-failure RA subjects and MTX- incomplete responders, respectively • Study 3, early study compared MTX and ETA therapy • Study 4 included subjects who had failed at least 1 DMARD other than MTX Characteristics of included populations: • Adults with RA • 14% to 22% across treatment arms were elderly Characteristics of interventions: ETA (25 mg) twice weekly and comparison (placebo or MTX) | • Elderly subjects had similar or less response to treatment than younger subjects (ACR 20, ACR 50, ACR 70) • Elderly ETA-treated subjects had similar or slightly lower, ACR responses compared with younger ETA treated subjects across all timepoints • ACR 20/50/70 responses after 6 mos of ETA treatment were 70%/45%/15% for elderly subjects and 65%/39%/15% in younger subjects • For LRA extension, ACR responses were similar between age groups • ACR 20/50/70 responses were 70%/47%/11% in elderly subjects and 75%/53%/29% in younger subjects after 72 mos ETA treatment in extension • Study 3, ACR responses tended to be lower in elderly group compared with younger group in both MTX and ETA treatment arms • After 24 mos ETA treatment, ACR 20/50/70 responses were 54%/22%/14% for elderly ERA subjects and 77%/54%/32% for younger subjects • In Study 3 extension, ACR 20/50/70 responses were 60%/40%/19% in elderly subjects and 79%/58%/40% in younger subjects after 48 mos of treatment in extension • In Study 4, elderly subjects had greater separation between efficacy responses achieved with ETA and MTX versus either monotherapy compared with younger subjects • After 12 mos treatment with combiation ETA and MTX, ACR 20/50/70 responses were 77%/68%/39% • For both age groups, treatment with ETA resulted in improved efficacy and function compared with control treatment, and combination therapy with ETA plux MTX resulted in greater efficacy than eitehr ETA or MTx used alone • Efficacy responses of elderly subjects were sustained for up to 6 yrs • Radiographic progression, M-SHS after 1 year of treatment was lower in subjects treated with both ETA and MTX compared with subjects treated with either agent used alone and this pattern was similar in both age groups | • Rates of serious adverse events tended to be higher in elderly than younger subjects; however, rates of safety events observed in elderly ETA-treated subjects did not exceed rates in elderly placebo or MTX-treated subjects
Author, yr, country, funding: Fleischmann et al., 2003, multinational, Immunex corporation (last author, George Spencer-Green, is full- time employee at Immunex) Study Design: Pooled analysis Aims of the Review: To compare safety and efficacy of ETA in pts with RA who were ≥65 yrs to those < 65 yrs in open- label and RCTs Number of Pts: 1,128 Improvement in signs and symptoms was assessed for those who were able to receive ETA continuously for at least 1 yr (n=1059) | Studies included: All 9 are not clearly identified; 4 that are: • Moreland et al., 1997 • Weinblatt et al., 1999 • Moreland et al., 1999 • Bathon et al., 2000 Characteristics of included studies: • 4 double-blind RCT • 5 open-label trials • 8 trials evaluated pts with long-standing disease who failed previous DMARD therapy and 1 evaluated pts with recent onset RA (≤ 3 yrs) who never received MTX Characteristics of included populations: • Adults with RA • 83% < 65 yrs old • 17% > 65 • 8 trials evaluated pts with long-standing disease who failed previous DMARD therapy and 1 evaluated pts with recent onset RA (≤ 3 yrs) who never received MTX Characteristics of interventions: • ETA twice weekly for all pts | • 17% of pts were ≥ 65 yrs old at time of study entry At 1 yr: • 69% of pts < 65 and 66% of pts ≥ 65 met ACR20 (P = 0.480) • 40% of pts ≥ 65 met ACR50 and 17% met ACR70, compared to 44% and 20% for < 65 group, respectively (P values NR) • Subgroup analysis of those with early RA showed no difference in ACR20 response between those ≥ 65 and those < 65 (51% vs. 58%, P = 0.265) • Same for subgroup of those with late RA (58% vs. 63%, P = 0.321) | • Any infection (< 65 vs. ≥ 65: 1.56 events/PY vs. 1.36, P = 0.036) • Injection site reactions (4.31 events/PY vs. 1.47, P < 0.001), headaches (0.37 vs. 0.18, P < 0.001), and rhinitis (0.19 vs. 0.10, P = 0.006) occurred at higher rates in younger pts (< 65) • Rates of other AEs were comparable between 2 groups: rash, diarrhea, nausea, and abdominal pain | Publication Bias Assessed: NR Heterogeneity Assessed: NR Standard Method of Study Appraisals: NR Comprehensive Search Strategy: No Quality Rating: Poor
Author, yr, country, funding: Rheumatoid Arthritis Clinical Trial Archive Group, 1995, Multinational, NIH grants Study Design: Systematic review Aims of the Review: To evaluate whether age and renal impairment affect rate of side effects or efficacy of MTX in RA pts Number of Pts: 496 | Studies included: 11 MTX clinical trials: • Weinblatt, et al., 1985 • Furst, et al., 1989 • Schmid, et al., unpublished study • Williams, et al., 1985 • Wilke, et al., unpublished study • Weinblatt, et al., 1990 • Williams, et al., 1992 • Suarez et al 1988 • Morassut, et al., 1989 • Hamdy, et al., 1987 • Bell, et al., 1988. Characteristics of included studies: • RCTs • Placebo control or comparative trial • MTX as 1 treatment arm • Adult RA pts • Trial completed (although not necessarily published) by end of 1991, and trial 12 weeks or longer (to end or to crossover) Characteristics of included populations: • Adult RA pts treated with MTX Characteristics of interventions: • All pts treated with MTX (doses NR) | • Study compares subgroups of pts treated with MTX • Neither age nor renal impairment had any effect on efficacy of MTX • Odds of major clinical improvement by age were 1.0 for < 60 yr old group (referent), 1.4 (0.7, 2.6) for 60–64, 1.0 (0.5, 2.2) for 65–69, and 0.7 (0.3, 1.7) for ≥ 70 (efficacy regression analyses controlled for age group, sex, renal function, study of origin, initial tender joint count, grip strength, steroid dose, NSAID used at baseline, and maximum MTX dose) • Odds of major clinical improvement by creatinine clearance were 1.0 for ≥ 99.8 ml/min (referent), 0.6 (0.3, 1.0) for 78.6–99.9 ml/min, 1.1 (0.6, 2.0) for 62.6–78.6 ml/min, and 1.0 (0.5, 2.1) for < 62.6 ml/min • Age did not affect rate of toxicity. Those in the oldest group were not at a higher risk of side effects from MTX • Pts with renal impairment had worse toxicity scores and a higher overall rate of toxicity; mean worst toxicity scores were 2.2 (referent), 3.0 (P = < 0.05), 2.9 (P = < 0.05), and 3.3 (P = < 0.01) for ≥ 99.8 ml/min (referent), 78.6–99.9 ml/min, 62.6–78.6 ml/min, and < 62.6 ml/min. groups respectively; Rates of any toxicity were 55%, 64%, 65%, and 72% for groups respectively (P NR) • They report that pts with renal impairment were at higher risk of severe toxicity and for respiratory toxicity; however, 95% CI crosses 1 for all but 1 group; for severe toxicity odds for 4 groups were 1.0 (referent), 3.0 (0.7, 13.0), 5.7 (1.4, 23.6), and 4.5 (0.9, 22.6); for respiratory toxicity, 1.0 (referent), 5.9 (0.6, 57.0), 5.6 (0.5, 60.4), and 6.9 (0.5, 88.8) | • No significant difference for liver toxicity between different creatinine clearance groups 1.0 (referent) 1.8 (1.0, 3.4) 1.2 (0.6, 2.3) 1.8 (0.8, 3.7) • Toxicity regressions adjusted for age, sex, creatinine clearance, baseline NSAID use (yes/no), maximum MTX dose, and study of origin | Publication Bias Assessed: NR Heterogeneity Assessed: Yes Standard Method of Study Appraisals: NR Comprehensive Search Strategy: Yes Quality Rating: Fair

## REFERENCES

Antoni C, Krueger GG, de Vlam K, Birbara C, Beutler A, Guzzo C, et al. (2005). Infliximab improves signs and symptoms of psoriatic arthritis: results of the IMPACT 2 trial. Ann Rheum Dis.
Antoni CE, Kavanaugh A, Kirkham B, Tutuncu Z, Burmester GR, Schneider U, et al. (2005). Sustained benefits of infliximab therapy for dermatologic and articular manifestations of psoriatic arthritis: results from the infliximab multinational psoriatic arthritis controlled trial (IMPACT). Arthritis Rheum.
Askling J, Fored CM, Baecklund E, Brandt L, Backlin C, Ekbom A, et al. (2005). Haematopoietic malignancies in rheumatoid arthritis: lymphoma risk and characteristics after exposure to tumour necrosis factor antagonists. Ann Rheum Dis.
Askling J, Fored CM, Brandt L, Baecklund E, Bertilsson L, Coster L, et al. (2005). Risk and case characteristics of tuberculosis in rheumatoid arthritis associated with tumor necrosis factor antagonists in Sweden. Arthritis Rheum.
Askling J, Fored CM, Brandt L, Baecklund E, Bertilsson L, Feltelius N, et al. (2005). Risks of solid cancers in patients with rheumatoid arthritis and after treatment with tumour necrosis factor antagonists. Ann Rheum Dis.
Baecklund E, Iliadou A, Askling J, Ekbom A, Backlin C, Granath F, et al. (2006). Association of chronic inflammation, not its treatment, with increased lymphoma risk in rheumatoid arthritis. Arthritis Rheum.
Bathon JM, Fleischmann RM, Van der Heijde D, Tesser JR, Peloso PM, Chon Y, et al. (2006). Safety and efficacy of etanercept treatment in elderly subjects with rheumatoid arthritis. J Rheumatol.
Bathon JM, Martin RW, Fleischmann RM, Tesser JR, Schiff MH, Keystone EC, et al. (2000). A comparison of etanercept and methotrexate in patients with early rheumatoid arthritis. N Engl J Med.
Bergstrom L, Yocum DE, Ampel NM, Villanueva I, Lisse J, Gluck O, et al. (2004). Increased risk of coccidioidomycosis in patients treated with tumor necrosis factor alpha antagonists. Arthritis Rheum.
Boers M, Verhoeven AC, Markusse HM, van de Laar MA, Westhovens R, van Denderen JC, et al. (1997). Randomised comparison of combined step-down prednisolone, methotrexate and sulphasalazine with sulphasalazine alone in early rheumatoid arthritis. Lancet.
Bongartz T, Sutton AJ, Sweeting MJ, Buchan I, Matteson EL, Montori V. (2006). Anti-TNF antibody therapy in rheumatoid arthritis and the risk of serious infections and malignancies: systematic review and meta-analysis of rare harmful effects in randomized controlled trials. J Am Med Assoc.
Breedveld FC, Emery P, Keystone E, Patel K, Furst DE, Kalden JR, et al. (2004). Infliximab in active early rheumatoid arthritis. Ann Rheum Dis.
Breedveld FC, Weisman MH, Kavanaugh AF, Cohen SB, Pavelka K, van Vollenhoven R, et al. (2006). The PREMIER study: A multicenter, randomized, double-blind clinical trial of combination therapy with adalimumab plus methotrexate versus methotrexate alone or adalimumab alone in patients with early, aggressive rheumatoid arthritis who had not had previous methotrexate treatment. Arthritis Rheum.
Brown SL, Greene MH, Gershon SK, Edwards ET, Braun MM. (2002). Tumor necrosis factor antagonist therapy and lymphoma development: twenty-six cases reported to the Food and Drug Administration. Arthritis Rheum.
Cannon GW, Holden WL, Juhaeri J, Dai W, Scarazzini L, Stang P. (2004). Adverse events with disease modifying antirheumatic drugs (DMARD): a cohort study of leflunomide compared with other DMARD. J Rheumatol.
Capell H, Madhok R, Porter D, Munro R, McInnes I, Hunter J, et al. (2007). Combination therapy with sulphasalazine and methotrexate is more effective than either drug alone in rheumatoid arthritis (ra) patients with a suboptimal response to sulphasalazine: Results from the double blind placebo controlled mascot study. Ann Rheum Dis.
Chakravarty EF, Michaud K, Wolfe F. (2005). Skin cancer, rheumatoid arthritis, and tumor necrosis factor inhibitors. J Rheumatol.
Chakravarty EF, Sanchez-Yamamoto D, Bush TM. (2003). The use of disease modifying antirheumatic drugs in women with rheumatoid arthritis of childbearing age: a survey of practice patterns and pregnancy outcomes. J Rheumatol.
Chung ES, Packer M, Lo KH, Fasanmade AA, Willerson JT. (2003). Randomized, double-blind, placebo-controlled, pilot trial of infliximab, a chimeric monoclonal antibody to tumor necrosis factor-alpha, in patients with moderate-to-severe heart failure: results of the anti-TNF Therapy Against Congestive Heart Failure (ATTACH) trial. Circulation.
Clark W, Jobanputra P, Barton P, Burls A. (2004). The clinical and cost-effectiveness of anakinra for the treatment of rheumatoid arthritis in adults: a systematic review and economic analysis. Health Technol Assess.
Cohen S, Cannon G, Schiff M, Weaver A, Fox R, Olsen N, et al. (2001). Two-year, blinded, randomized, controlled trial of treatment of active rheumatoid arthritis with leflunomide compared with methotrexate. Utilization of leflunomide in the treatment of rheumatoid arthritis. Arthritis Rheum.
Cohen S, Hurd E, Cush J, Schiff M, Weinblatt ME, Moreland LW, et al. (2002). Treatment of rheumatoid arthritis with anakinra, a recombinant human interleukin-1 receptor antagonist, in combination with methotrexate: results of a twenty-four-week, multicenter, randomized, double-blind, placebo-controlled trial. Arthritis Rheum.
Cohen SB, Moreland LW, Cush JJ, Greenwald MW, Block S, Shergy WJ, et al. (2004). A multicentre, double blind, randomised, placebo controlled trial of anakinra (Kineret), a recombinant interleukin 1 receptor antagonist, in patients with rheumatoid arthritis treated with background methotrexate. Ann Rheum Dis.
Cohen SB, Woolley JM, Chan W. (2003). Interleukin 1 receptor antagonist anakinra improves functional status in patients with rheumatoid arthritis. J Rheumatol.
Combe BG, Codreanu C, Fiocco U, Gaubitz M, Geusens PP, Kvien TK, et al. (2006). Double-blind comparison of etanercept and sulphasalazine, alone and combined, in patients with active rheumatoid arthritis despite receiving sulphasalazine. Ann Rheum Dis.
De Bandt M, Sibilia J, Le Loet X, Prouzeau S, Fautrel B, Marcelli C, et al. (2005). Systemic lupus erythematosus induced by anti-tumour necrosis factor alpha therapy: a French national survey. Arthritis Res Ther.
Dixon WG, Watson K, Lunt M, Hyrich KL, Silman AJ, Symmons DP. (2006). Rates of serious infection, including site-specific and bacterial intracellular infection, in rheumatoid arthritis patients receiving anti-tumor necrosis factor therapy: Results from the British Society for Rheumatology Biologics Register. Arthritis Rheum.
Doran MF, Crowson CS, Pond GR, O’Fallon WM, Gabriel SE. (2002). Predictors of infection in rheumatoid arthritis. Arthritis Rheum.
Dougados M, Combe B, Cantagrel A, Goupille P, Olive P, Schattenkirchner M, et al. (1999). Combination therapy in early rheumatoid arthritis: a randomised, controlled, double blind 52 week clinical trial of sulphasalazine and methotrexate compared with the single components. Ann Rheum Dis.
Edwards JC, Szczepanski L, Szechinski J, Filipowicz-Sosnowska A, Emery P, Close DR, et al. (2004). Efficacy of B-cell-targeted therapy with rituximab in patients with rheumatoid arthritis. N Engl J Med.
Emery P, Breedveld FC, Jubb RW, Sorensen H, Oed C, Loew-Friedrich I. (1999). Efficacy and safety of leflunomide vs. methotrexate in rheumatoid arthritis (RA): results of a double-blind, randomized, 2-year trial. Arthritis Rheum.
Emery P, Breedveld FC, Lemmel EM, Kaltwasser JP, Dawes PT, Gomor B, et al. (2000). A comparison of the efficacy and safety of leflunomide and methotrexate for the treatment of rheumatoid arthritis. Rheumatology (Oxford).
Emery P, Fleischmann R, Filipowicz-Sosnowska A, Schechtman J, Szczepanski L, Kavanaugh A, et al. (2006). The efficacy and safety of rituximab in patients with active rheumatoid arthritis despite methotrexate treatment: results of a phase IIB randomized, double-blind, placebo-controlled, dose-ranging trial. Arthritis Rheum.
Feltelius N, Fored CM, Blomqvist P, Bertilsson L, Geborek P, Jacobsson LT, et al. (2005). Results from a nationwide postmarketing cohort study of patients in Sweden treated with etanercept. Ann Rheum Dis.
Fleischmann RM, Baumgartner SW, Tindall EA, Weaver AL, Moreland LW, Schiff MH, et al. (2003). Response to etanercept (Enbrel) in elderly patients with rheumatoid arthritis: a retrospective analysis of clinical trial results. J Rheumatol.
Fleischmann RM, Schechtman J, Bennett R, Handel ML, Burmester GR, Tesser J, et al. (2003). Anakinra, a recombinant human interleukin-1 receptor antagonist (r-metHuIL-1ra), in patients with rheumatoid arthritis: A large, international, multicenter, placebo-controlled trial. Arthritis Rheum.
Fleischmann RM, Tesser J, Schiff MH, Schechtman J, Burmester GR, Bennett R, et al. (2006). Safety of extended treatment with anakinra in patients with rheumatoid arthritis. Ann Rheum Dis.
Flendrie M, Creemers MC, Welsing PM, den Broeder AA, van Riel PL. (2003). Survival during treatment with tumour necrosis factor blocking agents in rheumatoid arthritis. Ann Rheum Dis.
Flendrie M, Vissers WH, Creemers MC, de Jong EM, van de Kerkhof PC, van Riel PL. (2005). Dermatological conditions during TNF-alpha-blocking therapy in patients with rheumatoid arthritis: a prospective study. Arthritis Res Ther.
Gartlehner G, Hansen RA, Jonas BL, Thieda P, Lohr KN. (2006). The comparative efficacy and safety of biologics for the treatment of rheumatoid arthritis: a systematic review and metaanalysis. J Rheumatol.
Geborek P, Bladstrom A, Turesson C, Gulfe A, Petersson IF, Saxne T, et al. (2005). Tumour necrosis factor blockers do not increase overall tumour risk in patients with rheumatoid arthritis, but may be associated with an increased risk of lymphomas. Ann Rheum Dis.
Geborek P, Crnkic M, Petersson IF, Saxne T. (2002). Etanercept, infliximab, and leflunomide in established rheumatoid arthritis: clinical experience using a structured follow up programme in southern Sweden. Ann Rheum Dis.
Genovese MC, Bathon JM, Fleischmann RM, Moreland LW, Martin RW, Whitmore JB, et al. (2005). Longterm safety, efficacy, and radiographic outcome with etanercept treatment in patients with early rheumatoid arthritis. J Rheumatol.
Genovese MC, Bathon JM, Martin RW, Fleischmann RM, Tesser JR, Schiff MH, et al. (2002). Etanercept versus methotrexate in patients with early rheumatoid arthritis: two-year radiographic and clinical outcomes. Arthritis Rheum.
Genovese MC, Cohen S, Moreland L, Lium D, Robbins S, Newmark R, et al. (2004). Combination therapy with etanercept and anakinra in the treatment of patients with rheumatoid arthritis who have been treated unsuccessfully with methotrexate. Arthritis Rheum.
Goekoop-Ruiterman YP, de Vries-Bouwstra JK, Allaart CF, van Zeben D, Kerstens PJ, Hazes JM, et al. (2005). Clinical and radiographic outcomes of four different treatment strategies in patients with early rheumatoid arthritis (the BeSt study): a randomized, controlled trial. Arthritis Rheum.
Goekoop-Ruiterman YP, de Vries-Bouwstra JK, Allaart CF, van Zeben D, Kerstens PJ, Hazes JM, et al. (2007). Comparison of treatment strategies in early rheumatoid arthritis: a randomized trial. Ann Intern Med.
Gomez-Reino JJ, Carmona L, Valverde VR, Mola EM, Montero MD. (2003). Treatment of rheumatoid arthritis with tumor necrosis factor inhibitors may predispose to significant increase in tuberculosis risk: a multicenter active-surveillance report. Arthritis Rheum.
Haagsma C, van Riel P, de Jong A, van de Putte L. (1997). Combination of sulphasalazine and methotrexate versus the single components in early rheumatoid arthritis: a randomized, controlled, double-blind, 52 week clinical trial. Br J Rheum.
Harley CR, Frytak JR, Tandon N. (2003). Treatment compliance and dosage administration among rheumatoid arthritis patients receiving infliximab, etanercept, or methotrexate. Am J Manag Care.
Hochberg MC, Tracy JK, Hawkins-Holt M, Flores RH. (2003). Comparison of the efficacy of the tumour necrosis factor alpha blocking agents adalimumab, etanercept, and infliximab when added to methotrexate in patients with active rheumatoid arthritis. Ann Rheum Dis.
Hyrich KL, Symmons DP, Watson KD, Silman AJ. (2006). Comparison of the response to infliximab or etanercept monotherapy with the response to cotherapy with methotrexate or another disease-modifying antirheumatic drug in patients with rheumatoid arthritis: Results from the British Society for Rheumatology Biologics Register. Arthritis Rheum.
Jacobsson LT, Turesson C, Gulfe A, Kapetanovic MC, Petersson IF, Saxne T, et al. (2005). Treatment with tumor necrosis factor blockers is associated with a lower incidence of first cardiovascular events in patients with rheumatoid arthritis. J Rheumatol.
Jones G, Crotty M, Brooks P. (2000). Interventions for treating psoriatic arthritis. Cochrane Database Syst Rev.
Kaltwasser J, Nash P, Gladman D, Rosen C, Behrens F, Jones P, et al. (2004). Efficacy and safety of leflunomide in the treatment of psoriatic arthritis and psoriasis: a multinational, double-blind, randomized, placebo-controlled clinical trial. Arthritis Rheum.
Katz JA, Antoni C, Keenan GF, Smith DE, Jacobs SJ, Lichtenstein GR. (2004). Outcome of pregnancy in women receiving infliximab for the treatment of Crohn’s disease and rheumatoid arthritis. Am J Gastroenterol.
Kavanaugh A, Antoni C, Krueger GG, Yan S, Bala M, Dooley LT, et al. (2006). Infliximab improves health related quality of life and physical function in patients with psoriatic arthritis. Ann Rheum Dis.
Kavanaugh A, Antoni C, Mease P, Gladman D, Yan S, Bala M, et al. (2006). Effect of infliximab therapy on employment, time lost from work, and productivity in patients with psoriatic arthritis. J Rheumatol.
Kavanaugh A, Antoni CE, Gladman D, Wassenberg S, Zhou B, Beutler A, et al. (2006). The Infliximab Multinational Psoriatic Arthritis Controlled Trial (IMPACT): results of radiographic analyses after 1 year. Ann Rheum Dis.
Keane J, Gershon S, Wise RP, Mirabile-Levens E, Kasznica J, Schwieterman WD, et al. (2001). Tuberculosis associated with infliximab, a tumor necrosis factor alpha-neutralizing agent. N Engl J Med.
Kirwan J, Hallgren R, Mielants H, Wollheim F, Bjorck E, Persson T, et al. (2004). A randomised placebo controlled 12 week trial of budesonide and prednisolone in rheumatoid arthritis. Ann Rheum Dis.
Klareskog L, van der Heijde D, de Jager JP, Gough A, Kalden J, Malaise M, et al. (2004). Therapeutic effect of the combination of etanercept and methotrexate compared with each treatment alone in patients with rheumatoid arthritis: double-blind randomised controlled trial. Lancet.
Korpela M, Laasonen L, Hannonen P, Kautiainen H, Leirisalo-Repo M, Hakala M, et al. (2004). Retardation of joint damage in patients with early rheumatoid arthritis by initial aggressive treatment with disease-modifying antirheumatic drugs: five-year experience from the Fin-Raco Study. Arthritis Rheum.
Kosinski M, Kujawski SC, Martin R, Wanke LA, Buatti MC, Ware JE, et al. (2002). Health-related quality of life in early rheumatoid arthritis: impact of disease and treatment response. Am J Manag Care.
Kremer J, Genovese M, Cannon G, Caldwell J, Cush J, Furst D, et al. (2002). Concomitant leflunomide therapy in patients with active rheumatoid arthritis despite stable doses of methotrexate. A randomized, double-blind, placebo-controlled trial. Ann Intern Med.
Kristensen LE, Saxne T, Geborek P. (2006). The LUNDEX, a new index of drug efficacy in clinical practice: results of a five-year observational study of treatment with infliximab and etanercept among rheumatoid arthritis patients in southern Sweden. Arthritis Rheum.
Kwon HJ, Cote TR, Cuffe MS, Kramer JM, Braun MM. (2003). Case reports of heart failure after therapy with a tumor necrosis factor antagonist. Ann Intern Med.
Landewe RB, Boers M, Verhoeven AC, Westhovens R, van de Laar MA, Markusse HM, et al. (2002). COBRA combination therapy in patients with early rheumatoid arthritis: long-term structural benefits of a brief intervention. Arthritis Rheum.
Langer HE, Missler-Karger B. (2003). Kineret: efficacy and safety in daily clinical practice: an interim analysis of the Kineret response assessment initiative (kreative) protocol. Int J Clin Pharmacol Res.
Larsen A, Kvien TK, Schattenkirchner M, Rau R, Scott DL, Smolen JS, et al. (2001). Slowing of disease progression in rheumatoid arthritis patients during long-term treatment with leflunomide or sulfasalazine. Scand J Rheum.
Lebwohl M, Blum R, Berkowitz E, Kim D, Zitnik R, Osteen C, et al. (2005). No evidence for increased risk of cutaneous squamous cell carcinoma in patients with rheumatoid arthritis receiving etanercept for up to 5 years. Arch Dermatol.
Ledingham J, Deighton C. (2005). Update on the British Society for Rheumatology guidelines for prescribing TNFalpha blockers in adults with rheumatoid arthritis (update of previous guidelines of April 2001). Rheumatology (Oxford).
Lee JH, Slifman NR, Gershon SK, Edwards ET, Schwieterman WD, Siegel JN, et al. (2002). Life-threatening histoplasmosis complicating immunotherapy with tumor necrosis factor alpha antagonists infliximab and etanercept. Arthritis Rheum.
Listing J, Strangfeld A, Kary S, Rau R, von Hinueber U, Stoyanova-Scholz M, et al. (2005). Infections in patients with rheumatoid arthritis treated with biologic agents. Arthritis Rheum.
Listing J, Strangfeld A, Rau R, Kekow J, Gromnica-Ihle E, Klopsch T, et al. (2006). Clinical and functional remission: even though biologics are superior to conventional DMARDs overall success rates remain low--results from RABBIT, the German biologics register. Arthritis Res Ther.
Maetzel A, Wong A, Strand V, Tugwell P, Wells G, Bombardier C. (2000). Meta-analysis of treatment termination rates among rheumatoid arthritis patients receiving disease-modifying anti-rheumatic drugs. Rheumatology (Oxford).
Maillefert JF, Combe B, Goupille P, Cantagrel A, Dougados M. (2003). Long term structural effects of combination therapy in patients with early rheumatoid arthritis: five year follow up of a prospective double blind controlled study. Ann Rheum Dis.
Maini R, St Clair EW, Breedveld F, Furst D, Kalden J, Weisman M, et al. (1999). Infliximab (chimeric anti-tumour necrosis factor alpha monoclonal antibody) versus placebo in rheumatoid arthritis patients receiving concomitant methotrexate: a randomised phase III trial. ATTRACT Study Group. Lancet.
Maini RN, Breedveld FC, Kalden JR, Smolen JS, Furst D, Weisman MH, et al. (2004). Sustained improvement over two years in physical function, structural damage, and signs and symptoms among patients with rheumatoid arthritis treated with infliximab and methotrexate. Arthritis Rheum.
Mease PJ, Gladman DD, Ritchlin CT, Ruderman EM, Steinfeld SD, Choy EH, et al. (2005). Adalimumab for the treatment of patients with moderately to severely active psoriatic arthritis: results of a double-blind, randomized, placebo-controlled trial. Arthritis Rheum.
Mease PJ, Goffe BS, Metz J, VanderStoep A, Finck B, Burge DJ. (2000). Etanercept in the treatment of psoriatic arthritis and psoriasis: a randomised trial. Lancet.
Mease PJ, Kivitz AJ, Burch FX, Siegel EL, Cohen SB, Ory P, et al. (2004). Etanercept treatment of psoriatic arthritis: safety, efficacy, and effect on disease progression. Arthritis Rheum.
Mease PJ, Kivitz AJ, Burch FX, Siegel EL, Cohen SB, Ory P, et al. (2006). Continued inhibition of radiographic progression in patients with psoriatic arthritis following 2 years of treatment with etanercept. J Rheumatol.
Mohan AK, Cote TR, Block JA, Manadan AM, Siegel JN, Braun MM. (2004). Tuberculosis following the use of etanercept, a tumor necrosis factor inhibitor. Clin Infect Dis.
Mohan N, Edwards ET, Cupps TR, Oliverio PJ, Sandberg G, Crayton H, et al. (2001). Demyelination occurring during anti-tumor necrosis factor alpha therapy for inflammatory arthritides. Arthritis Rheum.
Moreland LW, Weinblatt ME, Keystone EC, Kremer JM, Martin RW, Schiff MH, et al. (2006). Etanercept treatment in adults with established rheumatoid arthritis: 7 years of clinical experience. J Rheumatol.
Mottonen T, Hannonen P, Leirisalo-Repo M, Nissila M, Kautiainen H, Korpela M, et al. (1999). Comparison of combination therapy with single-drug therapy in early aheumatoid arthritis: a randomised trial. Lancet.
Nash P, Thaci D, Behrens F, Falk F, Kaltwasser JP. (2006). Leflunomide improves psoriasis in patients with psoriatic arthritis: an in-depth analysis of data from the TOPAS study. Dermatology.
Nuki G, Bresnihan B, Bear MB, McCabe D. (2002). Long-term safety and maintenance of clinical improvement following treatment with anakinra (recombinant human interleukin-1 receptor antagonist) in patients with rheumatoid arthritis: extension phase of a randomized, double-blind, placebo-controlled trial. Arthritis Rheum.
O’Dell JR, Haire CE, Erikson N, Drymalski W, Palmer W, Eckhoff PJ, et al. (1996). Treatment of rheumatoid arthritis with methotrexate alone, sulfasalazine and hydroxychloroquine, or a combination of all three medications. N Engl J Med.
O’Dell J, Leff R, Paulsen G, Haire C, Mallek J, Eckhoff P, et al. (2002). Treatment of rheumatoid arthritis with methotrexate and hydroxychloroquine, methotrexate and sulfasalazine, or a combination of the three medications: results of a two-year, randomized, double-blind, placebo-controlled trial. Arthritis Rheum.
O’Dell JR, Petersen K, Leff R, Palmer W, Schned E, Blakely K, et al. (2006). Etanercept in combination with sulfasalazine, hydroxychloroquine, or gold in the treatment of rheumatoid arthritis. J Rheumatol.
Osiri M, Shea B, Robinson V, Suarez Almazor M, Strand V, Tugwell P, et al. (2003). Leflunomide for treating rheumatoid arthritis. Cochrane Database Syst Rev.
Puolakka K, Kautiainen H, Mottonen T, Hannonen P, Korpela M, Julkunen H, et al. (2004). Impact of initial aggressive drug treatment with a combination of disease-modifying antirheumatic drugs on the development of work disability in early rheumatoid arthritis: a five-year randomized followup trial. Arthritis Rheum.
Rheumatoid Arthritis Clinical Trial Archive Group. (1995). The effect of age and renal function on the efficacy and toxicity of methotrexate in rheumatoid arthritis. J Rheumatol.
Ruderman EM, Markenson J. (2003). Granulomatous infections and tumor necrosis factor antagonists therapy: update through June 2002. Arthritis Rheum.
Saag KG, Koehnke R, Caldwell JR, Brasington R, Burmeister LF, Zimmerman B, et al. (1994). Low dose long-term corticosteroid therapy in rheumatoid arthritis: an analysis of serious adverse events. Am J Med.
Salliot C, Gossec L, Ruyssen-Witrand A, Luc M, Duclos M, Guignard S, et al. (2006). Infections during tumour necrosis factor-{alpha} blocker therapy for rheumatic diseases in daily practice: a systematic retrospective study of 709 patients. Rheumatology.
Schaible TF. (2000). Long term safety of infliximab. Can J Gastroenterol.
Schiff MH, Burmester GR, Kent JD, Pangan AL, Kupper H, Fitzpatrick SB, et al. (2006). Safety analyses of adalimumab (HUMIRA) in global clinical trials and US postmarketing surveillance of patients with rheumatoid arthritis. Ann Rheum Dis.
Schiff MH, DiVittorio G, Tesser J, Fleischmann R, Schechtman J, Hartman S, et al. (2004). The safety of anakinra in high-risk patients with active rheumatoid arthritis: six-month observations of patients with comorbid conditions. Arthritis Rheum.
Schiff MH, Yu EB, Weinblatt ME, Moreland LW, Genovese MC, White B, et al. (2006). Long-term experience with etanercept in the treatment of rheumatoid arthritis in elderly and younger patients: patient-reported outcomes from multiple controlled and open-label extension studies. Drugs & aging.
Scott D, Smolen J, Kalden J, van de Putte L, Larsen A, Kvien T, et al. (2001). Treatment of active rheumatoid arthritis with leflunomide: two year follow up of a double blind, placebo controlled trial versus sulfasalazine. Ann Rheum Dis.
Setoguchi S, Solomon DH, Weinblatt ME, Katz JN, Avorn J, Glynn RJ, et al. (2006). Tumor necrosis factor alpha antagonist use and cancer in patients with rheumatoid arthritis. Arthritis Rheum.
Shin IS, Baer AN, Kwon HJ, Papadopoulos EJ, Siegel JN. (2006). Guillain-Barre and Miller Fisher syndromes occurring with tumor necrosis factor alpha antagonist therapy. Arthritis Rheum.
Slifman NR, Gershon SK, Lee JH, Edwards ET, Braun MM. (2003). Listeria monocytogenes infection as a complication of treatment with tumor necrosis factor alpha-neutralizing agents. Arthritis Rheum.
Smolen J, Kalden J, Scott D, Rozman B, Kvien T, Larsen A, et al. (1999). Efficacy and safety of leflunomide compared with placebo and sulphasalazine in active rheumatoid arthritis: a double-blind, randomised, multicentre trial. Lancet.
Smolen JS, Han C, Bala M, Maini RN, Kalden JR, van der Heijde D, et al. (2005). Evidence of radiographic benefit of treatment with infliximab plus methotrexate in rheumatoid arthritis patients who had no clinical improvement: a detailed subanalysis of data from the anti-tumor necrosis factor trial in rheumatoid arthritis with concomitant therapy study. Arthritis Rheum.
Smolen JS, Han C, van der Heijde D, Emery P, Bathon JM, Keystone E, et al. (2006). Infliximab treatment maintains employability in patients with early rheumatoid arthritis. Arthritis Rheum.
Sokka T, Pincus T. (2003). Eligibility of patients in routine care for major clinical trials of anti-tumor necrosis factor alpha agents in rheumatoid arthritis. Arthritis Rheum.
St Clair EW, van der Heijde DM, Smolen JS, Maini RN, Bathon JM, Emery P, et al. (2004). Combination of infliximab and methotrexate therapy for early rheumatoid arthritis: a randomized, controlled trial. Arthritis Rheum.
Strand V, Cohen S, Schiff M, Weaver A, Fleischmann R, Cannon G, et al. (1999). Treatment of active rheumatoid arthritis with leflunomide compared with placebo and methotrexate. Arch Intern Med.
Strand V, Tugwell P, Bombardier C, Maetzel A, Crawford B, Dorrier C, et al. (1999). Function and health-related quality of life: results from a randomized controlled trial of leflunomide versus methotrexate or placebo in patients with active rheumatoid arthritis. Leflunomide Rheumatoid Arthritis Investigators Group. Arthritis Rheum.
Suissa S, Ernst P, Hudson M, Bitton A, Kezouh A. (2004). Newer disease-modifying antirheumatic drugs and the risk of serious hepatic adverse events in patients with rheumatoid arthritis. Am J Med.
Suissa S, Hudson M, Ernst P. (2006). Leflunomide use and the risk of interstitial lung disease in rheumatoid arthritis. Arthritis Rheum.
Svensson B, Ahlmen M, Forslind K. (2003). Treatment of early RA in clinical practice: a comparative study of two different DMARD/corticosteroid options. Clin Exp Rheumatol.
Svensson B, Boonen A, Albertsson K, van der Heijde D, Keller C, Hafstrom I. (2005). Low-dose prednisolone in addition to the initial disease-modifying antirheumatic drug in patients with early active rheumatoid arthritis reduces joint destruction and increases the remission rate: a two-year randomized trial. Arthritis Rheum.
Tesser J, Fleischmann R, Dore R, Bennett R, Solinger A, Joh T, et al. (2004). Concomitant medication use in a large, international, multicenter, placebo controlled trial of anakinra, a recombinant interleukin 1 receptor antagonist, in patients with rheumatoid arthritis. J Rheumatol.
van der Heijde D, Klareskog L, Rodriguez-Valverde V, Codreanu C, Bolosiu H, Melo-Gomes J, et al. (2006). Comparison of etanercept and methotrexate, alone and combined, in the treatment of rheumatoid arthritis: two-year clinical and radiographic results from the TEMPO study, a double-blind, randomized trial. Arthritis Rheum.
van der Heijde D, Klareskog L, Singh A, Tornero J, Melo-Gomes J, Codreanu C, et al. (2006). Patient reported outcomes in a trial of combination therapy with etanercept and methotrexate for rheumatoid arthritis: the TEMPO trial. Ann Rheum Dis.
van Riel PL, Taggart AJ, Sany J, Gaubitz M, Nab HW, Pedersen R, et al. (2006). Efficacy and safety of combination etanercept and methotrexate versus etanercept alone in patients with rheumatoid arthritis with an inadequate response to methotrexate: The ADORE study. Ann Rheum Dis.
Wailoo A, Brennan A, Bansback N, Nixon R, Wolfe F, Michaud K. (2006). Modeling the cost effectiveness of etanercept, adalimumab and anakinra compared to infliximab in the treatment of patients with rheumatoid arthritis in the Medicare program.
Wallis RS, Broder MS, Wong JY, Hanson ME, Beenhouwer DO. (2004). Granulomatous infectious diseases associated with tumor necrosis factor antagonists. Clin Infect Dis.
Wasserman MJ, Weber DA, Guthrie JA, Bykerk VP, Lee P, Keystone EC. (2004). Infusion-related reactions to infliximab in patients with rheumatoid arthritis in a clinical practice setting: relationship to dose, antihistamine pretreatment, and infusion number. J Rheumatol.
Weaver AL, Lautzenheiser RL, Schiff MH, Gibofsky A, Perruquet JL, Luetkemeyer J, et al. (2006). Real-world effectiveness of select biologic and DMARD monotherapy and combination therapy in the treatment of rheumatoid arthritis: results from the RADIUS observational registry. Curr Med Res Opin.
Weinblatt M, Combe B, Covucci A, Aranda R, Becker JC, Keystone E. (2006). Safety of the selective costimulation modulator abatacept in rheumatoid arthritis patients receiving background biologic and nonbiologic disease-modifying antirheumatic drugs: A one-year randomized, placebo-controlled study. Arthritis Rheum.
Weinblatt ME, Keystone EC, Furst DE, Kavanaugh AF, Chartash EK, Segurado OG. (2006). Long term efficacy and safety of adalimumab plus methotrexate in patients with rheumatoid arthritis: ARMADA 4 year extended study. Ann Rheum Dis.
Weinblatt ME, Keystone EC, Furst DE, Moreland LW, Weisman MH, Birbara CA, et al. (2003). Adalimumab, a fully human anti-tumor necrosis factor alpha monoclonal antibody, for the treatment of rheumatoid arthritis in patients taking concomitant methotrexate: the ARMADA trial. Arthritis Rheum.
Weinblatt ME, Kremer JM, Bankhurst AD, Bulpitt KJ, Fleischmann RM, Fox RI, et al. (1999). A trial of etanercept, a recombinant tumor necrosis factor receptor:Fc fusion protein, in patients with rheumatoid arthritis receiving methotrexate. N Engl J Med.
Westhovens R, Cole JC, Li T, Martin M, Maclean R, Lin P, et al. (2006). Improved health-related quality of life for rheumatoid arthritis patients treated with abatacept who have inadequate response to anti-TNF therapy in a double-blind, placebo-controlled, multicentre randomized clinical trial. Rheumatology (Oxford).
Westhovens R, Yocum D, Han J, Berman A, Strusberg I, Geusens P, et al. (2006). The safety of infliximab, combined with background treatments, among patients with rheumatoid arthritis and various comorbidities: a large, randomized, placebo-controlled trial. Arthritis Rheum.
Wolfe F, Caplan L, Michaud K. (2006). Treatment for rheumatoid arthritis and the risk of hospitalization for pneumonia: associations with prednisone, disease-modifying antirheumatic drugs, and anti-tumor necrosis factor therapy. Arthritis Rheum.
Wolfe F, Michaud K, Anderson J, Urbansky K. (2004). Tuberculosis infection in patients with rheumatoid arthritis and the effect of infliximab therapy. Arthritis Rheum.
Wolfe F, Michaud K. (2004). Heart failure in rheumatoid arthritis: rates, predictors, and the effect of anti-tumor necrosis factor therapy. Am J Med.
Wolfe F, Michaud K. (2004). Lymphoma in rheumatoid arthritis: the effect of methotrexate and anti-tumor necrosis factor therapy in 18,572 patients. Arthritis Rheum.
Woolacott N, Bravo Vergel Y, Hawkins N, Kainth A, Khadjesari Z, Misso K, et al. (2006). Etanercept and infliximab for the treatment of psoriatic arthritis: a systematic review and economic evaluation. Health Technol Assess.
Zink A, Listing J, Kary S, Ramlau P, Stoyanova-Scholz M, Babinsky K, et al. (2005). Treatment continuation in patients receiving biological agents or conventional DMARD therapy. Ann Rheum Dis.