# Appendix D Excluded Studies

Not Published in English

1. Rau R, Wassenberg S, Zeidler H. Low Dose Prednisolone Therapy (LDPT) Retards Radiographically Detectable Destruction in Early Rheumatoid Arthritis--Preliminary Results of a Multicenter, Randomized, Parallel, Double Blind Study. Zeitschrift für Rheumatologie. 2000;59(Supple 2):II/90–6.

2. Sander O, Rau R. Treatment of Refractory Rheumatoid Arthritis With a Tumor Necrosis Factor Alpha Receptor Fusion Protein (Tnfr 55-Igg1) - a Monocentric Observation in 80 Patients. Zeitschrift fur Rheumatologie 1998;57(5):307–11.

3. Schnabel A, Reinhold K, Willmann V, Dihlmann W, Gross W. Side Effects and Efficacy of 15 Mg and 25 Mg Methotrexate Per Week in Rheumatoid Arthritis. Z Rheumatol 1994;53(3):142–9.

Wrong Outcome

4. Ang DC, Paulus HE, Louie JS. Patient’s ethnicity does not influence utilization of effective therapies in rheumatoid arthritis. J Rheumatol 2006;33(5):870–8.

5. Baslund B, Tvede N, Danneskiold-Samsoe B, Larsson P, Panayi G, Petersen J, et al. Targeting Interleukin-15 in Patients With Rheumatoid Arthritis: a Proof-of-Concept Study. Arthritis and rheumatism. 2005;52(9):2686–92.

6. Breedveld FC, Han C, Bala M, van der Heijde D, Baker D, Kavanaugh AF, et al. Association Between Baseline Radiographic Damage and Improvement in Physical Function After Treatment of Patients With Rheumatoid Arthritis. Annals of the rheumatic diseases. 2005;64(1):52–5.

7. Buch MH, Seto Y, Bingham SJ, Bejarano V, Bryer D, White J, et al. C-reactive protein as a predictor of infliximab treatment outcome in patients with rheumatoid arthritis: defining subtypes of nonresponse and subsequent response to etanercept. Arthritis Rheum 2005;52(1):42–8.

8. Buckley LM, Leib ES, Cartularo KS, Vacek PM, Cooper SM. Effects of low dose methotrexate on the bone mineral density of patients with rheumatoid arthritis. J Rheumatol 1997;24(8):1489–94.

9. Carmona L, Hernandez-Garcia C, Vadillo C, Pato E, Balsa A, Gonzalez-Alvaro I, et al. Increased risk of tuberculosis in patients with rheumatoid arthritis. J Rheumatol 2003;30(7):1436–9.

10. Cassell S, Kavanaugh AF. Therapies for psoriatic nail disease. A systematic review. J Rheumatol 2006;33(7):1452–6.

11. Cella D, Yount S, Sorensen M, Chartash E, Sengupta N, Grober J. Validation of the Functional Assessment of Chronic Illness Therapy Fatigue Scale relative to other instrumentation in patients with rheumatoid arthritis. J Rheumatol 2005;32(5):811–9.

12. Chung CP, Russell AS, Segami MI, Ugarte CA. The effect of low-dose prednisone on bone mineral density in Peruvian rheumatoid arthritis patients. Rheumatol Int 2005;25(2):114–7.

13. Colwell CW, Jr., Robinson CA, Stevenson DD, Vint VC, Morris BA. Osteonecrosis of the femoral head in patients with inflammatory arthritis or asthma receiving corticosteroid therapy. Orthopedics 1996;19(11):941–6.

14. Cooper C, Coupland C, Mitchell M. Rheumatoid arthritis, corticosteroid therapy and hip fracture. Ann Rheum Dis 1995;54(1):49–52.

15. Criswell LA, Lum RF, Turner KN, Woehl B, Zhu Y, Wang J, et al. The influence of genetic variation in the HLA-DRB1 and LTA-TNF regions on the response to treatment of early rheumatoid arthritis with methotrexate or etanercept. Arthritis Rheum 2004;50(9):2750–6.

16. Cunnane G, Madigan A, Murphy E, FitzGerald O, Bresnihan B. The effects of treatment with interleukin-1 receptor antagonist on the inflamed synovial membrane in rheumatoid arthritis. Rheumatology (Oxford) 2001;40(1):62–9.

17. Dahlqvist SR, Engstrand S, Berglin E, Johnson O. Conversion towards an atherogenic lipid profile in rheumatoid arthritis patients during long-term infliximab therapy. Scand J Rheumatol 2006;35(2):107–11.

18. di Comite G, Marinosci A, Di Matteo P, Manfredi A, Rovere-Querini P, Baldissera E, et al. Neuroendocrine modulation induced by selective blockade of TNF-alpha in rheumatoid arthritis. Ann N Y Acad Sci 2006;1069:428–37.

19. Felder M, Ruegsegger P. Bone loss in patients with rheumatoid arthritis--effect of steroids measured by low dose quantitative computed tomography. Rheumatol Int 1991;11(1):41–4.

20. Finckh A, Simard JF, Gabay C, Guerne PA. Evidence for differential acquired drug resistance to anti-tumour necrosis factor agents in rheumatoid arthritis. Ann Rheum Dis 2006;65(6):746–52.

21. Garton MJ, Reid DM. Bone mineral density of the hip and of the anteroposterior and lateral dimensions of the spine in men with rheumatoid arthritis. Effects of low-dose corticosteroids. Arthritis Rheum 1993;36(2):222–8.

22. Genant HK. Interleukin-1 Receptor Antagonist Treatment of Rheumatoid Arthritis Patients: Radiologic Progression and Correlation of Genant/Sharp and Larsen Scoring Methods. Seminars in arthritis and rheumatism. 2001;30(5 Suppl 2):26–32.

23. Georgiadis AN, Papavasiliou EC, Lourida ES, Alamanos Y, Kostara C, Tselepis AD, et al. Atherogenic lipid profile is a feature characteristic of patients with early rheumatoid arthritis: effect of early treatment--a prospective, controlled study. Arthritis Res Ther 2006;8(3):R82.

24. Gibofsky A, Palmer WR, Goldman JA, Lautzenheiser RL, Markenson JA, Weaver A, et al. Real-world utilization of DMARDs and biologics in rheumatoid arthritis: the RADIUS (Rheumatoid Arthritis Disease-Modifying Anti-Rheumatic Drug Intervention and Utilization Study) study. Curr Med Res Opin 2006;22(1):169–83.

25. Gotzsche PC, Hansen M, Stoltenberg M, Svendsen A, Beier J, Faarvang KL, et al. Randomized, Placebo Controlled Trial of Withdrawal of Slow-Acting Antirheumatic Drugs and of Observer Bias in Rheumatoid Arthritis. Scandinavian Journal of Rheumatology. 1996;25(4):194–0.

26. Grassi W, De Angelis R, Cervini C. Corticosteroid prescribing in rheumatoid arthritis and psoriatic arthritis. Clin Rheumatol 1998;17(3):223–6.

27. Haagsma CJ, Blom HJ, van Riel PL, van’t Hof MA, Giesendorf BA, van Oppenraaij-Emmerzaal D, et al. Influence of sulphasalazine, methotrexate, and the combination of both on plasma homocysteine concentrations in patients with rheumatoid arthritis. Annals Rheum Dis. 1999;58(2):79–84.

28. Hall GM, Daniels M, Doyle DV, Spector TD. Effect of hormone replacement therapy on bone mass in rheumatoid arthritis patients treated with and without steroids. Arthritis Rheum 1994;37(10):1499–505.

29. Hall GM, Spector TD, Delmas PD. Markers of bone metabolism in postmenopausal women with rheumatoid arthritis. Effects of corticosteroids and hormone replacement therapy. Arthritis Rheum 1995;38(7):902–6.

30. Hall GM, Spector TD, Griffin AJ, Jawad AS, Hall ML, Doyle DV. The effect of rheumatoid arthritis and steroid therapy on bone density in postmenopausal women. Arthritis Rheum 1993;36(11):1510–6.

31. Hansen M, Florescu A, Stoltenberg M, Podenphant J, Pedersen-Zbinden B, Horslev-Petersen K, et al. Bone loss in rheumatoid arthritis. Influence of disease activity, duration of the disease, functional capacity, and corticosteroid treatment. Scand J Rheumatol 1996;25(6):367–76.

32. Haugeberg G, Orstavik RE, Uhlig T, Falch JA, Halse JI, Kvien TK. Bone loss in patients with rheumatoid arthritis: results from a population-based cohort of 366 patients followed up for two years. Arthritis Rheum 2002;46(7):1720–8.

33. Haugeberg G, Strand A, Kvien T, Kirwan J. Reduced Loss of Hand Bone Density With Prednisolone in Early Rheumatoid Arthritis: Results From a Randomized Placebo-Controlled Trial. Archives of internal medicine. 2005;165(11):1293–7.

34. Helliwell PS. Therapies for dactylitis in psoriatic arthritis. A systematic review. J Rheumatol 2006;33(7):1439–41.

35. Jiang Y, Genant HK, Watt I, Cobby M, Bresnihan B, Aitchison R, et al. A multicenter, double-blind, dose-ranging, randomized, placebo-controlled study of recombinant human interleukin-1 receptor antagonist in patients with rheumatoid arthritis: radiologic progression and correlation of Genant and Larsen scores. Arthritis Rheum 2000;43(5):1001–9.

36. Jonsdottir T, Forslid J, van Vollenhoven A, Harju A, Brannemark S, Klareskog L, et al. Treatment with tumour necrosis factor alpha antagonists in patients with rheumatoid arthritis induces anticardiolipin antibodies. Ann Rheum Dis 2004;63(9):1075–8.

37. Josipovic B. Levels of dehydroepiandrosterone sulfate in female patients with early stage of rheumatoid arthritis. Ann N Y Acad Sci 1999;876:145–7.

38. Kalla AA, Meyers OL, Kotze TJ, Laubscher R. Corticosteroid therapy and bone mass--comparison of rheumatoid arthritis and systemic lupus erythematosus. S Afr Med J 1994;84(7):404–9.

39. Kobelt G, Eberhardt K, Geborek P. TNF inhibitors in the treatment of rheumatoid arthritis in clinical practice: costs and outcomes in a follow up study of patients with RA treated with etanercept or infliximab in southern Sweden. Ann Rheum Dis 2004;63(1):4–10.

40. Kopp S, Alstergren P, Ernestam S, Nordahl S, Bratt J. Interleukin-1beta influences the effect of infliximab on temporomandibular joint pain in rheumatoid arthritis. Scand J Rheumatol 2006;35(3):182–8.

41. Korthals-de Bos I, Van Tulder M, Boers M, Verhoeven AC, Ader HJ, Bibo J, et al. Indirect and Total Costs of Early Rheumatoid Arthritis: a Randomized Comparison of Combined Step-Down Prednisolone, Methotrexate, and Sulfasalazine With Sulfasalazine Alone. The Journal of rheumatology. 2004;31(9):1709–16.

42. Kraan MC, Reece RJ, Barg EC, Smeets TJ, Farnell J, Rosenburg R, et al. Modulation of inflammation and metalloproteinase expression in synovial tissue by leflunomide and methotrexate in patients with active rheumatoid arthritis. Findings in a prospective, randomized, double-blind, parallel-design clinical trial in thirty-nine patients at two centers. Arthritis and Rheumatism. 2000;43(8):1820–30.

43. Kroot EJ, van Gestel AM, Swinkels HL, Albers MM, van de Putte LB, van Riel PL. Chronic comorbidity in patients with early rheumatoid arthritis: a descriptive study. J Rheumatol 2001;28(7):1511–7.

44. Kuuliala A, Leirisalo-Repo M, Mottonen T, Hannonen P, Nissila M, Kautiainen H, et al. Serum soluble interleukin-2 receptor predicts early remission in patients with recent-onset rheumatoid arthritis treated with a single disease-modifying antirheumatic drug. Clinical and Experimental Rheumatology. 2005;23(2):243–6.

45. Lodder MC, de Jong Z, Kostense PJ, Molenaar ET, Staal K, Voskuyl AE, et al. Bone mineral density in patients with rheumatoid arthritis: relation between disease severity and low bone mineral density. Ann Rheum Dis 2004;63(12):1576–80.

46. Macias I, Garcia-Perez S, Ruiz-Tudela M, Medina F, Chozas N, Giron-Gonzalez JA. Modification of pro- and antiinflammatory cytokines and vascular-related molecules by tumor necrosis factor-a blockade in patients with rheumatoid arthritis. J Rheumatol 2005;32(11):2102–8.

47. Maetzel A, Strand V, Tugwell P, Wells G, Bombardier C. Economic Comparison of leflunomide and methotrexate in patients with rheumatoid arthritis: an evaluation based on a 1-year randomised controlled trial. PharmacoEconomics. 2002;20(1):61–70.

48. Marotte H, Pallot-Prades B, Grange L, Tebib J, Gaudin P, Alexandre C, et al. The shared epitope is a marker of severity associated with selection for, but not with response to, infliximab in a large rheumatoid arthritis population. Ann Rheum Dis 2006;65(3):342–7.

49. Ollendorf DA, Peterson AN, Doyle J, Huse DM. Impact of leflunomide versus biologic agents on the costs of care for rheumatoid arthritis in a managed care population. Am J Manag Care 2002;8(7 Suppl):S203–13.

50. Pincus T, Marcum SB, Callahan LF. Longterm drug therapy for rheumatoid arthritis in seven rheumatology private practices: II. Second line drugs and prednisone. J Rheumatol 1992;19(12):1885–94.

51. Quinn MA, Conaghan PG, O’Connor PJ, Karim Z, Greenstein A, Brown A, et al. Very early treatment with infliximab in addition to methotrexate in early, poor-prognosis rheumatoid arthritis reduces magnetic resonance imaging evidence of synovitis and damage, with sustained benefit after infliximab withdrawal: results from a twelve-month randomized, double-blind, placebo-controlled trial. Arthritis Rheum 2005;52(1):27–35.

52. Saliu OY, Sofer C, Stein DS, Schwander SK, Wallis RS. Tumor-necrosis-factor blockers: differential effects on mycobacterial immunity. J Infect Dis 2006;194(4):486–92.

53. Seriolo B, Paolino S, Sulli A, Fasciolo D, Cutolo M. Effects of anti-TNF-alpha treatment on lipid profile in patients with active rheumatoid arthritis. Ann N Y Acad Sci 2006;1069:414–9.

54. Seriolo B, Paolino S, Sulli A, Ferretti V, Cutolo M. Bone metabolism changes during anti-TNF-alpha therapy in patients with active rheumatoid arthritis. Ann N Y Acad Sci 2006;1069:420–7.

55. Sokka T, Mottonen T, Hannonen P. Mortality in early “sawtooth” treated rheumatoid arthritis patients during the first 8–14 years. Scand J Rheumatol 1999;28(5):282–7.

56. Sokka T, Pincus T. Contemporary disease modifying antirheumatic drugs (DMARD) in patients with recent onset rheumatoid arthritis in a US private practice: methotrexate as the anchor drug in 90% and new DMARD in 30% of patients. J Rheumatol 2002;29(12):2521–4.

57. Tascioglu F, Oner C, Armagan O. The effect of low-dose methotrexate on bone mineral density in patients with early rheumatoid arthritis. Rheumatol Int 2003;23(5):231–5.

58. Tikly M, Zannettou N, Hopley M. A longitudinal study of rheumatoid arthritis in South Africans. MedGenMed 2003;5(1):2.

59. van der Heijde D, Landewe R, Klareskog L, Rodriguez-Valverde V, Settas L, Pedersen R, et al. Presentation and analysis of data on radiographic outcome in clinical trials: experience from the TEMPO study. Arthritis Rheum 2005;52(1):49–60.

60. Verhoeven AC, Bibo JC, Boers M, Engel GL, van der Linden S. Cost-Effectiveness and cost-utility of combination therapy in early rheumatoid arthritis: randomized comparison of combined step-down prednisolone, methotrexate and sulphasalazine with sulphasalazine alone. Br J Rheumatology. 1998;37(10):1102–9.

61. Verhoeven AC, Boers M, te Koppele JM, van der Laan WH, Markusse HM, Geusens P, et al. Bone turnover, joint damage and bone mineral density in early rheumatoid arthritis treated with combination therapy including high-dose prednisolone. Rheumatology (Oxford) 2001;40(11):1231–7.

62. Wallace DJ, Metzger AL, Stecher VJ, Turnbull BA, Kern PA. Cholesterol-lowering effect of hydroxychloroquine in patients with rheumatic disease: reversal of deleterious effects of steroids on lipids. Am J Med 1990;89(3):322–6.

63. Yee CS, Filer A, Pace A, Douglas K, Situnayake D, Rowe IF. The prevalence of patients with rheumatoid arthritis in the West Midlands fulfilling the BSR criteria for anti-tumour necrosis factor therapy: an out-patient study. Rheumatology (Oxford) 2003;42(7):856–9.

Drug Not Included

64. Anderson JJ, O’Neill A, Woodworth T, Haddad J, Sewell KL, Moreland LW. Health status response of rheumatoid arthritis to treatment with Dab486il-2. Arthritis Care and Research: the official journal of the Arthritis Health Professions Association. 1996;9(2):112–9.

65. Bae SC, Corzillius M, Kuntz KM, Liang MH. Cost-effectiveness of low dose corticosteroids versus non-steroidal anti-inflammatory drugs and COX-2 specific inhibitors in the long-term treatment of rheumatoid arthritis. Rheumatology (Oxford) 2003;42(1):46–53.

66. Blyth T, Hunter JA, Stirling A. Pain relief in the rheumatoid knee after steroid injection. A single-blind comparison of hydrocortisone succinate, and triamcinolone acetonide or hexacetonide. Br J Rheumatol 1994;33(5):461–3.

67. Capell H, Marabani M, Madhok R, Torley H, Hunter J. Degree and extent of response to sulphasalazine or penicillamine therapy for rheumatoid arthritis: results from a routine clinical environment over a two-year period. The Quarterly Journal of Medicine. 1990;75(276):335–44.

68. Capell HA, Madhok R, Hunter JA, Porter D, Morrison E, Larkin J, et al. Lack of radiological and clinical benefit over two years of low dose prednisolone for rheumatoid arthritis: results of a randomised controlled trial. Ann Rheum Dis 2004;63(7):797–803.

69. Capell HA, Murphy EA, Hunter JA. Rheumatoid arthritis: workload and outcome over 10 years. Q J Med 1991;79(290):461–76.

70. Choy EH, Kingsley GH, Khoshaba B, Pipitone N, Scott DL. A Two Year Randomised Controlled Trial of Intramuscular Depot Steroids in Patients With Established Rheumatoid Arthritis Who Have Shown an Incomplete Response to Disease Modifying Antirheumatic Drugs. Ann Rheum Dis 2005;64(9):1288–93.

71. Choy EHS, Scott DL, Kingsley GH, Williams P, Wojtulewski J, Papasavvas G, et al. Treating rheumatoid arthritis early with disease modifying drugs reduces joint damage: a randomised double blind trial of sulphasalazine vs diclofenac sodium. Clinical and Experimental Rheumatology. 2002;20(3):351–8.

72. Conaghan PG, O’Connor P, McGonagle D, Astin P, Wakefield RJ, Gibbon WW, et al. Elucidation of the relationship between synovitis and bone damage: a randomized magnetic resonance imaging study of individual joints in patients with early rheumatoid arthritis. Arthritis Rheum 2003;48(1):64–71.

73. Doran MF, Crowson CS, Pond GR, O’Fallon WM, Gabriel SE. Frequency of infection in patients with rheumatoid arthritis compared with controls: a population-based study. Arthritis Rheum 2002;46(9):2287–93.

74. Eberhardt R, Kruger K, Reiter W, Gross W, Zwingers T. Long-term therapy with the new glucocorticosteroid deflazacort in rheumatoid arthritis. Double-blind controlled randomized 12-months study against prednisone. Arzneimittelforschung 1994;44(5):642–7.

75. Egsmose C, TM H, Andersen LS, Beier JM, Christensen L, Ejstrup L, et al. Limited effect of sulphasalazine treatment in reactive arthritis. A randomised double blind placebo controlled trial. Annals Rheum Dis. 1997;56(1):32–6.

76. Felson DT, Anderson JJ, Meenan RF. The efficacy and toxicity of combination therapy in rheumatoid arthritis. A meta-analysis. Arthritis Rheum 1994;37(10):1487–91.

77. Ferraz MB, Pinheiro GR, Helfenstein M, Albuquerque E, Rezende C, Roimicher L, et al. Combination therapy with methotrexate and chloroquine in rheumatoid arthritis. A multicenter randomized placebo-controlled trial. Scandinavian J of Rheum. 1994;23(5):231–6.

78. Fraser AD, van Kuijk AWR, Westhovens R, Karim Z, Wakefield R, Gerards AH, et al. A randomised, double blind, placebo controlled, multicentre trial of combination therapy with methotrexate plus ciclosporin in patients with active psoriatic arthritis. Ann Rheum Dis. 2005;64(6):859–64.

79. Furtado RN, Oliveira LM, Natour J. Polyarticular corticosteroid injection versus systemic administration in treatment of rheumatoid arthritis patients: a randomized controlled study. J Rheumatol 2005;32(9):1691–8.

80. Gøtzsche P, Johansen H. Short-term low-dose corticosteroids vs placebo and nonsteroidal antiinflammatory drugs in rheumatoid arthritis. The Cochrane Database of Systematic Reviews 2005;2005(1).

81. Gough A, Sheeran T, Arthur V, Panayi G, Emery P. Adverse interaction between intramuscular methylprednisolone and sulphasalazine in patients with early rheumatoid arthritis. A pilot study. Scand J Rheumatol 1994;23(1):46–8.

82. Gray RE, Doherty SM, Galloway J, Coulton L, de Broe M, Kanis JA. A double-blind study of deflazacort and prednisone in patients with chronic inflammatory disorders. Arthritis Rheum 1991;34(3):287–95.

83. Griffith SM, Fisher J, Clarke S, Montgomery B, Jones PW, Saklatvala J, et al. Do patients with rheumatoid arthritis established on methotrexate and folic acid 5 mg daily need to continue folic acid supplements long term? Rheumatology (Oxford) 2000;39(10):1102–9.

84. Hannonen P, Mottonen T, Hakola M, Oka M. Sulfasalazine in early rheumatoid arthritis. A 48-week double-blind, prospective, placebo-controlled study. Arthritis and Rheumatism. 1993;36(11):1501–9.

85. Hetland ML, Stengaard-Pedersen K, Junker P, Lottenburger T, Ellingsen T, Andersen LS, et al. Combination treatment with methotrexate, cyclosporine, and intraarticular betamethasone compared with methotrexate and intraarticular betamethasone in early active rheumatoid arthritis: an investigator-initiated, multicenter, randomized, double-blind, parallel-group, placebo-controlled study. Arthritis Rheum 2006;54(5):1401–9.

86. Jessop JD, O’Sullivan MM, Lewis PA, Williams LA, Camilleri JP, Plant MJ, et al. A long-term five-year randomized controlled trial of hydroxychloroquine, sodium aurothiomalate, auranofin and penicillamine in the treatment of patients with rheumatoid AArthritis. Br J Rheum. 1998;37(9):992–1002.

87. Jeurissen ME, Boerbooms AM, van de Putte LB, Doesburg WH, Mulder J, Rasker JJ, et al. Methotrexate versus azathioprine in the treatment of rheumatoid arthritis. A forty-eight-week randomized, double-blind trial. Arthritis Rheum 1991;34(8):961–72.

88. Johnsen AK, Schiff MH, Mease PJ, Moreland LW, Maier AL, Coblyn JS, et al. Comparison of 2 doses of etanercept (50 vs 100 mg) in active rheumatoid arthritis: a randomized double blind study. J Rheumatol 2006;33(4):659–64.

89. Kirwan J, Byron M, Watt I. The relationship between soft tissue swelling, Joint space narrowing and erosive damage in hand x-rays of patients with rheumatoid arthritis. Rheumatology (Oxford) 2001;40(3):688–95.

90. Kirwan JR. The effect of glucocorticoids on joint destruction in rheumatoid arthritis. The arthritis and rheumatism council low-dose glucocorticoid study group. N Engl J Med 1995;333(3):142–6.

91. Lambert CM, Sandhu S, Lochhead A, Hurst NP, McRorie E, Dhillon V. Dose escalation of parenteral methotrexate in active rheumatoid arthritis that has been unresponsive to conventional doses of methotrexate: a randomized, controlled trial. Arthritis and Rheumatism. 2004;50(2):364–71.

92. Lard LR, Visser H, Speyer I, vander Horst-Bruinsma IE, Zwinderman AH, Breedveld FC, et al. Early versus delayed treatment in patients with recent-onset rheumatoid arthritis: comparison of two cohorts who received different treatment strategies. Am J Med 2001;111(6):446–51.

93. Lerndal T, Svensson B. A clinical study of Cph 82 vs methotrexate in early rheumatoid arthritis. Rheumatology (Oxford) 2000;39(3):316–20.

94. Messina OD, Barreira JC, Zanchetta JR, Maldonado-Cocco JA, Bogado CE, Sebastian ON, et al. Effect of low doses of deflazacort vs prednisone on bone mineral content in premenopausal rheumatoid arthritis. J Rheumatol 1992;19(10):1520–6.

95. Mladenovic V, Domljan Z, Rozman B, Jajic I, Mihajlovic D, Dordevic J, et al. Safety and effectiveness of leflunomide in the treatment of patients with active rheumatoid arthritis. Results of a randomized, placebo-controlled, Phase II Study. Arthritis and Rheumatism. 1995;38(11):1595–603.

96. Moreland L, R G, King K, Chase W, Weisman M, Greco T, et al. Results of a phase-I/II randomized, masked, placebo-controlled trial of recombinant human nterleukin-11 (Rhil-11) in the treatment of subjects with active rheumatoid arthritis. Arthritis Res 2001;3(4):247–52.

97. Nishimoto N, Yoshizaki K, Miyasaka N, Yamamoto K, Kawai S, Takeuchi T, et al. Treatment of rheumatoid arthritis with humanized anti-interleukin-6 receptor antibody: a multicenter, double-blind, placebo-controlled ttrial. Arthritis and Rheumatism. 2004;50(6):1761–9.

98. Paulus HE, Di Primeo D, Sanda M, Lynch JM, Schwartz BA, Sharp JT, et al. Progression of radiographic joint erosion during low dose corticosteroid treatment of rheumatoid arthritis. J Rheumatol 2000;27(7):1632–7.

99. Peltomaa R, Paimela L, Helve T, Leirisalo-Repo M. Comparison of intramuscular gold and sulphasalazine in the treatment of early rheumatoid arthritis. A one year prospective study. Scand J Rheum. 1995;24(6):330–5.

100. Perdriger A, Mariette X, Kuntz JL, Brocq O, Kara-Terki R, Loet XL, et al. Safety of infliximab used in combination with leflunomide or azathioprine in daily clinical practice. J Rheumatol 2006;33(5):865–9.

101. Plant M, O’Sullivan MM, Lewis P, Camilleri J, Coles E, Jessop J. What factors influence functional ability in patients with rheumatoid arthritis. Do they alter over time? Rheumatology (Oxford) 2005;44(9):1181–5.

102. Porter D, McInnes I, Hunter J, Capell H. Outcome of second line therapy in rheumatoid arthritis. Annals of the rheumatic diseases. 1994;53(12):812–5.

103. Sany J, Kaiser MJ, Jorgensen C, Trape G. Study of the tolerance of infliximab infusions with or without betamethasone premedication in patients with active rheumatoid arthritis. Ann Rheum Dis 2005;64(11):1647–9.

104. Suarez Almazor M, Belseck E, Shea BJ, Homik J, Wells G, Tugwell P. Antimalarials for treating rheumatoid arthritis. The Cochrane Database of Systematic Reviews 2000;2000(4).

105. Suarez Almazor M, Belseck E, Shea BJ, Tugwell P, Wells G. Methotrexate for treating rheumatoid arthritis. The Cochrane Database of Systematic Reviews 1998;1998(2).

106. Suarez Almazor M, Belseck E, Shea BJ, Tugwell P, Wells G. Sulfasalazine for treating rheumatoid arthritis. The Cochrane Database of Systematic Reviews 1998;1998(2).

107. Suarez Almazor M, Spooner C, Belseck E. Azathioprine for treating rheumatoid arthritis. The Cochrane Database of Systematic Reviews 2000;2000(4).

108. Tebib JG, Manil LM, Modder G, Verrier P, De Rycke Y, Bonmartin A, et al. Better results with rhenium-186 radiosynoviorthesis than with cortivazol in rheumatoid arthritis (RA): a two-year follow-up randomized controlled multicentre study. Clinical and Experimental Rheumatology. 2004;22(5):609–16.

109. The Australian Multicentre Clinical Trial Group. Sulfasalazine in early rheumatoid arthritis. J Rheumatol 1992;19(11):1672.

110. Tsakonas E, Fitzgerald AA, Fitzcharles MA, Cividino A, Thorne JC, M’Seffar A, et al. Consequences of delayed therapy with second-line agents in rheumatoid arthritis: a 3 year followup on the hydroxychloroquine in early rheumatoid arthritis (HERA) study. J Rheumatol 2000;27(3):623–9.

111. van der Heide A, Jacobs JW, Bijlsma JW, Heurkens AH, van Booma-Frankfort C, van der Veen MJ, et al. The effectiveness of early treatment with “second-line” antirheumatic drugs. A randomized, controlled trial. Ann Intern Med 1996;124(8):699–707.

112. van Everdingen AA, Jacobs JWG, Siewertsz Van Reesema DR, Bijlsma JWJ. Low-dose prednisone therapy for patients with early active rheumatoid aArthritis: cinical efficacy, disease-modifying properties, and side effects: a randomized, double-blind, placebo-controlled clinical trial. Annals of Internal Medicine. 2002;136(1):1–12.

113. van Everdingen AA, Siewertsz van Reesema DR, Jacobs JWG, Bijlsma JWJ. Low-dose glucocorticoids in early rheumatoid arthritis: discordant effects on bone mineral density and fractures? Clinical and Experimental Rheumatology. 2003;21(2):155–60.

114. van Jaarsveld CH, Jacobs JW, van der Veen MJ, Blaauw AA, Kruize AA, Hofman DM, et al. Aggressive treatment in early rheumatoid arthritis: a randomised controlled trial. Annals of the Rheumatic Diseases 2000;59(6):468–77.

115. van Jaarsveld CH, Jahangier ZN, Jacobs JW, Blaauw AA, van Albada-Kuipers GA, ter Borg EJ, et al. Toxicity of anti-rheumatic drugs in a randomized clinical trial of early rheumatoid arthritis. Rheumatology (Oxford) 2000;39(12):1374–82.

116. van Schaardenburg D, Valkema R, Dijkmans BA, Papapoulos S, Zwinderman AH, Han KH, et al. Prednisone treatment of elderly-onset rheumatoid arthritis. Disease activity and bone mass in comparison with chloroquine treatment. Arthritis and Rheumatism. 1995;38(3):334–42.

117. Verhoeven AC, Boers M, Tugwell P. Combination therapy in rheumatoid arthritis: updated systematic review. Br J Rheumatol 1998;37(6):612–9.

118. Verstappen S, van Albada Kuipers G, Bijlsma J, Blaauw A, Schenk Y, Haanen H, et al. A good response to early DMARD treatment of patients with rheumatoid arthritis in the first year predicts remission during follow up. Ann Rheum Dis 2005;64(1):38–43.

119. Verstappen SMM, Jacobs JWG, Bijlsma JWJ, Heurkens AHM, van Booma-Frankfort C, Borg EJt, et al. Five-year followup of rheumatoid arthritis patients after early treatment with disease-modifying antirheumatic drugs versus treatment according to the pyramid approach in the first year. Arthritis and Rheumatism. 2003;48(7):1797–807.

120. Wallberg-Jonsson S, Ohman ML, Dahlqvist SR. Cardiovascular morbidity and mortality in patients with seropositive rheumatoid arthritis in Northern Sweden. J Rheumatol 1997;24(3):445–51.

121. Wassenberg S, Rau R, Steinfeld P, Zeidler H. Very low-dose prednisolone in early rheumatoid arthritis retards radiographic progression over two years: a multicenter, double-blind, placebo-controlled trial. Arthritis and Rheumatism. 2005;52(11):3371–80.

122. Weinblatt ME, Kaplan H, Germain BF, Merriman RC, Solomon SD, Wall B, et al. Methotrexate in rheumatoid arthritis: effects on disease activity in a multicenter prospective study. The Journal of Rheumatology. 1991;18(3):334–8.

123. Wolfe F, Hawley DJ. The comparative risk and predictors of adverse gastrointestinal events in rheumatoid arthritis and osteoarthritis: a prospective 13 year study of 2131 patients. J Rheumatol 2000;27(7):1668–73.

Population Not Included

124. Boss B, Neeck G, Engelhardt B, Riedel W. Influence of corticosteroids on neutrophils, lymphocytes, their subsets, and T-cell activity markers in patients with active rheumatoid arthritis, compared to healthy controls. Ann N Y Acad Sci 1999;876:198–200.

125. Cheifetz A, Smedley M, Martin S, Reiter M, Leone G, Mayer L, et al. The incidence and management of infusion reactions to infliximab: a large center experience. Am J Gastroenterol 2003;98(6):1315–24.

126. Feagan BG, Yan S, Bala M, Bao W, Lichtenstein GR. The effects of infliximab maintenance therapy on health-related quality of life. Am J Gastroenterol 2003;98(10):2232–8.

127. Fernandez-Nebro A, Tomero E, Ortiz-Santamaria V, Castro MC, Olive A, de Haro M, et al. Treatment of rheumatic inflammatory disease in 25 patients with secondary amyloidosis using tumor necrosis factor alpha antagonists. Am J Med 2005;118(5):552–6.

Wrong Publication Type

128. Anakinra (Kineret) for rheumatoid arthritis. Med Lett Drugs Ther 2002;44(1124):18–9.

129. Is it true that vaccines may not be safe for people with rheumatoid arthritis (which I have)? Does that mean I shouldn’t get a flu shot? Johns Hopkins Med Lett Health After 50 2004;17(8):8.

130. Anandacoomarasamy A, Kannangara S, Barnsley L. Cutaneous vasculitis associated with infliximab in the treatment of rheumatoid arthritis. Intern Med J 2005;35(10):638–40.

131. Andres E, Limbach FX, Goichot B, Sibilia J. Silent thyroiditis associated with etanercept in rheumatoid arthritis. Ann Rheum Dis 2002;61(6):565.

132. Arend SM, Kuijper EJ, Allaart CF, Muller WH, Van Dissel JT. Cavitating pneumonia after treatment with infliximab and prednisone. Eur J Clin Microbiol Infect Dis 2004;23(8):638–41.

133. Armstrong DJ, McCarron MT, Wright GD. Successful treatment of rheumatoid vasculitis-associated foot-drop with infliximab. J Rheumatol 2005;32(4):759; author reply 759–60.

134. Arnold EL, Khanna D, Paulus H, Goodman MP. Acute injection site reaction to intraarticular etanercept administration. Arthritis Rheum 2003;48(7):2078–9.

135. Ashok D, Ayliffe WH, Kiely PD. Necrotizing scleritis associated with rheumatoid arthritis: long-term remission with high-dose infliximab therapy. Rheumatology (Oxford) 2005;44(7):950–1.

136. Asli B, Wechsler B, Lemaitre C. Inhibition of tumor necrosis factor alpha and ankylosing spondylitis. N Engl J Med 2003;348(4):359–61; author reply 359–61.

137. Bankhurst AD. Etanercept and methotrexate combination therapy. Clin Exp Rheumatol 1999;17(6 Suppl 18):S69–72.

138. Bartke U, Venten I, Kreuter A, Gubbay S, Altmeyer P, Brockmeyer NH. Human immunodeficiency virus-associated psoriasis and psoriatic arthritis treated with infliximab. Br J Dermatol 2004;150(4):784–6.

139. Bennett AN, Wong M, Zain A, Panayi G, Kirkham B. Adalimumab-induced asthma. Rheumatology (Oxford) 2005;44(9):1199–200.

140. Bleumink GS, ter Borg EJ, Ramselaar CG, Ch Stricker BH. Etanercept-induced subacute cutaneous lupus erythematosus. Rheumatology (Oxford) 2001;40(11):1317–9.

141. Boatright MD, Wang BW. Clinical infection with strongyloides sterocoralis following etanercept use for rheumatoid arthritis. Arthritis Rheum 2005;52(4):1336–7.

142. Brocq O, Albert C, Roux C, Gerard D, Breuil V, Ziegler LE. Adalimumab in rheumatoid arthritis after failed infliximab and/or etanercept therapy: experience with 18 patients. Joint Bone Spine 2004;71(6):601–3.

143. Burls A, Clark WK, Jobanputra P. Anakinra for rheumatoid arthritis. The Cochrane Database of Systematic Reviews 2005;2005(1).

144. Chevillotte-Maillard H, Ornetti P, Mistrih R, Sidot C, Dupuis J, Dellas JA, et al. Survival and safety of treatment with infliximab in the elderly population. Rheumatology (Oxford) 2005;44(5):695–6.

145. Clelland S, Hunek JR. Etanercept injection site reaction. Dermatol Nurs 2005;17(5):375-.

146. Clunie G, Voules S, Watts R. Dose reduction of etanercept--can we treat more patients using a fixed budget? Rheumatology (Oxford) 2003;42(4):600–1.

147. Cobo Ibanez T, Yehia Tayel M, Balsa Criado A, Hernandez Sanz A, Martin Mola E. Safety and efficacy of leflunomide and infliximab versus methotrexate and infliximab combination therapy in rheumatoid arthritis. Rheumatology (Oxford) 2005;44(11):1467–8.

148. Cocito D, Bergamasco B, Tavella A, Poglio F, Paolasso I, Costa P, et al. Multifocal motor neuropathy during treatment with infliximab. J Peripher Nerv Syst 2005;10(4):386–7.

149. Cohen CD, Horster S, Sander CA, Bogner JR. Kaposi’s sarcoma associated with tumour necrosis factor alpha neutralising therapy. Ann Rheum Dis 2003;62(7):684.

150. Cohen JD, Zaltni S, Kaiser MJ, Bozonnat MC, Jorgensen C, Daures JP, et al. Secondary addition of methotrexate to partial responders to etanercept alone is effective in severe rheumatoid arthritis. Ann Rheum Dis 2004;63(2):209–10.

151. Cohen MD, Conn DL. Benefits of low-dose corticosteroids in rheumatoid arthritis. Bull Rheum Dis 1997;46(4):4–7.

152. Cunnane G, Warnock M, Fye KH, Daikh DI. Accelerated nodulosis and vasculitis following etanercept therapy for rheumatoid arthritis. Arthritis Rheum 2002;47(4):445–9.

153. Day R. Adverse reactions to TNF-alpha inhibitors in rheumatoid arthritis. Lancet 2002;359(9306):540–1.

154. De Bandt M, Vittecoq O, Descamps V, Le Loet X, Meyer O. Anti-TNF-alpha-induced systemic lupus syndrome. Clin Rheumatol 2003;22(1):56–61.

155. Dumont-Berset M, Laffitte E, Gerber C, Dudler J, Panizzon RG. Eczematous drug eruption after infliximab. Br J Dermatol 2004;151(6):1272–3.

156. Emery P. Disease modification in rheumatoid arthritis with leflunomide. Scandinavian Journal of Rheumatology. Supplement. 1999;112(9):9–14.

157. Favalli EG, Arreghini M, Arnoldi C, Panni B, Marchesoni A, Tosi S, et al. Anti-tumor necrosis factor alpha switching in rheumatoid arthritis and juvenile chronic arthritis. Arthritis Rheum 2004;51(2):301–2.

158. Franklin CM. Clinical experience with soluble TNF p75 receptor in rheumatoid arthritis. Semin Arthritis Rheum 1999;29(3):172–81.

159. Furst DE. Anakinra: review of recombinant human interleukin-I receptor antagonist in the treatment of rheumatoid arthritis. Clin Ther 2004;26(12):1960–75.

160. Goldenberg MM. Etanercept, a novel drug for the treatment of patients with severe, active rheumatoid arthritis. Clin Ther 1999;21(1):75–87; discussion 1–2.

161. Hirche D, Rubbert A, Lunau L, Krieg T, Eming SA. Successful treatment of refractory rheumatoid arthritis-associated leg ulcerations with adalimumab. Br J Dermatol 2005;152(5):1062–4.

162. Hoshida Y, Yamamoto S, Wada N, Xu JX, Sasaki T, Aozasa K. Infliximab-associated lymphoproliferative disorders. Int J Hematol 2005;81(4):356–7.

163. Hrycaj P, Korczowska I, Lacki JK. Severe Parkinson’s disease in rheumatoid arthritis patient treated with infliximab. Rheumatology (Oxford) 2003;42(5):702–3.

164. Inoue K, Takano H, Yanagisawa R, Yoshikawa T. Effects of tumor necrosis factor-alpha inhibitors on lung lesions with rheumatoid arthritis. Chest 2003;124(1):413–4; author reply 414.

165. Kaiser MJ, Bozonnat MC, Jorgensen C, Daures JP, Sany J. Effect of etanercept on tenosynovitis and nodules in rheumatoid arthritis. Arthritis Rheum 2002;46(2):559–60.

166. Kelaidi C, Tulliez M, Lecoq-Lafon C, Pham XV, Kahan A, Dreyfus F, et al. Long-term remission of an EBV-positive B cell lymphoproliferative disorder associated with rheumatoid arthritis under methotrexate with anti-CD20 monoclonal antibody (Rituximab) monotherapy. Leukemia 2002;16(10):2173–4.

167. Kemp E, Nielsen H, Petersen LJ, Gam AN, Dahlager J, Horn T, et al. Newer immunomodulating drugs in rheumatoid arthritis may precipitate glomerulonephritis. Clin Nephrol 2001;55(1):87–8.

168. Kempeni J. Preliminary results of early clinical trials with the fully human anti-TNFalpha monoclonal antibody D2E7. Ann Rheum Dis 1999;58(90001):70i–72.

169. Kempeni J. Update on D2E7: a fully human anti-tumour necrosis factor alpha monoclonal antibody. Ann Rheum Dis 2000;59(90001):44i–45.

170. Kirwan J, Shea B, Boers M. Glucocorticoids for Slowing Radiological Progression in Rheumatoid Arthritis. The Cochrane Database of Systematic Reviews 2005;2005(1).

171. Korkmaz C, Kasifoglu T, Yasar B. Acceleration of left-ventricular diastolic dysfunction and pulmonary hypertension after TNF-alpha blocker. Ann Pharmacother 2005;39(6):1138–9.

172. Kramer N, Chuzhin Y, Kaufman LD, Ritter JM, Rosenstein ED. Methotrexate pneumonitis after initiation of infliximab therapy for rheumatoid arthritis. Arthritis Rheum 2002;47(6):670–1.

173. Kremer JM. Safety, efficacy, and mortality in a long-term cohort of patients with rheumatoid arthritis taking methotrexate: followup after a mean of 13.3 years. Arthritis Rheum 1997;40(5):984–5.

174. Kreuter A, Rose C, Zillikens D, Altmeyer P. Bullous rheumatoid neutrophilic dermatosis. J Am Acad Dermatol 2005;52(5):916–8.

175. Kucharz EJ, Gozdzik J, Kopec M, Kotulska A, Lewicki M, Pieczyrak R, et al. A single infusion of infliximab increases the serum endostatin level in patients with rheumatoid arthritis. Clin Exp Rheumatol 2003;21(2):273–4.

176. Kurschat P, Rubbert A, Poswig A, Scharffetter-Kochanek K, Krieg T, Hunzelmann N. Treatment of psoriatic arthritis with etanercept. J Am Acad Dermatol 2001;44(6):1052.

177. Liberopoulos EN, Drosos AA, Elisaf MS. Exacerbation of tuberculosis enteritis after treatment with infliximab. Am J Med 2002;113(7):615.

178. Manadan AM, Block JA, Sequeira W. Mycobacteria tuberculosis peritonitis associated with etanercept therapy. Clin Exp Rheumatol 2003;21(4):526.

179. Mang R, Stege H, Ruzicka T, Krutmann J. Response of severe psoriasis to infliximab. Dermatology 2002;204(2):156–7.

180. Marchesoni A, Puttini PS, Gorla R, Caporali R, Arnoldi C, Atzeni F, et al. Cyclosporine in addition to infliximab and methotrexate in refractory rheumatoid arthritis. Clin Exp Rheumatol 2005;23(6):916–7.

181. McCain ME, Quinet RJ, Davis WE. Etanercept and infliximab associated with cutaneous vasculitis. Rheumatology (Oxford) 2002;41(1):116–7.

182. Mease PJ. Cytokine blockers in psoriatic arthritis. Annals of the Rheumatic Diseases. 2001;60(Suppl 3):iii37–40.

183. Mease PJ. Adalimumab: an anti-TNF agent for the treatment of psoriatic arthritis. Expert Opin Biol Ther 2005;5(11):1491–504.

184. Michaelsson G, Kajermo U, Michaelsson A, Hagforsen E. Infliximab can precipitate as well as worsen palmoplantar pustulosis: possible linkage to the expression of tumour necrosis factor-alpha in the normal palmar eccrine sweat duct? Br J Dermatol 2005;153(6):1243–4.

185. Misery L, Perrot JL, Gentil-Perret A, Pallot-Prades B, Cambazard F, Alexandre C. Dermatological complications of etanercept therapy for rheumatoid arthritis. Br J Dermatol 2002;146(2):334–5.

186. Molloy E, Ramakrishnan S, Murphy E, Barry M. Morbidity and mortality in rheumatoid patients during treatment with adalimumab and infliximab. Rheumatology (Oxford) 2004;43(4):522–3.

187. Montagna GL, Malesci D, Buono R, Valentini G. Asthenoazoospermia in patients receiving anti-tumour necrosis factor {alpha} agents. Ann Rheum Dis 2005;64(11):1667.

188. Murphy FT, Enzenauer RJ, Battafarano DF, David-Bajar K. Etanercept-associated injection-site reactions. Arch Dermatol 2000;136(4):556–7.

189. Musial J, Undas A, Celinska-Lowenhoff M. Polymyositis associated with infliximab treatment for rheumatoid arthritis. Rheumatology (Oxford) 2003;42(12):1566–8.

190. Nakelchik M, Mangino JE. Reactivation of histoplasmosis after treatment with infliximab. Am J Med 2002;112(1):78.

191. Nikas SN, Temekonidis TI, Zikou AK, Argyropoulou MI, Efremidis S, Drosos AA. Treatment of resistant rheumatoid arthritis by intra-articular infliximab injections: a pilot study. Ann Rheum Dis 2004;63(1):102–3.

192. Nikas SN, Voulgari PV, Takalou IP, Katsimbri P, Drosos AA. Healing of psoriatic skin lesions, and improvement of psoriatic arthritis resistant to immunosuppressive drugs, after infliximab treatment. Ann Rheum Dis 2005;64(11):1665–7.

193. Novak S, Cikes N. Infliximab-induced lupus or rheumatoid arthritis (RA) overlapping with systemic lupus erythematosus (SLE) unmasked by infliximab. Clin Exp Rheumatol 2004;22(2):268.

194. Ornetti P, Solau E, Gaudin P, Sibilia J, Berthelot JM, Puechal X, et al. Increase in methotrexate dose in patients with rheumatoid arthritis who have an inadequate response to infliximab. Ann Rheum Dis 2005;64(9):1379–80.

195. Ostor AJ, Crisp AJ, Somerville MF, Scott DG. Fatal exacerbation of rheumatoid arthritis associated fibrosing alveolitis in patients given infliximab. BMJ 2004;329(7477):1266.

196. Ostrov BE. Beneficial effect of etanercept on rheumatoid lymphedema. Arthritis Rheum 2001;44(1):240–1.

197. Pagliano P, Attanasio V, Fusco U, Mohamed DA, Rossi M, Faella FS. Does etanercept monotherapy enhance the risk of Listeria monocytogenes meningitis? Ann Rheum Dis 2004;63(4):462–3.

198. Popovic M, Stefanovic D, Pejnovic N, Popovic R, Glisic B, Obradovic S, et al. Comparative study of the clinical efficacy of four DMARDs (leflunomide, methotrexate, cyclosporine, and levamisole) in patients with rheumatoid arthritis. Transplant Proc 1998;30(8):4135–6.

199. Provenzano G, Termini A, Le Moli C, Rinaldi F. Efficacy of infliximab in psoriatic arthritis resistant to treatment with disease modifying antirheumatic drugs: an open pilot study. Ann Rheum Dis 2003;62(7):680–1.

200. Reddy AR, Backhouse OC. Does etanercept induce uveitis? Br J Ophthalmol 2003;87(7):925.

201. Richter C, Wanke L, Steinmetz J, Reinhold-Keller E, Gross WL. Mononeuritis secondary to rheumatoid arthritis responds to etanercept. Rheumatology (Oxford) 2000;39(12):1436–7.

202. Rinaldi F, Provenzano G, Termini A, Spinello M, La Seta F. Long term infliximab treatment for severe psoriatic arthritis: evidence of sustained clinical and radiographic response. Ann Rheum Dis 2005;64(9):1375–6.

203. Rozman B. Clinical Experience With Leflunomide in Rheumatoid Arthritis. The Journal of rheumatology. 1998;52(Suppl):27–32.

204. Russell E, Zeihen M, Wergin S, Litton T. Patients receiving etanercept may develop antibodies that interfere with monoclonal antibody laboratory assays. Arthritis Rheum 2000;43(4):944.

205. Scott DL, Kingsley GH. Tumor necrosis factor inhibitors for rheumatoid arthritis. N Engl J Med 2006;355(7):704–12.

206. Sholsberg J, Jackson R. Best evidence topic report. Intra-articular corticosteroid injections in acute rheumatoid monoarthritides. Emerg Med J 2004;21(2):204.

207. Simpson D, Scott LJ. Adalimumab : in psoriatic arthritis. Drugs 2006;66(11):1487–96.

208. Smith D, Letendre S. Viral pneumonia as a serious complication of etanercept therapy. Ann Intern Med 2002;136(2):174.

209. Soliotis F, Glover M, Jawad AS. Severe skin reaction after leflunomide and etanercept in a patient with rheumatoid arthritis. Ann Rheum Dis 2002;61(9):850–1.

210. Vis M, Voskuyl AE, Wolbink GJ, Dijkmans BA, Lems WF. Bone mineral density in patients with rheumatoid arthritis treated with infliximab. Ann Rheum Dis 2005;64(2):336–7.

211. Vis M, Wolbink GJ, Lodder MC, Kostense PJ, van de Stadt RJ, de Koning MH, et al. Early changes in bone metabolism in rheumatoid arthritis patients treated with infliximab. Arthritis Rheum 2003;48(10):2996–7.

212. Yazici Y, Erkan D, Lockshin MD. Etanercept in the treatment of severe, resistant psoriatic arthritis: continued efficacy and changing patterns of use after two years. Clin Exp Rheumatol 2002;20(1):115.

Wrong Study Design

213. Summaries for patients. Tumor necrosis factor antagonists and heart failure. Ann Intern Med 2003;138(10):I48.

214. Abramovits W, Arrazola P, Gupta AK. Enbrel (etanercept). Skinmed 2004;3(6):333–5.

215. Aggarwal A, Panda S, Misra R. Effect of etanercept on matrix metalloproteinases and angiogenic vascular endothelial growth factor: a time kinetic study. Ann Rheum Dis 2004;63(7):891–2.

216. Ang HT, Helfgott S. Do the clinical responses and complications following etanercept or infliximab therapy predict similar outcomes with the other tumor necrosis factor-alpha antagonists in patients with rheumatoid arthritis? J Rheumatol 2003;30(11):2315–8.

217. Antoni C, Dechant C, Hanns-Martin Lorenz PD, Wendler J, Ogilvie A, Lueftl M, et al. Open-label study of infliximab treatment for psoriatic arthritis: clinical and magnetic resonance imaging measurements of reduction of inflammation. Arthritis Rheum 2002;47(5):506–12.

218. Antoni C, Kalden J. Combination therapy of the chimeric monoclonal anti-tumor necrosis factor alpha antibody (Infliximab) with methotrexate in patients with rheumatoid arthritis. Clinical and Experimental Rheumatology. 1999;17(6 Suppl 18):S73–7.

219. Argyropoulou MI, Glatzouni A, Voulgari PV, Xydis VG, Nikas SN, Efremidis SC, et al. Magnetic resonance imaging quantification of hand synovitis in patients with rheumatoid arthritis treated with infliximab. Joint Bone Spine 2005;72(6):557–61.

220. Baumgartner SW, Fleischmann RM, Moreland LW, Schiff MH, Markenson J, Whitmore JB. Etanercept (Enbrel) in patients with rheumatoid arthritis with recent onset versus established disease: improvement in disability. J Rheumatol 2004;31(8):1532–7.

221. Bibbo C, Goldberg JW. Infectious and healing complications after elective orthopaedic foot and ankle surgery during tumor necrosis factor-alpha inhibition therapy. Foot Ankle Int 2004;25(5):331–5.

222. Bologna C, Jorgensen C, Sany J. Association of methotrexate and corticosteroids in the treatment of patients with rheumatoid arthritis. Clin Exp Rheumatol 1996;14(4):401–6.

223. Bresnihan B, Newmark R, Robbins S, Genant HK. Effects of anakinra monotherapy on joint damage in patients with rheumatoid arthritis. Extension of a 24-week randomized, placebo-controlled trial. J Rheumatol 2004;31(6):1103–11.

224. Buckley LM, Leib ES, Cartularo KS, Vacek PM, Cooper SM. Effects of low dose corticosteroids on the bone mineral density of patients with rheumatoid arthritis. J Rheumatol 1995;22(6):1055–9.

225. Bukhari MA, Wiles NJ, Lunt M, Harrison BJ, Scott DG, Symmons DP, et al. Influence of disease-modifying therapy on radiographic outcome in inflammatory polyarthritis at five years: results from a large observational inception study. Arthritis Rheum 2003;48(1):46–53.

226. Calguneri M, Pay S, Caliskaner Z, Apras S, Kiraz S, Ertenli I, et al. Combination therapy versus monotherapy for the treatment of patients with rheumatoid arthritis. Clinical and experimental rheumatology. 1999;17(6):699–704.

227. Campion GV, Lebsack ME, Lookabaugh J, Gordon G, Catalano M. Dose-range and dose-frequency study of recombinant human interleukin-1 receptor antagonist in patients with rheumatoid arthritis. The IL-1Ra Arthritis Study Group. Arthritis Rheum 1996;39(7):1092–101.

228. Cauza E, Spak M, Cauza K, Hanusch-Enserer U, Dunky A, Wagner E. Treatment of psoriatic arthritis and psoriasis vulgaris with the tumor necrosis factor inhibitor infliximab. Rheumatol Int 2002;22(6):227–32.

229. Ciconelli R, Ferraz M, Visioni R, Oliveira L, Atra E. A Randomized double-blind controlled trial of sulphasalazine combined with pulses of methylprednisolone or placebo in the treatment of rheumatoid arthritis. British Journal of Rheumatology. 1996;35(2):150–4.

230. Cohen G, Courvoisier N, Cohen JD, Zaltni S, Sany J, Combe B. The efficiency of switching from infliximab to etanercept and vice-versa in patients with rheumatoid arthritis. Clin Exp Rheumatol 2005;23(6):795–800.

231. Covelli M, Scioscia C, Iannone F, Lapadula G. Repeated infusions of low-dose infliximab plus methotrexate in psoriatic arthritis: immediate benefits are not maintained after discontinuation of infliximab. Clin Exp Rheumatol 2005;23(2):145–51.

232. Cuchacovich M, Ferreira L, Aliste M, Soto L, Cuenca J, Cruzat A, et al. Tumour necrosis factor-alpha (TNF-alpha) levels and influence of -308 TNF-alpha promoter polymorphism on the responsiveness to infliximab in patients with rheumatoid arthritis. Scand J Rheumatol 2004;33(4):228–32.

233. De Rycke L, Baeten D, Kruithof E, Van den Bosch F, Veys EM, De Keyser F. Infliximab, but not etanercept, induces IgM anti-double-stranded DNA autoantibodies as main antinuclear reactivity: biologic and clinical implications in autoimmune arthritis. Arthritis Rheum 2005;52(7):2192–201.

234. del Porto F, Aloe L, Lagana B, Triaca V, Nofroni I, D’Amelio R. Nerve growth factor and brain-derived neurotrophic factor levels in patients with rheumatoid arthritis treated with TNF-alpha blockers. Ann N Y Acad Sci 2006;1069:438–43.

235. den Broeder A, van de Putte L, Rau R, Schattenkirchner M, Van Riel P, Sander O, et al. A single dose, placebo controlled study of the fully human anti-tumor necrosis factor-alpha antibody adalimumab (D2E7) in patients with rheumatoid arthritis. J Rheumatol 2002;29(11):2288–98.

236. Dunne CA, Moran CJ, Thompson PW. The effect of regular intramuscular corticosteroid therapy on bone mineral density in rheumatoid patients. Scand J Rheumatol 1995;24(1):48–9.

237. Durez P, Nzeusseu Toukap A, Lauwerys BR, Manicourt DH, Verschueren P, Westhovens R, et al. A randomised comparative study of the short term clinical and biological effects of intravenous pulse methylprednisolone and infliximab in patients with active rheumatoid arthritis despite methotrexate treatment. Ann Rheum Dis 2004;63(9):1069–74.

238. Durez P, Van den Bosch F, Corluy L, Veys EM, De Clerck L, Peretz A, et al. A dose adjustment in patients with rheumatoid arthritis not optimally responding to a standard dose of infliximab of 3 mg/kg every 8 weeks can be effective: a Belgian prospective study. Rheumatology (Oxford) 2005;44(4):465–8.

239. Farahani P, Levine M, Gaebel K, Wang EC, Khalidi N. Community-based evaluation of etanercept in patients with rheumatoid arthritis. J Rheumatol 2006;33(4):665–70.

240. Felson DT, Anderson JJ, Meenan RF. The comparative efficacy and toxicity of second-line drugs in rheumatoid arthritis. Results of two metaanalyses. Arthritis Rheum 1990;33(10):1449–61.

241. Finckh A, Simard JF, Duryea J, Liang MH, Huang J, Daneel S, et al. The effectiveness of anti-tumor necrosis factor therapy in preventing progressive radiographic joint damage in rheumatoid arthritis: a population-based study. Arthritis Rheum 2006;54(1):54–9.

242. Fleischmann RM, Cohen SB, Moreland LW, Schiff M, Mease PJ, Smith DB, et al. Methotrexate dosage reduction in patients with rheumatoid arthritis beginning therapy with infliximab: the infliximab rheumatoid arthritis methotrexate tapering (iRAMT) trial. Curr Med Res Opin 2005;21(8):1181–90.

243. Fries JF, Williams CA, Morfeld D, Singh G, Sibley J. Reduction in long-term disability in patients with rheumatoid arthritis by disease-modifying antirheumatic drug-based treatment strategies. Arthritis Rheum 1996;39(4):616–22.

244. Furst D, Erikson N, Clute L, Koehnke R, Burmeister L, Kohler J. Adverse experience with methotrexate during 176 weeks of a longterm prospective trial in patients with rheumatoid arthritis. The Journal of Rheumatology. 1990;12:1628–35.

245. Genovese MC, Becker JC, Schiff M, Luggen M, Sherrer Y, Kremer J, et al. Abatacept for rheumatoid arthritis refractory to tumor necrosis factor alpha inhibition. N Engl J Med 2005;353(11):1114–23.

246. George D, Kadlubek P, Batra D, Goldberg G. Infliximab dose and charge escalation patterns in managed care. Manag Care Interface 2004;Suppl A:5–8.

247. Gibson JN, Poyser NL, Morrison WL, Scrimgeour CM, Rennie MJ. Muscle protein synthesis in patients with rheumatoid arthritis: effect of chronic corticosteroid therapy on prostaglandin F2 alpha availability. Eur J Clin Invest 1991;21(4):406–12.

248. Giles JT, Bartlett SJ, Gelber AC, Nanda S, Fontaine K, Ruffing V, et al. Tumor necrosis factor inhibitor therapy and risk of serious postoperative orthopedic infection in rheumatoid arthritis. Arthritis Rheum 2006;55(2):333–7.

249. Gran JT, Myklebust G. Toxicity of sulphasalazine in rheumatoid arthritis. Possible protective effect of rheumatoid factors and corticosteroids. Scand J Rheumatol 1993;22(5):229–32.

250. Grigor C, Capell H, Stirling A, McMahon AD, Lock P, Vallance R, et al. Effect of a treatment strategy of tight control for rheumatoid arthritis (the Ticora Study): a single-blind randomised controlled trial. Lancet. 2004;364(9430):263–9.

251. Haagsma C, van Riel P, van de Putte L. Combining sulphasalazine and methotrexate in rheumatoid arthritis: early clinical impressions. British Journal of Rheumatology. 1995;34(Suppl 2):104–8.

252. Haagsma CJ, van Riel PL, de Rooij DJ, Vree TB, Russel FJ, van’t Hof MA, et al. Combination of methotrexate and sulphasalazine vs methotrexate alone: a randomized open clinical trial in rheumatoid arthritis patients resistant to sulphasalazine therapy. British Journal of Rheumatology. 1994;33(11):1049–55.

253. Harrison MJ, Kim CA, Silverberg M, Paget SA. Does age bias the aggressive treatment of elderly patients with rheumatoid arthritis? J Rheumatol 2005;32(7):1243–8.

254. Heytman M, Ahern MJ, Smith MD, Roberts-Thomson PJ. The longterm effect of pulsed corticosteroids on the efficacy and toxicity of chrysotherapy in rheumatoid arthritis. J Rheumatol 1994;21(3):435–41.

255. Higashida J, Wun T, Schmidt S, Naguwa SM, Tuscano JM. Safety and efficacy of rituximab in patients with rheumatoid arthritis refractory to disease modifying antirheumatic drugs and anti-tumor necrosis factor-alpha treatment. J Rheumatol 2005;32(11):2109–15.

256. Hoekstra M, van Ede A, Haagsma C, van de Laar M, Huizinga T, Kruijsen M, et al. Factors associated with toxicity, final dose, and efficacy of methotrexate in patients with rheumatoid arthritis. Annals of the Rheumatic Diseases. 2003;62(5):423–6.

257. Hurlimann D, Forster A, Noll G, Enseleit F, Chenevard R, Distler O, et al. Anti-tumor necrosis factor-alpha treatment improves endothelial function in patients with rheumatoid arthritis. Circulation 2002;106(17):2184–7.

258. Islam M, Alam M, Haq S, Moyenuzzaman M, Patwary M, Rahman M. Efficacy of sulphasalazine plus methotrexate in rheumatoid arthritis. Bangladesh Medical Research Council Bulletin. 2000;26(1):1–7.

259. Kalden JR, Schattenkirchner M, Sorensen H, Emery P, Deighton C, Rozman B, et al. The efficacy and safety of leflunomide in patients with active rheumatoid arthritis: a five-year followup study. Arthritis and Rheumatism. 2003;48(6):1513–20.

260. Kalden JR, Scott DL, Smolen JS, Schattenkirchner M, Rozman B, Williams BD, et al. Improved functional ability in patients with rheumatoid arthritis - Longterm treatment with leflunomide versus sulfasalazine. Journal of Rheumatology 2001;28(9):1983–91.

261. Kalden Nemeth D, Grebmeier J, Antoni C, Manger B, Wolf F, Kalden J. Nmr Monitoring of rheumatoid arthritis patients receiving anti-TNF-Alpha monoclonal antibody therapy. Rheumatology International. 1997;16(6):249–55.

262. Keystone EC, Schiff MH, Kremer JM, Kafka S, Lovy M, DeVries T, et al. Once-weekly administration of 50 mg etanercept in patients with active rheumatoid arthritis: results of a multicenter, randomized, double-blind, placebo-controlled trial. Arthritis Rheum 2004;50(2):353–63.

263. Kiortsis DN, Mavridis AK, Vasakos S, Nikas SN, Drosos AA. Effects of infliximab treatment on lipoprotein profile in patients with rheumatoid arthritis and ankylosing spondylitis. J Rheumatol 2006;33(5):921–3.

264. Klareskog L, Gaubitz M, Rodriguez-Valverde V, Malaise M, Dougados M, Wajdula J. A long-term, open-label trial of the safety and efficacy of etanercept (ENBREL(R)) in patients with rheumatoid arthritis not treated with other DMARDs (3-year Interim Report). Ann Rheum Dis 2006.

265. Kremer J, Genovese M, Cannon GW, Caldwell J, Cush J, Furst DE, et al. Combination leflunomide and methotrexate (MTX) therapy for patients with active rheumatoid arthritis failing MTX monotherapy: open-label extension of a randomized, double-blind, placebo controlled trial. The Journal of Rheumatology. 2004;31(8):1521–31.

266. Kremer JM, Genant HK, Moreland LW, Russell AS, Emery P, Abud-Mendoza C, et al. Effects of abatacept in patients with methotrexate-resistant active rheumatoid arthritis: a randomized trial. Ann Intern Med 2006;144(12):865–76.

267. Kroesen S, Widmer AF, Tyndall A, Hasler P. Serious bacterial infections in patients with rheumatoid arthritis under anti-TNF-alpha therapy. Rheumatology (Oxford) 2003;42(5):617–21.

268. Lard LR, Boers M, Verhoeven A, Vos K, Visser H, Hazes JMW, et al. Early and Aggressive Treatment of Rheumatoid Arthritis Patients Affects the Association of Hla Class Ii Antigens With Progression of Joint Damage. Arthritis and rheumatism. 2002;46(4):899–905.

269. Lems WF, Jahangier ZN, Jacobs JW, Bijlsma JW. Vertebral fractures in patients with rheumatoid arthritis treated with corticosteroids. Clin Exp Rheumatol 1995;13(3):293–7.

270. Lequerre T, Vittecoq O, Klemmer N, Goeb V, Pouplin S, Menard JF, et al. Management of infusion reactions to infliximab in patients with rheumatoid arthritis or spondyloarthritis: experience from an immunotherapy unit of rheumatology. J Rheumatol 2006;33(7):1307–14.

271. Lindqvist E, Saxne T, Geborek P, Eberhardt K. Ten year outcome in a cohort of patients with early rheumatoid arthritis: health status, disease process, and damage. Ann Rheum Dis 2002;61(12):1055–9.

272. Mastroianni A, Minutilli E, Mussi A, Bordignon V, Trento E, D’Agosto G, et al. Cytokine profiles during infliximab monotherapy in psoriatic arthritis. Br J Dermatol 2005;153(3):531–6.

273. Montecucco C, Caporali R, Caprotti P, Caprotti M, Notario A. Sex hormones and bone metabolism in postmenopausal rheumatoid arthritis treated with two different glucocorticoids. J Rheumatol 1992;19(12):1895–900.

274. Moreland LW, Alten R, Van den Bosch F, Appelboom T, Leon M, Emery P, et al. Costimulatory blockade in patients with rheumatoid arthritis: a pilot, dose-finding, double-blind, placebo-controlled clinical trial evaluating CTLA-4Ig and LEA29Y eighty-five days after the first infusion. Arthritis Rheum 2002;46(6):1470–9.

275. Moreland LW, Cohen SB, Baumgartner SW, Tindall EA, Bulpitt K, Martin R, et al. Long-term safety and efficacy of etanercept in patients with rheumatoid arthritis. J Rheumatol 2001;28(6):1238–44.

276. Moreland LW, Genovese MC, Sato R, Singh A. Effect of etanercept on fatigue in patients with recent or established rheumatoid arthritis. Arthritis Rheum 2006;55(2):287–93.

277. Mroczkowski PJ, Weinblatt ME, Kremer JM. Methotrexate and leflunomide combination therapy for patients with active rheumatoid arthritis. Clin Exp Rheumatol 1999;17(6 Suppl 18):S66–8.

278. Pisitkun P, Pattarowas C, Siriwongpairat P, Totemchokchyakarn K, Nantiruj K, Janwityanujit S. Reappraisal of cervical spine subluxation in Thai patients with rheumatoid arthritis. Clin Rheumatol 2004;23(1):14–8.

279. Puolakka K, Kautiainen H, Mottonen T, Hannonen P, Korpela M, Hakala M, et al. Early suppression of disease activity is essential for maintenance of work capacity in patients with recent-onset rheumatoid arthritis: five-year experience from the FIN-RACo Trial. Arthritis and Rheumatism. 2005;52(1):36–41.

280. Rau R, Simianer S, van Riel PL, van de Putte LB, Kruger K, Schattenkirchner M, et al. Rapid alleviation of signs and symptoms of rheumatoid arthritis with intravenous or subcutaneous administration of adalimumab in combination with methotrexate. Scand J Rheumatol 2004;33(3):145–53.

281. Reece RJ, Kraan MC, Radjenovic A, Veale DJ, O’Connor PJ, Ridgway JP, et al. Comparative assessment of leflunomide and methotrexate for the treatment of rheumatoid arthritis, by dynamic enhanced magnetic resonance imaging. Arthritis and Rheumatism. 2002;46(2):366–72.

282. Salvarani C, Cantini F, Olivieri I, Macchioni P, Padula A, Niccoli L, et al. Efficacy of infliximab in resistant psoriatic arthritis. Arthritis Rheum 2003;49(4):541–5.

283. Schnabel A, Herlyn K, Burchardi C, Reinhold Keller E, Gross WL. Long-term tolerability of methotrexate at doses exceeding 15 mg per week in rheumatoid arthritis. Rheumatology International. 1996;15(5):195–200.

284. Schnabel A, Reinhold Keller E, Willmann V, Gross W. Tolerability of methotrexate starting with 15 or 25 mg/week for rheumatoid arthritis. Rheumatology International. 1994;14(1):33–8.

285. Shergy WJ, Isern RA, Cooley DA, Harshbarger JL, Huffstutter JE, Hughes GM, et al. Open label study to assess infliximab safety and timing of onset of clinical benefit among patients with rheumatoid arthritis. J Rheumatol 2002;29(4):667–77.

286. Sinigaglia L, Nervetti A, Mela Q, Bianchi G, Del Puente A, Di Munno O, et al. A multicenter cross sectional study on bone mineral density in rheumatoid arthritis. Italian Study Group on Bone Mass in Rheumatoid Arthritis. J Rheumatol 2000;27(11):2582–9.

287. St Clair EW, Wagner CL, Fasanmade AA, Wang B, Schaible T, Kavanaugh A, et al. The relationship of serum infliximab concentrations to clinical improvement in rheumatoid arthritis: results from attract, a multicenter, randomized, double-blind, placebo-controlled trial. Arthritis and Rheumatism. 2002;46(6):1451–9.

288. Stern R, Wolfe F. Infliximab dose and clinical status: results of 2 studies in 1642 patients with rheumatoid arthritis. J Rheumatol 2004;31(8):1538–45.

289. Taylor P, Steuer A, Gruber J, McClinton C, Cosgrove D, Blomley M, et al. Ultrasonographic and radiographic results from a two-year controlled trial of immediate or one-year-delayed addition of infliximab to ongoing methotrexate therapy in patients with erosive early rheumatoid arthritis. Arthritis and Rheumatism 2006;54(1):47–53.

290. Torrance GW, Tugwell P, Amorosi S, Chartash E, Sengupta N. Improvement in health utility among patients with rheumatoid arthritis treated with adalimumab (a human anti-TNF monoclonal antibody) plus methotrexate. Rheumatology (Oxford) 2004;43(6):712–8.

291. van der Veen MJ, Bijlsma JW. The effect of methylprednisolone pulse therapy on methotrexate treatment of rheumatoid arthritis. Clin Rheumatol 1993;12(4):500–5.

292. van Vollenhoven RF, Ernestam S, Harju A, Bratt J, Klareskog L. Etanercept versus etanercept plus methotrexate: a registry-based study suggesting that the combination is clinically more efficacious. Arthritis Res Ther 2003;5(6):R347–51.

293. Verstappen S, Jacobs J, Bijlsma JW. The Utrecht experience with different treatment strategies in early rheumatoid arthritis. Clinical and Experimental Rheumatology. 2003;21(5 Suppl 31):S165–8.

294. Vlak T, Eldar R. Disability in rheumatoid arthritis after monotherapy with DMARDs. International Journal Rehabilitation Research 2003;26(3):207–12.

295. Weinblatt ME, Kremer JM, Coblyn JS, Maier AL, Helfgott SM, Morrell M, et al. Pharmacokinetics, safety, and efficacy of combination treatment with methotrexate and leflunomide in patients with active rheumatoid arthritis. Arthritis Rheum 1999;42(7):1322–8.

296. Weinblatt ME, Weissman BN, Holdsworth DE, Fraser PA, Maier AL, Falchuk KR, et al. Long-term prospective study of methotrexate in the treatment of rheumatoid arthritis. 84-Month Update. Arthritis and Rheumatism. 1992;35(2):129–37.

297. Weisman MH, Moreland LW, Furst DE, Weinblatt ME, Keystone EC, Paulus HE, et al. Efficacy, pharmacokinetic, and safety assessment of adalimumab, a fully human anti-tumor necrosis factor-alpha monoclonal antibody, in adults with rheumatoid arthritis receiving concomitant methotrexate: a pilot study. Clin Ther 2003;25(6):1700–21.

298. Westhovens R, Cole JC, Li T, Martin M, Maclean R, Lin P, et al. Improved health-related quality of life for rheumatoid arthritis patients treated with abatacept who have inadequate response to anti-TNF therapy in a double-blind, placebo-controlled, multicentre randomized clinical trial. Rheumatology (Oxford) 2006;45(10):1238–46.

299. Westhovens R, Houssiau F, Joly J, Everitt DE, Zhu Y, Sisco D, et al. A phase I study assessing the safety, clinical response, and pharmacokinetics of an experimental infliximab formulation for subcutaneous or intramuscular administration in patients with rheumatoid arthritis. J Rheumatol 2006;33(5):847–53.

300. Yazici Y, Erkan D, Kulman I, Belostocki K, Harrison MJ. Decreased flares of rheumatoid arthritis during the first year of etanercept treatment: further evidence of clinical effectiveness in the “real world”. Ann Rheum Dis 2002;61(7):638–40.

301. Yelin E, Trupin L, Katz P, Lubeck D, Rush S, Wanke L. Association between etanercept use and employment outcomes among patients with rheumatoid arthritis. Arthritis Rheum 2003;48(11):3046–54.

302. Yun JE, Lee SW, Kim TH, Jun JB, Jung S, Bae SC, et al. The incidence and clinical characteristics of Mycobacterium tuberculosis infection among systemic lupus erythematosus and rheumatoid arthritis patients in Korea. Clin Exp Rheumatol 2002;20(2):127–32.