# Appendix B Search Strings

#2 | Search (“Arthritis, Psoriatic”[MeSH] OR “Arthritis, Rheumatoid”[MeSH]) | 82356
#3 | Search (“Arthritis, Psoriatic”[MeSH] OR “Arthritis, Rheumatoid”[MeSH]) Limits: All Adult: 19+ years, English, Publication Date from 1990, Humans | 16462
#5 | Search “Adrenal Cortex Hormones”[MeSH] OR corticosteroid* | 190820
#6 | Search #3 AND #5 | 686
#7 | Search #3 AND #5 Limits: Editorial, Letter, Practice Guideline | 18
#8 | Search #6 NOT #7 | 668
#18 | Search “Methotrexate”[MeSH] OR “leflunomide”[Substance Name] OR “Sulfasalazine”[MeSH] OR “Hydroxychloroquine”[MeSH] | 28712
#28 | Search “TNFR-Fc fusion protein”[Substance Name] OR etanercept OR “infliximab”[Substance Name] OR “adalimumab”[Substance Name] OR “cytotoxic T lymphocyte-associated antigen 4-immunoglobulin”[Substance Name] OR abatacept OR remicade OR enbrel OR humira OR “rituximab”[Substance Name] OR “interleukin 1 receptor antagonist protein”[Substance Name] OR anakinra | 8701
#29 | Search #3 AND #18 | 1365
#30 | Search #3 AND #28 | 777
#31 | Search #3 AND #18 Limits: Editorial, Letter, Practice Guideline | 237
#32 | Search #29 NOT #31 | 1128
#33 | Search #3 AND #28 Limits: Editorial, Letter, Practice Guideline | 178
#34 | Search #30 NOT #33 | 599
#35 | Search #8 OR #30 OR #34 | 1405

2 were discarded as clearly out of scope, so PUBMED = 1403

Cochrane Reviews = 84 = 24 New, unduplicated

EMBASE =1808 = 469 New, unduplicated

Unduplicated = 1986