# Appendix A Peer Reviewers and Acknowledgments

This study was supported by Contract 290-02-0016 from the Agency for Healthcare Research and Quality (AHRQ), Task No. 7. We acknowledge the continuing support of Beth Collins Sharp, Ph.D., R.N., Director of the AHRQ Evidence-Based Practice Center (EPC) Program, and Carmen Kelly, Pharm.D., R.Ph., L.T. U.S. Public Health Service, the AHRQ Task Order Officer for this project. We extend our appreciation to our peer reviewers: Joel Kremer, M.D., Director of Research at the Center for Rheumatology in Albany, New York; Barbara T. Blumenauer, M.D., a Rheumatologist in British Columbia; Larry Moreland, M.D., of the Spain Rehabilitation Center at the University of Alabama; and Arthur Kavanaugh, M.D., Professor Medicine at the Center for Innovative Therapy at the University of California San Diego. All provided thoughtful advice on the draft report. The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at RTI International and the University of North Carolina (UNC). We would particularly acknowledge Timothy Carey, M.D., M.P.H., for insightful comments on the first draft and helpful suggestions throughout the project; Lynn Whitener, Dr.P.H., M.S.L.S., our EPC Librarian; and UNC supporting staff Stacey Williams. We also express our gratitude to RTI staff Tammeka Swinson, Research Analyst, and Jennifer Drolet, M.A., editor.