# Results

## Introduction

This chapter is organized as follows. First, we discuss general results of the literature searches and characteristics of included studies. Second, we present the available evidence by Key Question (KQ). Within each KQ we present evidence on the efficacy or risk of harms first, followed by the comparative effectiveness and risk of harms, as well as grades of the strength of evidence (SOE). Within each section on efficacy, comparative effectiveness, or absolute or comparative risk of harms, we discuss evidence on psychological interventions first, followed by studies on pharmacological interventions, and lastly by studies on emerging interventions. In addition, according to the specifications from the Agency for Healthcare Research and Quality (AHRQ) for a comparative effectiveness review (CER), within each KQ section we present key points and detailed synthesis. Table 6 lists the main questions that we address in this chapter.

Table 6 Key Questions about interventions to prevent PTSD in adults after exposure to psychological trauma

Key Questions
KQ 1: What are the efficacy and comparative effectiveness of early interventions to prevent PTSD?
KQ 2: What is the impact of timing, intensity, or dosage of intervention on effectiveness and harms?
KQ 3: What are the efficacy, comparative effectiveness, and harms in subpopulations and different traumatic exposures?
KQ 4: What are the absolute and comparative risk of harms from early interventions to prevent PTSD?

PTSD = posttraumatic stress disorder

We focus on randomized controlled trials (RCTs) and prospective observational studies for all questions; for KQ 4 on harms, we also include retrospective observational studies. Evidence tables for all included studies, by KQ, are presented in Appendix E.

Reasons for exclusion were based on eligibility criteria or methodological assessments. We rated 37 studies that otherwise met eligibility criteria as having high risk of bias (Appendix F). The main reasons for rating RCTs as high risk of bias were poor randomization, high loss to followup, and lack of ITT analysis. We briefly discuss high-risk-of-bias studies in the report only if no studies of better methodological quality were available.

Studies reviewed for this report employed a notable array of diagnostic scales, some of which assess posttraumatic stress disorder (PTSD) and others that assess other outcomes of interest, such as health-related quality of life. Commonly used measures include the:

- BDI: Beck Depression Inventory;
- CAPS, CAPS-2: Clinician Administered PTSD Scales;
- HADS: Hospital Anxiety and Depression Rating Scale;
- IES, IES-R: Impact of Event Scale;
- PCL: Posttraumatic Stress Disorder Checklist;
- PDS: Posttraumatic Stress Diagnostic Scale; and
- SF-36: Medical Outcomes Study Health Survey–Short Form 36.

## Results of Literature Searches

We identified 2,563 citations from searches, reviews of reference lists, and grey literature. Figure 2 documents the disposition of the 267 articles retrieved for full-text review for this report. Overall, we included 56 full-text articles (based on 55 studies) but only used 19 articles (based on 55 studies) but only used 19 articles (based on 19 studies) in our main analyses, selected 106 articles for background, and excluded 211 full-text articles for various reasons. In general, the number of articles exceeds the number of studies because results of some studies were published in multiple articles. Articles excluded during full-text review are listed in Appendix D with reasons for their exclusion.

Figure 2 Disposition of articles

CINAHL = Cumulative Index to Nursing and Allied Health Literature; EMBASE = Excerpta Medica Database; IPA = International Pharmaceutical Abstracts; PICOTS = patient populations, interventions, comparators, outcomes, timing, and settings; PILOTS = Published International Literature on Traumatic Stress; PRISMA = Preferred Reporting Items for Systematic Review and Meta-analyses

Figure 2 is titled “Disposition of articles.” The figure is a flow chart that summarizes the search and selection of articles: there were 2468 citations identified by searching MEDLINE®, IPA, CINAHL®, PsycINFO®, EMBASE®, the Cochrane Library, PILOTS, and Web of Science. In addition, 95 references were identified by hand searches and by searching grey literature. After removal of duplicate citations, titles and abstracts of 2563 references were screened for potential inclusion. Of these, 267 were deemed appropriate for full-text review to determine eligibility. After full-text review, 211 were excluded: 17 for ineligible type of publication; 31 for ineligible study design; 163 failed to meet at least one PICOTS element; and 37 were deemed as having a high risk of bias. Fifteen articles representing 19 studies are included in this report’s qualitative synthesis and 4 of these studies, including one high risk of bias study, are included in quantitative analyses.

## Description of Included Studies

We included 19 articles reporting on 19 studies of low or medium risk of bias in our main analyses: of the included studies, all were RCTs (Figure 2). Nine RCTs used head-to-head comparisons of early interventions; the other 10 compared active interventions with inactive comparison conditions. Evidence tables of studies with low or medium risk of bias are presented in Appendix E. In addition, we rated 37 studies that met eligibility criteria as high risk of bias (Appendix F). Table 7 presents a summary of the study designs, prevention type (i.e., universal or targeted), study comparisons, results, and methodological shortcomings of the 37 studies we rated as high risk of bias. For most interventions we had stronger, more reliable evidence to answer a particular question. When we found no evidence rated as low or medium risk of bias, we present information from high-risk-of-bias studies. When RCTs were rated as high risk of bias because of inadequate randomization, we viewed them as non-randomized studies and critically appraised them accordingly. In all cases, however, they were ultimately rated as high risk of bias non-randomized studies because they did not adequately control for differences in baseline characteristics.

Table 7 Summary of studies rated high risk of bias

Author, Year, Study Design, Prevention Type | Population, Trauma Type | Comparison | Summary of Results | Reason for Rating of High Risk of Bias
Acierno et al., 2004^83^ RCT Universal | Civilians Crimes | CBT-based video intervention plus standard services vs. standard services only | Neither incidence of PTSD nor PTSD symptom severity differed between the groups. | - No baseline PTSD ratings; - High overall attrition (29%); - “Completers analysis” only
Adler et al., 2009^27^ RCT Universal | U.S. Army service members Combat | Stress management vs. Battlemind debriefing vs. small Battlemind training vs. large Battlemind training | PTSD symptom severity was lower in the three Battlemind groups than in the stress management group. | - Study staff masked at followup but not baseline; - High overall attrition (>50%); - ITT not sufficient to account for risk of bias due to attrition
Adler et al., 2008^84^ RCT Universal | U.S. Army service members Combat | CISD vs. stress management vs. survey only | PTSD symptom severity did not differ between any of the groups. | - Randomization method not described, so impossible to determine how it affects risk of bias; - High overall attrition (71%); - Statistical approach to control for effect of attrition not sufficient to account for risk of bias due to attrition; - No allocation concealment
Eid et al., 2001^85^ Prospective cohort study Universal | First responders Fatal traffic accident | Debriefing plus stress management vs. debriefing | Combined intervention was associated with a lower frequency of posttraumatic stress symptoms. | - Cohort study with a small sample size; - No reported adjustment for confounders; - Further risk of bias assessment impossible due to inadequate reporting of methods
Brom et al., 1993^86^ RCT Universal | Civilians MVA | SC vs. monitoring only | PTSD symptom severity did not differ between the counseling and monitoring only groups. | - Randomization process not described, so impossible to determine how it affects risk of bias; - Unclear how attrition handled; - Statistically significant group differences at baseline; - Unclear if outcome assessors masked
Bryant et al., 1999^87^ RCT Targeted | Civilians with ASD MVA or nonsexual assault | PE plus anxiety management vs. PE alone vs. SC | The combined intervention and PE alone were both associated with lower PTSD incidence and less PTSD symptom severity than SC. No differences in PTSD outcomes occurred between PE alone and PE plus anxiety management. | - High overall attrition (23%); - “Completers analysis” only
Bryant et al., 2003^88^ RCT Targeted | Civilians with ASD MVA or nonsexual assault | CBT vs. SC | The CBT group had lower incidence of PTSD rates and less PTSD symptom severity than the SC group. | - High overall attrition (49%) from end of parent studies (see Bryant et al., 1998 and Bryant et al., 1999)87,89
Bryant et al., 2006^90^ RCT Targeted | Civilians with ASD MVA or nonsexual assault | CBT+Hypnosis vs. CBT alone vs. SC | Both the combined intervention and CBT alone were associated with lower incidence of PTSD and less PTSD symptom severity at 3-year followup than in the SC group. | - High overall attrition (39%) from end of parent study (see Bryant et al., 2005)91
Bugg et al., 2009^92^ Targeted | Civilians with ASD symptoms Physical injury or accident | Structured writing intervention vs. information-only control | Incidence of PTSD did not differ between groups. | - High overall attrition (51% including postrandomization exclusions); - Relatively large proportion not completing all three intervention sessions (31%); - Substantial differences between groups by sex
Carlier et al., 1998^93^ Retrospective cohort study Universal | First responders (police officers) Fatal civilian plane crash | CISD vs. no CISD | Findings were mixed: incidence of PTSD did not differ between groups, while the no CISD group exhibited greater PTSD symptom severity. | - Risk of recall bias because no data available until 8 months after trauma; - High risk of selection bias and confounding from subjects’ self-selection to treatment groups
Crespo et al., 2010^94^ RCT Targeted | Civilian women with PTSD symptoms but not full PTSD diagnosis Intimate partner violence | CBT with exposure techniques vs. CBT with communication skills training instead | CBT with exposure techniques was generally associated with lower PTSD symptom severity than CBT with communication skills training. However, the communication skills group had fewer re-experiencing symptoms at posttreatment than the exposure group. | - Randomization process at high risk for bias; - High overall attrition (32%); - Statistically significant baseline differences in education level, depression symptom levels, and reason for seeking treatment (Exposure group’s presenting reason more often violence than communication skills group)
Deahl et al., 2000^95^ RCT Universal | British UN peacekeepers Combat in Yugoslavia | Preoperational and postoperational psychological debriefing vs. Preoperational debriefing only | Neither incidence of PTSD or PTSD symptom severity differed between groups. | - Not true randomization; - High overall attrition (48%); - Baseline data collected from only 64% of the whole sample before intervention; - Unclear whether study used the same truly random samples for the postbaseline outcomes as at baseline; - Data not available for all participants at all times but no reasons for missing data given
Foa et al., 1995^96^ Prospective cohort study Targeted | Civilian women meeting PTSD symptom criteria only Sexual or nonsexual assault | Brief CBT vs. assessment-only control | The CBT group experienced a smaller incidence of PTSD and less PTSD symptom severity than the assessment only group at posttreatment, but not at later followup. | - Nonrandomized study with small sample size (N=20); - Attrition data NR; - High risk of selection bias and confounding; - Participants matched on some variables but not all; - Timing of outcomes differed by group
Foa et al., 2006^97^ RCT Targeted | Civilian women meeting PTSD symptom criteria only Sexual or nonsexual assault | Brief CBT vs. SC vs. assessment-only control | CBT was associated with less PTSD symptom severity at posttreatment than SC, but not the assessment-only group. At later followup, all groups had similar incidence of PTSD and PTSD symptom severity. | - High overall (27%) and differential attrition (SC vs. assessment-only: 16%); - ITT not sufficient to account for risk of bias due to attrition
Frappell-Cooke et al., 2010^98^ Prospective cohort study Universal | UK Royal Marines and Army returning from Afghanistan Combat | Units with experience using trauma risk management debriefing vs. Units using trauma risk management for first time | Neither incidence of PTSD nor PTSD symptom severity differed between groups. | - Nonrandomized study with high overall (24%) and differential (43%) attrition; - “Completers analysis” only
Freyth et al., 2010^99^ RCT Targeted | Civilians with ASD Sexual or nonsexual assault, accidents, other (unspecified) | PE vs. SC (both groups receiving psychoeducation and progressive relaxation) | PTSD symptom severity did not differ between groups. | - Inadequate randomization; - Attrition reported only for 4-year followup time point; - Attrition unclear at 3-month followup time point (last data collection point for all main outcomes); - Unclear if all participants retained at posttreatment
Gelpin et al., 1996^100^ Prospective cohort study Universal | Civilians admitted to the emergency room Trauma exposure NR | Benzodiazepines vs. no benzodiazepines | PTSD symptom severity did not differ between groups. | - Unclear if only “completers analysis” used; - High risk of selection bias because administration of benzodiazepines based on clinician’s evaluation of efficacy, side effects, distress level, and other characteristics like severity of trauma; - Specific drug of choice (either alprazolam or clonazepam) administered in nonsystematic way
Gidron et al., 2001^101^ RCT Targeted | MVA survivors with minimum heart rate of 95 BPM at emergency room admission (PTSD predictor) MVA | Memory Structuring Intervention (MSI) vs. supportive listening | MSI was associated with less PTSD symptom severity. | - Method of randomization unclear; - Unclear attrition; - Inadequate statistical analysis
Grainger et al., 1997^102^ Prospective cohort study Universal | U.S. survivors of Hurricane Andrew Natural disaster | EMDR vs. waitlist | EMDR was associated with less PTSD symptom severity. | - Only 29% of participants receiving at least 1 session of EMDR included in analysis; ○ Only participants completing both baseline and posttreatment assessments analyzed; - Inclusion criteria unclear (other than surviving Hurricane Andrew); ○ May have been established after treatment given to survivors; - Unclear if only “completers analysis” used; ○ Only waitlist group completers reported; - Unclear how late some participants might have first received treatment
Hobbs et al., 1996^103^ RCT Targeted | Civilians with posttraumatic symptoms MVA | Psychological debriefing vs. control | Neither incidence of PTSD nor PTSD symptom severity differed between groups. | - High differential attrition (16%); - Completers analysis only
Holmes et al., 2007^104^ RCT Universal | Civilians Major physical trauma | Interpersonal counseling vs. treatment as usual | Neither incidence of PTSD nor PTSD symptom severity differed between groups. | - High overall (36%) and differential attrition (25%); - No ITT reported
Jotzo et al., 2005^105^ Prospective cohort study Universal | Civilian mothers Premature birth of child | Structured single-session crisis intervention combined with additional psychological aid vs. standard care | The crisis intervention was associated with lower PTSD symptom severity. | - No baseline PTSD data collected; - Information about attrition, ITT, blinding, or confounding largely unavailable
Kenardy et al., 2008^106^ RCT Universal | Civilian parents of injured children Pediatric accidental traumatic injury | Psychoeducational information booklet vs. no intervention | Psychoeducation was associated with less PTSD symptom severity in a “completers analysis,” but ITT results found no difference between groups. | - Inadequate randomization; - High overall attrition (36%)
Krauseneck et al., 2010^107^ Prospective cohort study Universal | Civilian medical patients Cardiac surgery (i.e., coronary artery bypass grafting [CABG] or cardiac valve replacement) | Beta-blocker (metoprolol) vs. placebo | Women in the metoprolol group had fewer traumatic memories and less PTSD symptom severity than women in the placebo group but these outcomes did not differ among men. | - High risk of confounding due to lack of measurement or adjustment for the following potential confounders:; ○ Beta-blockers administered postoperatively in Germany “according to a standard protocol”, which is not described; ○ Potentially important clinical reasons for not giving beta-blockers to some patients, such as preoperative characteristics or postoperative course, that could indicate illness severity after surgery; ○ Unclear how potential confounders related to risk of PTSD symptoms
Peres et al., 2011^108^ Prospective cohort study Targeted | Police officers with partial/sub-threshold PTSD Combat (gunfire attack), witnessing fellow officers dying | Exposure-based therapy and cognitive restructuring vs. waitlist | The intervention was associated with less PTSD symptom severity, but it was not reported whether between-group outcomes were statistically different. | - Not randomized; - Attrition and number of subjects included in analysis NR; - Impossible to determine similarity of original groups; - Unclear how statistical analyses conducted
Peris et al., 2011^109^ Retrospective cohort study Universal | Civilian medical patients Severe and/or critical injuries | ICU-based psychological interventions (i.e., educational, counseling, stress management, psychological support and coping strategies) vs. standard care | The intervention was associated with lower incidence of PTSD and less PTSD symptom severity. | - No randomization; - High overall (44%) and differential (16%) attrition; - Study groups evaluated at two different time periods; - Outcome assessment not blinded
Pitman et al., 2002^51^ RCT Universal | Civilians presenting to the emergency department Traumatic events (unspecified) | Propranolol vs. placebo | Neither PTSD symptom severity nor incidence of PTSD differed between groups, although fewer patients in the propranolol group experienced physiologic responses following imagery of the traumatic event. | - High overall (41%) and differential (15%) atttrion in small sample; - “Completers analysis” only
Resnick et al., 1999^110^ RCT Universal | Civilian women Sexual assault | Psychoeducational video plus usual care vs. usual care alone | Differences in PTSD symptom severity between groups were not reported, and whether PTSD outcomes were compared is not clear. | - Inadequate randomization; - Outcome assessment not blinded; - Difficult to assess differential attrition because the number of participants in each arm completing assesments varied by assessment and time point; - Noncomparability of assessment schedules for one of the conditions
Richards, 2001^111^ NRCT Universal | Civilians working in a major UK financial services company Armed robberies | CISD integrated within CISM vs. CISD alone | CISD integrated within CISM was associated with lower PTSD symptom severity. | - High overall attrition (50%); - Unclear whether control group was concurrent
Rothbaum et al., 2008^112^ Prospective cohort study Universal | Civilians presenting to the emergency department Mixed (MVA, physical assault, interpersonal violence, pedestrian accident, other accident, or other unspecified trauma) | Imaginal exposure therapy vs. assessment only | PTSD symptom severity did not differ between groups. | - Nonrandomized study with small sample size (n=10); ○ Possible statistically significant between-group differences at baseline (e.g., age, sex); - High overall attrition (20%); - “Completers analysis” only; - No attempts to adjust for potential confounding from participants’ trauma histories and whether previous traumas from adulthood or childhood; - Participants not screened for ASD or PTSD at baseline when eligibility assessed
Schelling et al., 2004^113^ RCT Universal | Civilian medical patients with high risk for pronounced inflammatory reactions after surgery Cardiac surgery | Stress doses of hydrocortisone vs. standard postoperative care | Hydrocortisone was associated with less PTSD symptom severity, but the frequency of traumatic memories did not differ between groups. | - High overall attrition (47%); - “Completers analysis” only
Schelling et al., 2001^114^ RCT Universal | Civilian medical patients Septic shock | Stress doses of hydrocortisone vs. standard postoperative care | Incidence of PTSD was lower in the hydrocortisone group, but frequency of traumatic memories did not differ between groups. | - High overall attrition (50%); - Unclear if participants blinded in intital study
Stein et al., 2007^47^ RCT Universal | Civilian medical patients Severe physical injuries requiring specialized emergency care | Propranolol (beta-blocker) vs. gabapentin (anticonvulsant) vs. placebo | Neither PTSD symptom severity nor incidence of PTSD differed between groups. | - ITT likely not conducted; - No reporting of important baseline characteristics by treatment group or between-group comparisons; PCL-C outcomes not reported except in line graph
Tecic et al., 2011^115^ RCT Universal | Civilian medical patients Mixed (MVA, bicycle accident, pedestrian accident, collapse, assault, other trauma) | Short-term inpatient psychotherapy (using cognitive, exposure-based, SC, and relaxation elements) vs. long-term inpatient and outpatient psychotherapy (same as short-term plus outpatient therapy focused on coping with daily life after discharge) | PTSD symptom severity did not differ between groups. | - High overall (44%) and differential (22%) attrition; - Unclear whether ITT used
Vaiva et al., 2003^116^ Prospective cohort study Targeted | Civilian emergency department patients presenting with tachycardia MVA or physical assault | Propranolol (beta-blocker) plus standard treatment vs. standard treatment alone | The propranolol group had lower PTSD symptom severity and incidence of PTSD. | - Attrition data NR and unclear how attrition handled in the analysis; - No baseline data collected about PTSD symptoms; - Risk of selection bias due to participant self-selection into treatment groups, which is not addressed in analysis
Vijayakumar and Kumar, 2008^117^ Prospective cohort study Universal | Civilians Natural disaster (tsunami) | Mental health support vs. no intervention | Mental health support was associated with lower PTSD symptom severity. | - Attrition rates and method of handling dropouts NR; - PTSD measure piloted for this study, but no validity data provided; - Only one statistically significant baseline difference (illiteracy) taken into account in statistical analysis; Outcome assessors not blinded
Zohar et al., 2011^118^ RCT Targeted | Patients with threshold or subthreshold ASD symptoms Work accident, MVA, or snake bite | Hydrocortisone vs. placebo | The hydrocortisone group was less likely to develop PTSD than patients receiving placebo. | - High overall (32%) and differential (20%) attrition; - Only p values for between-group CAPS score differences reported; Outcomes displayed in bar graphs, but mean scores and measures of variance not reported

ASD = acute stress disorder; BPM = beats per minute; CABG = coronary artery bypass grafting; CAPS = Clinician Administered PTSD Scale; CBT = cognitive behavioral therapy; CISD = critical incident stress debriefing; CISM = critical incident stress management; COPD = chronic obstructive pulmonary disease; DSM = Diagnostic and Statistical Manual of Mental Disorders; EMDR = eye movement desensitization and reprocessing therapy; ICU = intensive care unit; ITT = intent-to-treat analysis; MSI = Memory Structuring Intervention; MVA = motor vehicle accident(s); NR = not reported; PCL-C = Posttraumatic Stress Disorder Checklist-Civilian Version; PE = prolonged exposure therapy; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial; SC = supportive counseling; UK = United Kingdom; UN = United Nations; U.S. = United States

If not stated otherwise, trials described in the results chapter are of medium risk of bias.

The majority of included studies focused on psychological and pharmacological interventions. Only one study evaluated an emerging intervention.119 For most pharmacological and emerging interventions reliable evidence was lacking. Table 8 presents the number of studies for each included intervention.

Table 8 Number of low and medium risk-of-bias studies for each eligible intervention

Intervention Type | Intervention | Studies on Efficacy | Studies on Comparative Effectiveness | Studies on Impact of Timing, Intensity, and Dosing | Studies on Risk of Harms
Psychological Interventions | Cognitive behavioral therapy | 1 | 3 | 0 | 0
Psychological Interventions | Cognitive processing therapy | 0 | 0 | 0 | 0
Psychological Interventions | Coping skills therapy (including stress inoculation therapy) | 0 | 0 | 0 | 0
Psychological Interventions | Cognitive therapy (including cognitive restructuring therapy) | 2 | 2 | 0 | 0
Psychological Interventions | Debriefing interventions (including critical incident stress debriefing and critical incident stress management) | 2 | 2 | 1 | 1
Psychological Interventions | Exposure-based therapies (including imaginal and in vivo exposure, as well as prolonged exposure) | 3 | 2 | 0 | 0
Psychological Interventions | Eye movement desensitization and reprocessing | 0 | 0 | 0 | 0
Psychological Interventions | Interpersonal therapy | 0 | 0 | 0 | 0
Psychological Interventions | Psychoeducation | 2 | 1 | 0 | 0
Psychological Interventions | Psychological first aid | 0 | 0 | 0 | 0
Psychological Interventions | Other clearly defined psychological interventions (self-help materials)^a^ | 1 | 0 | 0 | 0
Psychological Interventions | Other clearly defined psychological interventions (supportive counseling)^b^ | 3 | 3 | 0 | 0
Psychological Interventions | Other clearly defined psychological interventions (Battlemind training)^c^ | 0 | 1 | 0 | 0
Pharmacological Interventions | Alpha blockers | 0 | 0 | 0 | 0
Pharmacological Interventions | Anticonvulsants | 0 | 0 | 0 | 0
Pharmacological Interventions | Benzodiazepines^d^ | 0 | 0 | 1 | 1
Pharmacological Interventions | Beta blockers | 0 | 0 | 0 | 0
Pharmacological Interventions | Monoamine oxidase inhibitors | 0 | 0 | 0 | 0
Pharmacological Interventions | Narcotics | 0 | 0 | 1 | 1
Pharmacological Interventions | Nonbenzodiazepine sedatives/hypnotics | 0 | 0 | 0 | 0
Pharmacological Interventions | Opioid antagonists | 0 | 0 | 0 | 0
Pharmacological Interventions | Other second-generation antidepressants | 0 | 0 | 0 | 0
Pharmacological Interventions | Second-generation (atypical) antipsychotics | 0 | 0 | 0 | 0
Pharmacological Interventions | Selective serotonin reuptake inhibitors | 1 | 1 | 0 | 0
Pharmacological Interventions | Serotonin and norepinephrine reuptake inhibitors | 0 | 0 | 0 | 0
Pharmacological Interventions | Steroids | 1 | 0 | 0 | 0
Pharmacological Interventions | Tricyclic antidepressants | 0 | 0 | 0 | 0
Emerging Interventions | Complementary and alternative medicine approaches | 0 | 0 | 0 | 0
Emerging Interventions | New models of health care delivery (collaborative care) | 1 | 0 | 0 | 0

a One study evaluated the efficacy of a self-help booklet on PTSD outcomes following a new breast cancer diagnosis. Although self-help materials are not listed in Table 3, this intervention is being included as an eligible psychological intervention.

b Three studies evaluated the efficacy, and another three evaluated the comparative effectiveness of supportive counseling interventions on PTSD outcomes following birth-related trauma or mixed trauma, respectively. Although supportive counseling is not listed in Table 3, it is being included as an eligible psychological intervention.

c One study evaluated the comparative effectiveness of Battlemind training on PTSD outcomes following military deployment. Although Battlemind training is not listed in Table 3, it is being included as an eligible psychological intervention.

d One study evaluated the impact of sedation depth achieved by midazolam plus morphine infusion on PTSD outcomes following critical illness. Although midazolam is not listed in Table 3, it is being included as an eligible benzodiazepine.

Populations enrolled in the available studies were exposed to primarily “civilian” types of trauma (e.g., domestic violence or abuse, accidents, natural events) and only secondarily “military” trauma. The majority of studies were funded by government agencies in the United States and other countries, including Australia, Israel, Switzerland, and the United Kingdom, followed by private-sector sponsors such as foundations. Only two studies were supported by academic funding120,121 and only one by funding from a pharmaceutical company.122

## KQ 1 Efficacy and Comparative Effectiveness of Interventions To Prevent PTSD

### Description of Included Studies

Overall, 52 studies met eligibility criteria for KQ 1.^27,47,51,83–97,99–114,116–133^ Of these, 35 were rated as high risk of bias,27,47,51,83–88,90,92–97,99–114,116–118,122 and we did not include them in the main analyses reported below. Of 13 studies that identified one or more funding sources, 10 had government funding,89,91,119,122,123,125,127–129,131 5 had support from a private foundation or grant,120–122,127,130 and 1 had pharmaceutical industry funding.122 Four trials did not specify a funding source.124,126,132,133

### Efficacy of Psychological, Pharmacological, and Emerging Interventions

#### Description of Included Studies

Thirteen studies addressed efficacy.119–123,125,127–133 Of these, 11 involved psychological interventions—cognitive behavioral therapy (CBT), CBT combined with hypnosis, cognitive therapy (CT), debriefing, prolonged exposure therapy (PE), psychoeducation, self-help, and supportive counseling (SC). One study involved a stepped collaborative care intervention that incorporated care management, evidence-based pharmacotherapy and CBT components.119 These studies were conducted in119,125,128,133 and outside the United States.120–123,127,129–131 They included a variety of populations such as victims of crime, motor vehicle accidents (MVAs), other types of accidents, intimate partner violence, sexual assault, and terrorist attacks; critically ill patients; and mothers experiencing traumatic childbirth or caring for a critically ill child. Two trials involved pharmacologic interventions. One studied stress doses of hydrocortisone in high-risk patients undergoing cardiac surgery132 and one compared escitalopram with either CT, PE, placebo, or waitlist.122

### Key Points: Efficacy

- Collaborative care is effective at reducing the severity of PTSD symptoms for civilian victims of injuries requiring inpatient surgical admission at 6-month, 9-month, and 12-month followup (low SOE).
- Debriefing is not effective in reducing either the incidence of PTSD or the severity of PTSD or depressive symptoms in civilian victims of crime, assault, or accident trauma at 6-month followup (low SOE).
- Evidence was insufficient for interventions to prevent the incidence of PTSD in the following cases:
  ○ CBT for civilian victims of MVAs, falls, assaults, and work-related trauma admitted to the intensive care unit
  ○ CT for hospitalized survivors of MVAs and terrorist attacks and for victims of nonsexual assault or MVAs
  ○ Debriefing for victims of crime, assault, or accident trauma at 2-week, 6-week, and 11-month followup
  ○ PE for hospitalized survivors of MVAs and terrorist attacks, for victims of nonsexual assault or MVAs, and for survivors of various trauma types including rape
  ○ Psychoeducation for victims of violent crime
  ○ Self-help for women recently diagnosed with breast cancer
  ○ SC for mothers who recently experienced traumatic childbirth, underwent and emergency cesarean section, or were caring for their critically ill child
  ○ Hydrocortisone in high-risk patients undergoing cardiac surgery
  ○ Collaborative care for civilian victims of injuries requiring inpatient surgical admission at 12-month followup
- Evidence was insufficient for interventions to reduce the severity of PTSD symptoms in all of the cases described in the previous Key Point, as well as the following:
  ○ Collaborative care for civilian victims of injuries requiring inpatient surgical admission at 1-month and 3-month followup
- Evidence was insufficient for interventions to reduce the severity of related psychological symptoms in the following cases:
  ○ CBT for reducing symptoms of anxiety or depression in victims of MVAs, falls, assaults, and work-related trauma admitted to the ICU
  ○ CT for reducing symptoms of anxiety or depression in hospitalized survivors of MVAs and terrorist attacks and for victims of nonsexual assault or MVAs
  ○ Debriefing for reducing symptoms of anxiety or depression in victims of crime, assault, or accident trauma
  ○ PE for reducing symptoms of anxiety or depression at the end of treatment in victims of nonsexual assault or MVAs
  ○ Psychoeducation for reducing symptoms of depression in victims of violent crime
  ○ Self-help for reducing symptoms of anxiety or depression in women recently diagnosed with breast cancer
  ○ SC for reducing symptoms of anxiety or depression in mothers who recently experienced traumatic childbirth, underwent an emergency cesarean section, or were caring for their critically ill child
  ○ Collaborative care for reducing symptoms of depression, alcohol use, or functional impairment in civilian victims of injuries requiring inpatient surgical admission

### Detailed Synthesis: Psychological Interventions

Table 9 summarizes the evidence about psychological interventions for two main outcomes: preventing PTSD (incidence of PTSD) and reducing PTSD symptom severity; it also lists the SOE grade for each intervention and outcome.

Table 9 Findings and strength of evidence for the efficacy of psychological interventions to prevent PTSD and reduce PTSD symptom severity

Intervention, Population | Outcome^a^ | Results | SOE^b^
Cognitive behavioral therapy, Civilian, mixed trauma types127 | Incidence of PTSD | CBT significantly less than control at 6- and 12-month followup (CAPS: 9% vs. 55%; 21 vs. 58%, p<0.05); 1 trial (N=46) | Insufficient
Cognitive behavioral therapy, Civilian, mixed trauma types127 | PTSD symptom severity | CBT significantly less than control at 6-month (CAPS: 31.95 vs. 52.45, p<0.05) and 12-month (CAPS: 25.26 vs. 52.50, ES (95% CI) = 1.11 (0.34 to 1.88), p<0.05) followup; 1 trial (N=46) | Insufficient
Cognitive therapy, Civilian, mixed trauma types122,123 | Incidence of PTSD | CT significantly less than control at 5-month followup (CAPS: 20.0% vs. 58.7%, p=0.002);122 1 trial (n=133) | Insufficient
Cognitive therapy, Civilian, mixed trauma types122,123 | PTSD symptom severity | CT not significantly different than control at the end of treatment (CAPS-2: 43.0 vs. 55.9, p=NR);123 1 trial (n=60) CT significantly less than control at 5-month followup (CAPS total: 29.5 vs. 50.6, p=NR);122 1 trial (n=133) | Insufficient
Debriefing, Civilian mixed trauma types129,131 | Incidence of PTSD | Debriefing not significantly different than control at 2-week,131 6-week,131 or 6-month (PSS-SR: 23% vs. 26%, p=NR)129 followup,^c^ data NR;131 2 trials (n=341) | Low
Debriefing, Civilian mixed trauma types129,131 | PTSD symptom severity | Debriefing not significantly different than control at 6-month (IES: 19.7 vs. 23.3, p=NR) followup^c;129^ 1 trial (n=105) Debriefing not significantly different than control at 2-week, 6-week, or 6-month followup, respectively (SI-PTSD: emotional debriefing, 18.1, 14.4, 10.2; educational debriefing, 16.2, 11.9, 9.3; No debriefing, 15.9, 10.5, 9.6, overall between-groups p=0.33);131 1 trial (N=236) | Low
Exposure-based therapies, Civilian, mixed trauma types122,123,128 | Incidence of PTSD | PE significantly less than control at the end of treatment (CAPS-2: 33% vs. 77%, p<0.001);123 1 trial (n=60) PE not significantly different than control at 4-week followup (PSS-I: 41% vs. 51%, p=0.60)^d;128^ 1 trial (N=137) PE significantly less than control at 5-month followup (CAPS: 21.6% vs. 57.1%, p<0.003);122 1 trial (n=156) | Insufficient
Psychoeducation, Civilian crime 129 and injury133 victims | Incidence of PTSD | Psychoeducation not significantly different than control at 1-month followup (PCL > 3: 46% vs. 51%, p=0.83);133 1 trial (n=79) Psychoeducation not significantly different than control at 6-month followup^c^ (PSS-SR: 11% vs. 26%, p=NR);129 1 trial (n=103) | Insufficient
Self-help materials, Women newly diagnosed with breast cancer120 | PTSD symptom severity | Significantly greater reduction for SHB than control at 3-month followup (PSDS-SR, Cohen’s d = −0.59 vs. −0.16, p=0.01) but not at 6-month followup (d = −0.47 vs. −0.13, p=NR); 1 trial (N=49) | Insufficient
Supportive counseling, Women, mixed trauma types121,125,130 | Incidence of PTSD | SC not significantly different than control at 4 to 6 weeks postpartum [MINI-PTSD: 34% vs. 30%, RR (95% CI)=1.15 (0.66 to 2.02), p=NS] or at 3 months postpartum [MINI-PTSD 6% vs. 17%, RR (95% CI)=0.35 (0.10 to 1.23), p=NS];121 1 trial (N=103) | Insufficient
Supportive counseling, Women, mixed trauma types121,125,130 | PTSD symptom severity | SC not significantly different than control at 6 months (IES difference: −3.5, p=NS);130 1 trial (N=162) SC significantly less than control at 12 months (PHSI-P difference: −2.0, p<0.05);125 1 trial (N=174) | Insufficient

CAPS = Clinician Administered PTSD Scale; CBT = cognitive behavioral therapy; CT = cognitive therapy; ES = effect size; IES = Impact of Event Scale; MINI-PTSD = Mini-International Neuropsychiatric Interview Post-Traumatic Stress Disorder; N = entire sample; n = subset of sample; NR = not reported; NS = not significant; PCL = Posttraumatic Stress Disorder Checklist; PE = prolonged exposure therapy; PHSI-P = Post-Hospitalization Stress Index for Parent; PSDS-SR = Posttraumatic Stress Diagnostic Scale-Self Report; PSS-I=PTSD Symptom Scale-Interview Version; PSS-SR = Post-traumatic Stress Disorder Scale-Self Report version; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial; RR = relative risk; SC = supportive counseling; SHB = self-help booklet; SI-PTSD = Structured Interview for PTSD; SOE = strength of evidence

a If the CAPS or CAPS-2 was the primary outcome measure, it is the only measure of PTSD symptom severity reported here. Additional outcome measures of PTSD symptom severity are reported in the subsection of the text for each intervention.

b For more detailed information about the rationale for SOE grading, please refer to Appendix G.

c Because of very high overall attrition (i.e., greater than 40% at 11-month followup) in this study of debriefing and psychoeducation,129 we considered all outcomes collected at that time point as having a high risk of bias and therefore do not report them here or in Appendix G.

d Due to high overall attrition (i.e., greater than 40% at 12-week followup) in this study of exposure-based therapy,128 we considered all of its outcomes collected at that time point as having a high risk of bias and therefore do not report them here.

#### Cognitive Behavioral Therapy

Overall, one study comparing CBT with usual care met our inclusion criteria (Table 10);127 four studies otherwise meeting inclusion criteria were omitted from our main data synthesis for high risk of bias.83,96,97,108,127 The remaining government-funded study was conducted in Australia with male and female civilian trauma victims who sustained an injury severe enough to warrant hospitalization of greater than 24 hours (Table 10); subjects were excluded if they had a moderate to severe brain injury.127 The investigators compared CBT (n=24) with usual care (n=22). The primary outcome measure was the Clinician Administered PTSD Scale (CAPS). Follow-up assessments were obtained at 6 and 12 months after treatment ended.

Table 10 Characteristics of included cognitive behavioral therapy trials

Study and Risk of Bias, Prevention Type | Study Design, Intervention (n) | Treatment Duration (Followup Duration) | Population and Trauma Type | Primary Outcome Measure and Baseline Score | Mean Age and Age Range (Years) | Percentage Female
O’Donnell et al., 2012^127^ Medium Targeted | Unblinded RCT, CBT (24) UC (22) | Four to 10 sessions of 90 minutes (12 months) | Civilian mixed (Transportation accidents, falls, assaults, work-related accidents, other forms of traumatic injury) | CAPS total score, CBT: 56.61 UC: 60.73 | 35.9^a^ (range NR) | 39.1^a^

CAPS = Clinician Administered PTSD Scale; CBT = cognitive behavioral therapy; n = subset of sample; NR = not reported; RCT = randomized controlled trial; UC = usual care

a Data not directly provided by the study authors. Data provided here are calculated by authors of this report.

Compared with patients receiving usual care, patients receiving CBT had a significantly lower prevalence of PTSD at both 6- and 12-month followup (Table 9). The CBT group also had significantly less severe PTSD symptoms as measured by the CAPS mean total score at both 6 and 12 months. Compared with usual care, the CBT group reported significantly lower symptoms of anxiety on the Hospital Anxiety and Depression Scale (HADS-A) at 6 (6.38 vs. 11.87, p≤0.05) and 12 months (7.84 vs. 11.0, p<0.05), as well as significantly lower symptoms of depression on the Beck Depression Index (BDI) at both followup points (12.24 vs. 31.20 and 13.95 vs. 29.00, p<0.05). At 6 months, the incidence of a major depressive episode was similar for the usual care and CBT groups (respectively, 9% vs. 4%, p=NS); however, at 12 months, more subjects in the usual care group met criteria for a major depressive episode than those in the CBT group (50% vs. 11%, p<0.05). At 6 and 12 months, the groups did not differ significantly with respect to the prevalence of anxiety disorders.

#### Cognitive Therapy

Table 11 summarizes the characteristics of the two CT studies meeting our inclusion criteria.122,123 They enrolled civilian mixed trauma samples of adults recruited from either an Australian “traumatic stress clinic” (n=60)123 or an Israeli hospital emergency department (n=133).122 Both compared CT with a waitlist group. For both studies, individuals that conducted clinical assessments were blinded to treatment condition, but the subjects were not blinded with respect to treatment group. Both studies included men and women ranging in age from 18 to 70 years. The primary outcome measure was the CAPS122 or the CAPS-2.^123^ Follow-up assessments were conducted at 5^122^ and 6 months.123 In one of these studies,122 the waitlist group received PE after 5-month followup, and we do not report this group’s 9-month outcomes in the report because the timing of the delayed intervention does not meet our eligibility criteria (see Table 3 in the Inclusion and Exclusion Criteria section). Both studies received government funding; one also received funding from a pharmaceutical company and a private foundation.122 One study used ITT analysis,123 and the other performed a “completer analysis” based on approximately 85 percent of the randomized sample.122

Table 11 Characteristics of included cognitive therapy trials

Study and Risk of Bias, Prevention Type | Study design, Intervention (n) | Treatment Duration (Followup Duration) | Population and Trauma Type | Primary Outcome Measure and Baseline Score | Mean Age and Age Range (Years) | Percentage Female
Bryant et al., 2008^123^ Low Targeted | Outcome assessors blinded RCT, CT (30) WL (30) | Five weekly 90-minute individual sessions (6 months) | Civilian mixed (MVAs, “other trauma,” physical assault, and “other accident”) | CAPS-2 total score, CT: 66.8 WL: 63.6 | NR | 57.8^a^
Shalev et al., 2011^122^ Medium Targeted | Outcome assessors blinded RCT, CT (40) WL (93) | 12 weekly 90-minute individual sessions (5 months)^b^ | Civilian mixed (Terrorist attacks, MVAs, work or other accidents) | CAPS total score, CT: 71.78 WL: 71.66 | NR | 52.1

CAPS = Clinician Administered PTSD Scale; CAPS-2 = Clinician Administered PTSD Scale-2; CT = cognitive therapy; MVA = motor vehicle accident; n = subset of sample; NR = not reported; RCT = randomized controlled trial; WL = waitlist

a Data not directly provided by the study authors. Data provided here are calculated by authors of this report.

b The WL group received PE after 5-month followup and was no longer an inactive comparison group. Because the timing of the delayed intervention does not meet our eligibility criteria, we do not report its outcomes at 9-month followup in the report.

One trial reported a significant difference in PTSD incidence between CT and waitlist groups at 5 months122 (Table 9). The studies also reported different findings for PTSD symptom severity outcomes. One study found no significant differences between the CT and waitlist groups,123 whereas the other study reported that CT was associated with lower PTSD symptom severity at 5 months.122 Only one of the two studies measured symptoms of anxiety and depression, reporting no significant differences between the CT and waitlist groups in anxiety (BAI, 23.4 vs. 19.6) or depression (BDI-2 18.9 vs. 21.9) scores at the end of treatment.123

#### Coping Skills Therapy

One study otherwise meeting our eligibility criteria reported on the effectiveness of coping skills or stress inoculation therapy but was omitted from our main data synthesis for high risk of bias.85

#### Debriefing Interventions

Two studies met our eligibility criteria for a debriefing intervention.129,131 Five studies otherwise meeting eligibility criteria were omitted from our main data synthesis for high risk of bias.84,85,93,95,103 Table 12 summarizes the characteristics of the two included studies, which we rated as low131 or medium risk of bias.129

Table 12 Characteristics of included debriefing trials

Study and Risk of Bias, Prevention Type | Study design, Intervention (n) | Treatment Duration (Followup Duration) | Population and Trauma Type | Primary Outcome Measure and Baseline Score | Mean Age and Age Range (Years) | Percentage Female
Rose et al., 1999^129^ Medium Universal | Unblinded RCT, Debriefing + psycho-education (54) Assessment only (51) | One, 1-hour individual session (6 months)^a^ | Civilian crime victims (Actual or threatened physical or sexual assault; bag snatch) | PSS, Debriefing + psychoeducation: 16.8 Assessment: 15.6 | 35 (18–76) | 24.8
Sijbrandij et al., 2006^131^ Low Universal | Unblinded RCT, Emotional debriefing (76) Educational debriefing (79) No debriefing (81) | One, 45- to 60-minute individual session (6 months) | Civilian assault or accident | SI-PTSD, Emotional debriefing: 19.9 Educational debriefing: 19.9 No debriefing: 17.7 | 40.4^b^ (range NR) | NR

n = subset of sample; NR = not reported; PSS = Post-traumatic Symptom Scale; RCT = randomized controlled trial; SI-PTSD = Structured Interview for PTSD

a Because of very high overall attrition (i.e., greater than 40% at 11-month followup) in this study of debriefing and psychoeducation,129 we considered all outcomes collected at that time point as having a high risk of bias and therefore do not report them here or in Appendix G.

b Data not directly provided by the study authors. Data provided here are calculated by authors of this report.

Both government-funded studies were conducted with civilian trauma samples and employed debriefing based on Mitchell’s Critical Incident Stress Debriefing protocol (CISD). One study compared two forms of CISD (“emotional debriefing” [n=76] and “educational debriefing” [n=79]) with a no-debriefing control group (n=81);131 the other study compared CISD plus education (n= 54) with assessment only (n=51).129 The “emotional debriefing” intervention consisted of CISD minus the educational component, and the “educational debriefing” intervention consisted of CISD minus the emotional component. Timing of the debriefing ranged from 9 to 31 days129 or 11 to 19 days131 post-trauma. The subjects and treatment providers were not blinded with respect to treatment group assignment. Subjects were excluded if they had been assaulted by a member of their household129 or if they had already received a debriefing session since the trauma.131 The primary outcome measures were the Post-traumatic Symptom Scale129 and the Structured Interview for PTSD.131 Follow-up assessments were conducted at 2 weeks, 6 weeks, and 6 months in one study131 and at 6 months after the debriefing in the other.129 Because of very high overall attrition (i.e., greater than 40% at 11-month followup) in one of the studies,129 we considered all of its outcomes collected at that time point as having a high risk of bias and therefore do not report them here.

The debriefing intervention and the inactive comparator did not differ significantly in the number of participants meeting criteria for PTSD or in reducing PTSD symptom severity at 6-month followup129,131 (Table 9). Both studies reported that groups did not differ significantly in severity of anxiety and depressive symptoms at followup. The mean BDI score did not differ significantly between the debriefing and assessment groups at 6-month followup (12.1 vs. 13.9, p=NR).129 Similarly, at 6-month followup, the mean HADS-Depression score and the change in HADS-Depression score did not differ significantly (p=0.23) in the groups that received emotional debriefing (3.8, −1.6), educational debriefing (3.2, −1.5), or no debriefing (3.2, −1.4).131 The emotional debriefing, educational debriefing, and no debriefing groups also did not differ significantly (p=0.96) in HADS-Anxiety score (5.0, 4.4, 4.6) or change in HADS-Anxiety score from pretreatment (−2.4, −2.2, −2.1) at 6-month followup.131

One study reported no differences between groups on perceived helpfulness of the intervention at 6 months (p>0.10).129

#### Exposure-Based Therapies

Three studies met our inclusion criteria for exposure-based interventions;122,123,128 two studies otherwise meeting our eligibility criteria were omitted from our main data synthesis for high risk of bias.99,112 Table 13 summarizes the characteristics of the three studies meeting our inclusion criteria.122,123,128

Table 13 Characteristics of included exposure-based trials

Study and Risk of Bias, Prevention Type | Study Design, Intervention (n) | Treatment Duration (Followup Duration) | Population and Trauma Type | Primary Outcome Measure and Baseline Score | Mean Age and Age Range (Years) | Percentage Female
Bryant et al., 2008^123^ Low Targeted | Outcome assessors blinded RCT, PE^a^ (30) WL (30) | Five weekly 90-minute individual sessions (6 months) | Civilian mixed (MVA, other trauma, physical assault, and other accident) | CAPS-2 total score, PE: 70.6 WL: 63.6 | NR | 57.8^b^
Rothbaum et al., 2012^128^ Medium Universal | Outcome assessors blinded RCT, PE (69) Assessment only (68) | Three 60-minute individual sessions (12 weeks)^c^ | Civilian mixed (Sexual assault, nonsexual assault, MVA, other) | PSS-I^d^ | 31.5^b^ (range NR) | 65
Shalev et al., 2012^122^ Medium Targeted | Outcome assessors blinded RCT, PE (63) WL (93) | 12 weekly 90-minute individual sessions (5 months)^e^ | Civilian mixed (Terrorist attacks, MVAs, work or other accidents) | CAPS total score, PE: 73.59 WL: 71.66 | NR | 52

CAPS/CAPS-2 = Clinician Administered PTSD Scale/Clinician Administered PTSD Scale-2; MVA = motor vehicle accident; n = subset of sample; NR = not reported; PDS = Posttraumatic Stress Diagnostic Scale; PE = prolonged exposure therapy; PSS-I = PTSD Symptom Scale-Interview version; RCT = randomized controlled trial; WL = waitlist

a Imaginal and/or in vivo exposure.

b Data not directly provided by the study authors. Data provided here are calculated by authors of this report.

c Because of high overall attrition (i.e., greater than 30% at 12-week followup) in this study of exposure-based therapy,128 we considered all of its outcomes collected at that time point as having a high risk of bias and therefore do not report them here or in Appendix G.

d PSS-I assessed at 4- and 12-week followup only; mean baseline PDS score was 18.9 in both groups.

e The WL group received PE after 5-month followup and was no longer an inactive comparison group. Because the timing of the delayed intervention does not meet our eligibility criteria, we do not report its outcomes at 9-month followup in the report.

All three studies compared PE with an inactive comparator of either a waitlist (WL)122,123 or assessment only128 in civilian mixed trauma samples. Additional details about two of these studies122,123 are provided in the previous section on Cognitive Therapy. The third study128 was conducted in the United States and assessed individuals ages 18 to 65 who presented to a Level I Trauma Center in a public hospital within 72 hours of experiencing a traumatic event. A total of 162 individuals were randomized to PE (30,123 69,^128^ and 63^122^) and 191 individuals were randomized to the inactive condition (30,123 68,^128^ and 93^122^). Because of high overall attrition (i.e., greater than 30% at 12-week followup) in one study of exposure-based therapy,128 we considered all of its outcomes collected at that time point as having a high risk of bias and therefore do not report them here. In addition, the waitlist group in another study received PE after 5-month followup, and we do not report this group’s 9-month outcomes in the report because the timing of the delayed intervention does not meet our eligibility criteria (see Table 3 in the Inclusion and Exclusion Criteria section).122

The prevalence of PTSD was significantly lower in groups receiving PE compared with WL or assessment only at the end of treatment123 and at 5-month 122 followup, but not at 4-week128 followup (Table 9). PTSD symptom severity was significantly lower in PE compared with WL or assessment only at the end of treatment123 and at 4-week,128 and 5-month122 followup (Table 9).

Compared with assessment only or WL, PE was associated with significantly lower symptoms of depression at 4 weeks (BDI-II, 15.4 vs. 21.4, p<0.05^128^) and at the end of treatment (BDI-2, 21.9 vs. 12.1, p=0.003).123 PE was also associated with significantly lower symptoms of anxiety (BAI, 19.6 vs. 13.4, p=0.004) at the end of treatment.123

#### Psychoeducation

Two studies met our eligibility criteria for psychoeducation,129,133 while one study otherwise meeting eligibility criteria was rated high risk of bias and omitted from our main data synthesis.110 Of the included studies (Table 14), one was conducted in the UK with civilian crime victims,110 and the other in the United States with civilians presenting to a trauma center with injuries requiring surgical intervention.133 Subjects were excluded if they had been assaulted by a member of their household129 or if they were in criminal custody.133 Subjects and treatment providers were not blinded with respect to treatment group assignment. The primary outcome measures were the PSS-SR and the PCL. Because of very high overall attrition (i.e., greater than 40% at 11-month followup) in one of the studies, we considered all of its outcomes collected at that time point as having a high risk of bias and therefore do not report them here.129

Table 14 Characteristics of included psychoeducation trials

Study and Risk of Bias, Prevention Type | Study Design, Intervention (n) | Treatment Duration (Followup Duration) | Population and Trauma Type | Primary Outcome Measure and Baseline Score | Mean Age and Age Range (Years) | Percentage Female
Rose et al., 1999^129^ Medium Universal | Unblinded RCT, Psychoeducation (52) Assessment only (51) | One 1-hour individual session (6 months)^a^ | Civilian crime victims (Actual or threatened physical or sexual assault; bag snatch) | PSS-SR, Psychoeducation: 16.0 Assessment: 15.6 | 35 (18–76) | 24.8
Wong et al., under review133 Medium Universal | Unblinded RCT, Psychoeducation (42) Control (37) | One 18-minute video (1 month) | Civilian mixed (Gunshot, falls, etc.) with physical injury | PCL, NR | 31.2^b^ (range NR) | 16

n = subset of sample; NR = not reported; PCL = Posttraumatic Stress Disorder Checklist; PSS-SR = Post-traumatic Stress Disorder Scale-Self Report version; RCT = randomized controlled trial

a Because of very high overall attrition (i.e., greater than 40% at 11-month followup) in this study of psychoeducation,129 we considered all outcomes collected at that time point as having a high risk of bias and therefore do not report them here or in Appendix G.

b Data not directly provided by the study authors. Data provided here are calculated by authors of this report.

The incidence of PTSD did not differ significantly between the psychoeducation and control groups at 1-month133 or at 6-month129 followup (Table 9). The psychoeducation and control groups did not differ significantly in PTSD symptom severity at 1-month133 or 6-month followup.129 There was no statistically significant difference between the psychoeducation group and the assessment-only group in severity of symptoms of depression at either follow-up point (BDI at 6 months, 9.8 vs. 13.9, p>0.10).129 There was no difference in perceived helpfulness of the psychoeducation intervention compared with assessment only, p>0.10).129

#### Self-Help Materials

One study met our eligibility criteria for self-help-based interventions;120 one study otherwise meeting our eligibility criteria was omitted from our main data synthesis for high risk of bias.106

The included trial (Table 15) was conducted in Australia with 49 women ranging in age from 32 to 86 years newly diagnosed with Stage 0 to II breast cancer. This study compared a CBT-based self-help booklet (SHB) group with an information-only booklet group. The SHB (which women were encouraged to read over a 3-month period) covered topics such as relaxation and meditation; coping with side effects; emotional adjustment, including cognitive restructuring around self-blame and stress management activities; body image and identity; social support; and survivorship. Subjects and treatment providers/assessors were not blinded as to diagnosis or treatment condition. The median amount of information read by the women was 100 percent in the intervention group and 75 percent in the control group; both groups reported using the material they received for up to 15 minutes per week, and the median number of worksheets completed by the women in the SHB group was 25 percent.

Table 15 Characteristics of included self-help booklet–based trial

Study and Risk of Bias, Prevention Type | Study Design, Intervention (n) | Treatment Duration (Followup Duration) | Population and Trauma Type | Primary Outcome Measure and Baseline Score | Mean Age and Age Range (Years) | Percentage Female
Beatty et al., 2010^120^ Medium Universal | Unblinded RCT, SHB (25) Information booklet (24) | NR (6 months) | Women medical (Newly diagnosed with breast cancer within previous month) (Civilian/military status not specified) | PSS-SR, 10.76^a^ | 55.2 (range NR) | 100

n = subset of sample; NR = not reported; RCT = randomized controlled trial; PSS-SR = Posttraumatic Stress Diagnostic Scale-Self Report version; SHB = self-help booklet.

a Reported for the entire sample, not by treatment arm

Compared with women in the information booklet group, women in the SHB group exhibited a significantly greater reduction in PTSD symptom severity from baseline to 3 months but not from baseline to 6 months (Table 9). Symptoms of depression and anxiety were measured with the Depression and Anxiety Stress Scales (DASS). The effect sizes for change in the severity of DASS-depression were small and did not differ significantly between the SHB group and the information booklet group at 3 months (0.15 vs. 0.03, p=NR) or 6 months (0.20 vs. −0.06, p=NR). Likewise, effect sizes for change in the severity of DASS-anxiety were small and did not differ significantly between the SHB group and the information booklet group at 3 months (0.19 vs. 0.17) or 6 months (0.33 vs. 0.18). Quality of life was measured with the European Organisation for Research and Treatment of Cancer Quality of Life Core Questionnaire and Breast Cancer Module. The effect sizes for change in quality of life were small and did not differ significantly between groups at 3 months (0.10 vs. 0.18, p=NR) or 6 months (0.18 vs. 0.37, p=NR).

#### Supportive Counseling

Three studies met the eligibility criteria for supportive counseling (SC).121,125,130 Three studies otherwise meeting eligibility criteria were omitted from our main data synthesis for high risk of bias.86,105,117 Table 16 summarizes the characteristics of the three studies included in the analyses.

Table 16 Characteristics of included supportive counseling trials

Study and Risk of Bias, Prevention Type | Study Design, Intervention (n) | Treatment Duration (Followup Duration) | Population and Trauma Type | Primary Outcome Measure and Baseline Score | Mean Age and Age Range (Years) | Percentage Female
Gamble et al., 2005^121^ Medium Universal | Outcome assessor blinded RCT, SC (50) Control (53) | One 40- to 60-minute session within 72 hours of birth (4–6 weeks and 3 months postpartum) | Civilian (Traumatic childbirth) | MINI-PTSD, SC: NR Control: NR | 28 (18–46) | 100
Melnyk et al., 2004^125^ Medium Universal | Unblinded RCT, COPE (90) Control (84) | Three-phase intervention, duration: NR (1, 3, 6, and 12 months postdischarge) | Civilian medical (Mothers of critically ill children) | PHSI-P, NR | 31.2 (18–52) | 100
Ryding et al., 2004^130^ Medium Universal | Unblinded RCT, SC (89) Control (73) | Two 2-hour group sessions (6 months) | Civilian medical (Emergency cesarean section) | IES, SC: NR Control: NR | 332 (19–44) | 100

COPE = Creating Opportunities for Parent Empowerment; IES = Impact of Event Scale; MINI-PTSD = Mini-International Neuropsychiatric Interview-Posttraumatic Stress Disorder; n = subset of sample; NR = not reported; PHSI-P = Post-Hospital Stress Index for Parents; RCT = randomized controlled trial; SC = supportive counseling

The three studies included women ranging in age from 18 to 76 years who recently experienced emergency cesarean section130 or an otherwise traumatic childbirth121 or who were caring for a critically ill child who had suffered an accidental injury.125 The specific format of SC differed across studies and included personal storytelling,130 a preventive educational-behavioral program to empower parents,125 and elements of critical stress debriefing.121 Subjects, but not the treatment providers, were blinded with respect to treatment group assignment. The researcher who conducted the 3-month follow-up assessment in one study was blinded as to group allocation.121 One study was government funded,125 and two were funded by private foundations.121,130 Each study used a different primary outcome measure to assess PTSD or PTSD symptom severity: the IES,130 the Post-Hospital Stress Index for Parents (PHSI-P),125 and the Mini-International Neuropsychiatric Interview-Post-Traumatic Stress Disorder (MINI-PTSD).121 Follow-up assessments were conducted at various intervals ranging from 4 weeks121 to 12 months.125

Compared with standard postnatal care, SC was not more effective in preventing PTSD in mothers at 4 to 6 weeks postpartum or at 3 months postpartum (Table 9).121 Six months after emergency cesarean section, there was no statistically significant difference in PTSD symptom severity between the group of mothers who received SC and the group who received standard postpartum care.130 In mothers caring for a critically ill child, PTSD symptom severity did not differ between the SC and the control group at 1-month, 3-month, or 6-month followup, but it was significantly lower at 12-month followup in mothers who received SC.125

In mothers who experienced traumatic childbirth, the percentage of women with a diagnosis of depression did not differ significantly between the two groups at 4 to 6 weeks postpartum (32% vs. 34%); however, at 3 months postpartum, fewer women who received SC had a diagnosis of depression as compared with those in the control group (8% vs. 32%, p=0.002).121 After emergency cesarean section, mothers who received SC did not differ from those in the control group on the severity of symptoms of depression (median Edinburgh Postnatal Depression Scale score: 6.0 vs. 6.0, p=0.1256) or in rate of depression (Edinburgh Postnatal Depression Scale score >12, 8.5% vs. 13.8%, p=NS).130 In mothers caring for their critically ill child, symptoms of depression were significantly lower in the SC group compared with the control group at 1-month (POMS depression subscale, 2.6 vs. 4.1, p<0.05) and 6-month (POMS depression subscale, 2.0 vs. 3.9, p<0.05) followup but not at 3- or 12-month follow-up.125 Two studies evaluated anxiety, and both reported there were no significant differences between the SC and control groups at 3-month followup (DASS-anxiety >9, 2% vs. 11% [RR (95% CI) = 0.18 (0.02 to 1.45)], p=NR;121 STAI, 38.4 vs. 40.7, p=NR125) as well as at 6-month followup (STAI, 36.0 vs. 39.1, p=NR)125 and 12-month followup (STAI, 35.8 vs. 40.9, p=NR).125

Finally, the perceived utility (helpfulness) of the SC intervention was rated as 8 or higher on a 10-point scale by 86 percent of women who experienced a traumatic childbirth.121 Similarly, 71 percent of women who experienced an emergency cesarean section reported that the SC intervention completely met their expectations.130

#### All Other Psychological Interventions

One study of eye movement desensitization and reprocessing102 and one study of interpersonal therapy104 met the eligibility criteria but were omitted from our main data synthesis for high risk of bias. No studies of cognitive processing therapy or psychological first aid met our inclusion criteria.

#### High-Risk-of-Bias Studies

We rated 33 studies as high risk of bias.27,47,51,83–88,90,92–97,99–101,103–110,112–114,116–118 In most cases, we had data from studies of either low or medium risk of bias, and we did not include these high-risk-of-bias studies in our analyses. For some psychological or related interventions or populations (e.g., veterans), however, we only found high-risk-of-bias studies; therefore, we briefly summarize them here.

##### Eye Movement Desensitization and Reprocessing Therapy

One unblinded, nonrandomized study compared the effect of a single session of eye movement desensitization and reprocessing (EMDR) with waitlist on PTSD symptom severity in U.S. survivors of Hurricane Andrew.102 Controlling for pretreatment levels, the EMDR group exhibited significantly lower scores at 1 month than the waitlist group on IES total (21.6 vs. 37.9, p<0.001), IES avoidance (10.5 vs. 16.6, p<0.03) and IES intrusion (11.2 vs. 21.6, p<0.001). IES scores remained relatively stable at the 3-month followup for the EMDR group (total, 24.3; avoidance, 12.6; intrusions, 11.8) but were not reported for controls.

##### Interpersonal Counseling

One randomized study conducted in Australia compared the effect of manualized interpersonal counseling versus treatment as usual (i.e., nonspecific psychological support) on PTSD incidence and related PTSD and psychological symptoms in victims of MVAs, falls, and nonaccidental injury.104 Interpersonal counseling focused on the impact of the trauma on interpersonal issues predating the traumatic event as well as those arising from the traumatic event in domains such as role transitioning, grief, and loss. At 6-month followup, no statistically significant differences were found between treatment groups in the incidence of PTSD or in the severity of PTSD, depression, or anxiety symptoms.

##### Memory Structuring Intervention

One study evaluated a novel intervention called “Memory Structuring Intervention” (MSI).101 MSI attempts to shift processing of traumatic memory from uncontrollable somatosensory and affective processes toward more controlled linguistic and cognitive processes by providing patients organization, labeling, and causality. Seventeen MVA survivors were randomly assigned to receive MSI versus supportive listening control 48 hours after their accident. At follow-up, PDS total (8.1 vs. 18.5, p<0.05), PDS arousal (4.2 vs. 7.7, p<0.05), and PDS intrusions (1.6 vs. 5.8, p<0.05) were significantly lower in MSI recipients than in controls.

##### Debriefing Plus Stress Coping Intervention

One study evaluated a stress coping intervention with military and civilian first responders to a traffic accident with multiple fatalities.85 The military responders received debriefing plus stress management, and the civilian responders received only debriefing. The results suggested better outcome in the military responders, as indicated by lower frequency of symptoms on the PTSS-10.

##### Structured Writing Intervention

One study evaluated the effectiveness of a writing intervention in 67 civilians who had experienced a traumatic physical injury or accident.92 The perceived utility of the writing intervention was high, but it was not more effective than the information-only control condition in reducing the incidence of PTSD.

### Detailed Synthesis: Pharmacological Interventions

Overall, two studies of pharmacologic interventions met eligibility criteria for KQ 1.^122,132^ Eight studies otherwise meeting eligibility criteria were omitted from the main data synthesis for high risk of bias.47,51,100,107,113,114,116,118 Both of the included studies involved civilian medical traumas, one with mixed trauma122 and one with stress following cardiac surgery.132 The funding was identified for only one of the studies,122 which had both governmental and industry support.

Table 17 summarizes the available evidence of the efficacy of two included studies testing pharmacologic interventions.

Table 17 Findings and strength of evidence of the efficacy of pharmacologic interventions

Intervention, Population | Outcome | Results | SOE^a^
Escitalopram vs. waitlist control or placebo, Civilian mixed trauma types122 | Incidence of PTSD | Escitalopram not significantly different than WL at 5-month followup (CAPS: 61.9% vs. 58.2%, p=NR); 1 trial (n=116)^b^ Escitalopram not significantly different than placebo at 5-month or 9-month followup (CAPS: 61.9% vs. 55.6%, p=0.57; 42.1% vs. 47.1%, p=NR); 1 trial (n=46)^c^ | Insufficient
Escitalopram vs. waitlist control or placebo, Civilian mixed trauma types122 | PTSD symptom severity | Escitalopram not significantly different than WL at 5-month followup (CAPS total: 48.7 vs. 50.6, p=NR); 1 trial (n=116)^b^ Escitalopram not significantly different than placebo at 5-month or 9-month followup (CAPS total: 48.7 vs. 47.1, p=NR; 47.2 vs. 45.7, p=NR); 1 trial (n=46)^c^ | Insufficient
Hydrocortisone stress dose vs. placebo, Cardiac surgery132 | Incidence of PTSD | Hydrocortisone less than placebo at 6-month followup (PTSS-10: 7.1% vs. 21.4%, p=NR^d^); 1 trial (n=28) | Insufficient
Hydrocortisone stress dose vs. placebo, Cardiac surgery132 | PTSD symptom severity | Hydrocortisone less than placebo at 6-month followup (PTSS-10: 15.5 vs. 25.5, p=0.03); 1 trial (n=28) In terms of the number and type of traumatic memories, hydrocortisone not significantly different than placebo at 6-month followup (PTSS-10: data NR, p≤0.33); 1 trial (n=28) | Insufficient

CAPS = Clinician Administered PTSD Scale; n = subset of sample; NR = not reported; PTSD = posttraumatic stress disorder; PTSS-10 = Posttraumatic Stress Symptom 10 Question Inventory; SOE = strength of evidence; WL = waitlist

a For more detailed information about the rationale for SOE grading, please refer to Appendix G.

b Completers of 116 randomized.

c Completers of 46 randomized.

d Data not directly provided by the study authors. Data provided here are calculated by authors of this report.

#### Selective Serotonin Reuptake Inhibitors (SSRIs)

Table 18 summarizes the characteristics of the one study meeting our inclusion criteria.122

Table 18 Characteristics of included SSRI trial

Study and Risk of Bias, Prevention Type | Study design, Intervention (n) | Treatment Duration (Followup Duration) | Population and Trauma Type | Primary Outcome Measure and Baseline Score | Mean Age and Age Range (Years) | Percentage Female
Shalev et al., 2011^122^ Medium Targeted | Double blind RCT, Escitalopram (23) Placebo (23) WL (93) | Escitalopram and placebo, 10 mg twice daily (9 months) WL: not applicable (5 months)^a^ | Civilian mixed (Terrorist attacks, MVAs, work or other accidents) | CAPS total score, Escitalopram: 79.83 Placebo: 74.91 WL: 71.66 | 37.8^b^ | 48.9^b^

CAPS = Clinician Administered PTSD Scale; Mg = milligrams; MVA = motor vehicle accident; n = subset of sample; RCT = randomized controlled trial; WL = waitlist

a The WL group received PE after 5-month followup and was no longer an inactive comparison group. Because the timing of the delayed intervention does not meet our eligibility criteria, we do not report its outcomes at 9-month followup in the report.

b Data not directly provided by the study authors. Data provided here are calculated by authors of this report.

This study was conducted in Israel with a mixed civilian trauma sample. Treatment arms included escitalopram (n=23), placebo (n=23), and waitlist (93). Additional details about this study can be found in the section on Cognitive Therapy.

The incidence of PTSD did not differ between the SSRI (61.9%) and waitlist (58.2%) groups at 5-month follow-up (p=NR) (Table 17). The incidence of PTSD did not differ between the SSRI group and the placebo group at 5-month (61.9% vs. 55.6%, p=0.57) or at 9-month (42.1% vs. 47.1%, p=NR) followup. There were no differences between the SSRI and waitlist groups on mean CAPS total and PSS-SR symptom severity scores at the 5-month follow-up assessment. There were no significant differences in PTSD symptom severity between SSRI and placebo at either 5-month or 9-month followup. This study did not report on any other outcomes of interest.

#### Steroids

##### Hydrocortisone

One study assessing the efficacy of hydrocortisone to prevent PTSD met our inclusion criteria.132 Three studies were rated as having a high risk of bias and omitted from our main data synthesis.113,114,118 Table 19 summarizes the characteristics of the one medium risk-of-bias study.132 One randomized, double-blind study was conducted in 36 adult German civilians who were at high risk for perioperative complications during cardiac surgery with cardiopulmonary bypass.132 Patients were not eligible if they were pregnant, required an emergency operation, had hepatic or renal dysfunction, were HIV positive, had insulin-dependent diabetes, had an extracardial septic focus, had chronic or acute inflammatory disease, required glucocorticoids other than hydrocortisone, or could not provide informed consent. Eligible patients were randomly assigned to 4 days of either stress doses of hydrocortisone (a loading dose followed by a taper) or placebo beginning before induction of anesthesia. At 6 months postsurgery, 28 patients (ages 63 to 73 years, 32% female, 14 in each arm) were assessed by phone.

Table 19 Characteristics of included hydrocortisone trial

Study and Risk of Bias, Prevention Type | Study Design, Intervention (n) | Treatment Duration (Followup Duration) | Population and Trauma Type | Primary Outcome Measure and Baseline Score | Mean Age and Age Range (Years) | Percentage Female
Weis et al, 2006^132^ Medium Targeted | Double-blind RCT, Hydrocortisone stress dose^a^ (14) Placebo (14) | 4 days (6 months) | Civilian medical; cardiac surgery | PTSS-10; Hydrocortisone: NR Placebo: NR | 68.5^b^ (63–73) | 32.1^b^

mg = milligrams; n = subset of sample; NR = not reported; POD = postoperative day; PTSS-10 = Posttraumatic Stress Symptom 10 Question Inventory; RCT = randomized controlled trial

a Loading dose of 100 mg over 10 minutes, followed by a continuous infusion of 10 mg/hour for 24 hours (postoperative day [POD] 1). This was reduced to 5 mg/hour on POD 2, tapered to 3 × 20 mg on POD 3, and then 3 × 10 mg on POD 4.

b Data not directly provided by the study authors. Data provided here are calculated by authors of this report.

Compared with the placebo group, the hydrocortisone group had significantly lower stress symptom scores as measured by the Posttraumatic Stress Symptom 10 Questionnaire Inventory (median of 15.5 vs. 25.5, p=0.03) and appeared less likely to have evidence of PTSD as defined by a stress symptom score > 35 (7.1% vs. 21.4%, p=NR) (Table 17). Patients did not differ significantly with regard to number and type of traumatic memories (p≤0.33). Also, patients in the hydrocortisone group had significantly higher health-related quality-of-life scores in 5 of 8 subscales and in both physical and mental summary scores (p≤0.01) on the Medical Outcomes Study Short Form (SF-36).

#### All Other Pharmacologic Interventions

One or more studies on the following pharmacologic therapies otherwise met inclusion criteria but were rated high risk of bias and omitted from the main data synthesis: anticonvulsants,47 benzodiazepines,100 and beta-blockers.47,51,107,116 No studies of the following therapies met inclusion criteria: alpha blockers, monoamine oxidase inhibitors, narcotics, nonbenzodiazepine sedatives or hypnotics, opioid antagonists, other second-generation antidepressants, second-generation (atypical) antipsychotics, serotonin and norepinephrine reuptake inhibitors, or tricyclic antidepressants.

#### High-Risk-of-Bias Studies

Eight studies comparing a pharmacologic intervention with placebo that were rated as high risk of bias otherwise met our eligibility criteria.47,51,100,107,113,114,116,118 One compared the effectiveness of two separate medications against each other and against placebo;47 all others compared a single medication with placebo or no treatment.51,100,107,113,114,116,118

##### Anticonvulsants—Gabapentin

An RCT pilot study compared the effectiveness of a 14-day treatment with propranolol (n=17) with gabapentin (n=14) and with placebo control (n=14) in patients admitted to a level 1 surgical trauma center after a severe physical injury requiring specialized emergency care.47 The PCL-C score decreased over time in all groups, but the treatment arms did not differ significantly at 1, 4, or 8 months; at the 4-month followup, rates of PTSD or major depressive disorder did not differ significantly across groups.

##### Benzodiazepines

A prospective cohort study in Israel compared the effectiveness of benzodiazepines (n=13) with no benzodiazepines (n=13) in civilians presenting to the emergency department following a traumatic event.100 Those receiving benzodiazepines were “judged to require medication” by attending physicians, suggesting greater symptom severity than the group not receiving benzodiazepines. The two groups did not differ in PTSD or anxiety scores at either 1 or 6 months.

##### Beta-Blockers

###### Metoprolol

A prospective observational study in Germany with a treatment completer analysis compared the effectiveness of metoprolol (n=84, dispensed to patients for a varying and unclear period) with placebo (n=44).107 Assignment between groups was at the discretion of the attending physicians. At 6-month followup, neither the number of traumatic memories nor PTSD symptom scores differed significantly between the two groups.

###### Propranolol

An RCT pilot study compared the effectiveness of a 14-day treatment with propranolol (n=17) with gabapentin (n=14) and with placebo control (n=14) in patients admitted to a level 1 surgical trauma center after a severe physical injury requiring specialized emergency care.47 The PCL-C score decreased over time in all groups, but the treatment arms did not differ significantly at 1, 4, or 8 months; at the 4-month followup, rates of PTSD or major depressive disorder did not differ significantly across groups.

A nonrandomized controlled trial in France compared the effectiveness of a 7-day treatment with propranolol (n=11) with treatment without propranolol (n=8 patients who refused propranolol but agreed to participate in the study) for patients presenting to the emergency department following MVA or physical assault.116 At 2 months after the event, patients receiving propranolol had lower severity scores on the Treatment Outcome PTSD scale and a lower risk of having a PTSD diagnosis.

A high-risk-of-bias RCT in the United States compared the effectiveness of 10 days of propranolol (n=19) with placebo (n=23) in civilians presenting to the emergency department following the experience of a traumatic event.51 At 1-month and 3-month follow-up assessments, CAPS symptom severity and PTSD incidence did not differ significantly between groups, but there were fewer “physiologic responders during imagery of the traumatic event” in the propranolol group (0/8) than the placebo group (6/14) (p=0.04).

###### SteroidsHydrocortisone

An RCT in Israel compared the effectiveness of a single bolus of hydrocortisone (n=15, dose based on weight) between 1.5 and 5.5 hours after the trauma with placebo (n=10) for patients presenting to an emergency department with a variety of traumas (traffic accidents, work accidents, snake bite).118 At 1 and 3 months, patients who received hydrocortisone were less likely to have a diagnosis of PTSD than those in the placebo arm.

An RCT in Germany compared the effectiveness of stress doses of hydrocortisone with standard postoperative care in patients after cardiac surgery.113 At 6 months postsurgery, 48 (26 hydrocortisone, 22 standard care) of 91 randomized patients were available for assessment. The median Posttraumatic 10 Stress Symptom Inventory score was significantly lower (p<0.05) in the hydrocortisone group (20.0) than in the standard care group (25.5), but the groups did not differ in traumatic memories.

An RCT in Germany compared the effectiveness of stress doses of hydrocortisone with placebo in patients with septic shock.114 At followup (median, 31 months), the incidence of PTSD was significantly lower (p<0.02) in the hydrocortisone group (1/9) compared with the placebo group (7/11). There were no significant differences between the groups in the number reporting traumatic experiences.

### Detailed Synthesis: Emerging Interventions

Overall, one study assessing the efficacy of an emerging intervention met eligibility criteria for KQ 1.^119^ It involved civilian traumas requiring hospitalization. The study was funded by governmental support.

Table 20 summarizes the available evidence of the efficacy of the single study testing an emerging intervention.

Table 20 Findings and strength of evidence of the absolute effectiveness of collaborative care interventions

Intervention, Population | Outcome | Results | SOE^a^
Collaborative care vs. usual care, Civilian trauma requiring hospitalization119 | Incidence of PTSD | Collaborative care not statistically different than usual care at 12 months [CAPS: OR (95% CI) = 1.39 (0.77 to 2.51)]; 1 trial (N=207) | Insufficient
Collaborative care vs. usual care, Civilian trauma requiring hospitalization119 | PTSD symptom severity | Collaborative care lower than usual care, as measured:; - by CAPS at 6 months (42.9 vs. 56.7, p<0.01) and 12 months (38.6 vs. 47.2, p<0.05) after injury; - by greater decrease in CAPS over 12 months following injury (group by time interaction, p<0.01); - by PCL-C at 6 months (40.6 vs. 49.9, p<0.01), 9 months (40.2 vs. 45.5, p<0.01) and 12 months (37.4 vs. 42.5, p<0.05) after injury); - by greater decrease in CAPS over 12 months following injury (group by time interaction, p<0.01; Collaborative care not statistically different than usual care at 1-month or 3-month followup after injury (PCL-C: 50.2 vs. 51.1 and 45.9 vs. 48.6, respectively, p=NR); 1 trial (N=207) | Low

CAPS = Clinician Administered PTSD Scale; CI = confidence interval; N = entire sample; NR = not reported; OR = odds ratio; PCL-C = PTSD Checklist-Civilian Version; PTSD = posttraumatic stress disorder; SOE = strength of evidence

a For more detailed information about the rationale for SOE grading, please refer to Appendix G.

#### Collaborative Care

One study assessing the absolute effectiveness of collaborative care to prevent PTSD met our inclusion criteria.119 Table 21 summarizes the characteristics of this low risk-of-bias study. This randomized, single-blind study was conducted in 207 adult civilian trauma patients requiring surgical hospitalization who screened positive for PTSD symptoms on two separate occasions within 1 month of the trauma. Patients were not eligible if they required immediate psychiatric intervention, lived over 100 miles from the trauma center, were currently incarcerated, or had recent histories of severe violence and were likely to face criminal charges. Eligible patients were randomly assigned to either 12 months of collaborative care, a stepped combination of care management, psychopharmacology, and cognitive behavioral therapy (n=104) or to a usual care control (n=103). The symptoms of PTSD and functional limitations were reassessed at 1-, 3-, 6-, 9-, and 12-month followup after the index injury admission. An ITT analysis was performed 12 months after the injury.

Table 21 Characteristics of included collaborative care trial

Study and Risk of Bias, Prevention Type | Study design, Intervention (n) | Treatment Duration (Followup Duration) | Population and Trauma Type | Primary Outcome Measure and Baseline Score | Mean Age and Age Range (Years) | Percentage Female
Zatzick et al., in press119 Low Targeted | Single blind RCT, CC (104) UC (103) | 12 months (12 months) | Civilian medical; trauma requiring surgical admission | CAPS; CC: NR UC: NR PCL-C; CC: 50.5 UC: 50.8 | 38.5 (range NR) | 47.8

CAPS = Clinician Administered PTSD Scale; CC = collaborative care; n = subset of sample; NR = not reported; PCL-C = PTSD Checklist-Civilian Version; RCT = randomized controlled trial; UC = usual care

Compared with usual care, the collaborative care group had significantly lower stress symptom scores beginning 6 months after injury (Table 20). Specifically, the collaborative care group had lower PTSD as measured by the Clinician-Administered PTSD Scale at followup 6 months (42.9 vs. 56.7, p<0.01) and 12 months (38.6 vs. 47.2, p<0.05) after the injury and over the course of the 12 months of treatment had a greater decrease in overall PTSD symptom severity (group-by-time interaction, p<0.01). Further, the collaborative care group had significantly lower stress scores as measured by the PCL-C at 6 months (40.6 vs. 49.9, p<0.01), 9 months (40.2 vs. 45.5, p<0.01), and 12 months (37.4 vs. 42.5, p<0.05) after injury, and a similar greater decrease in overall PTSD severity over the 12-month course (group-by-time interaction, p<0.001), although no significant difference was seen 1 month or 3 months after injury. The incidence of PTSD at 12 months did not differ between the groups (OR, 1.39; 95% CI, 0.77 to 2.51). Finally, patients did not differ significantly at 12-month followup with regard to symptoms of depression as measured by the PHQ-9 (8.4 vs. 10.1), alcohol use as measured by the Alcohol Use Disorders Identification Test (2.0 vs. 2.4), or functional impairment as measures by the SF-36 (43.7 vs. 41.2), although there was greater improvement in collaborative care group over the 12-month period (group-by-time interaction, p<0.01).

### Comparative Effectiveness: Psychological Versus Psychological Interventions

#### Description of Included Studies

Eight studies addressed the comparative effectiveness of a psychological intervention with another psychological intervention.89,91,122–124,126,129,131 The interventions included Battlemind training, CBT, CT, PE, debriefing, and SC. These studies were conducted outside the United States and included samples exposed to a variety of traumas, such as crime, physical assault, motor vehicle and other types of accidents, and terrorist attacks.

### Key Points: Comparative Effectiveness

- In individuals with acute stress disorder a meta-analysis comparing CBT with SC found that people who received CBT had greater reductions in severity of PTSD symptoms than those who received SC (moderate SOE). Differences between CBT and SC with respect to preventing PTSD (low SOE), reducing the severity of depression symptoms (low SOE), or reducing the severity of anxiety symptoms (moderate SOE) also favored CBT; these results, however, did not reach statistical significance.
- Evidence was insufficient for preventing PTSD or for reducing the severity of PTSD symptoms in the following cases:
  ○ Battlemind training versus standard postdeployment debriefing in armed forces personnel from the UK
  ○ CBT versus CBT plus hypnosis in civilian victims of nonsexual assault or MVAs
  ○ CBT plus hypnosis versus SC in civilian victims of nonsexual assault
  ○ CT versus PE in civilian victims of nonsexual assault or MVAs, or hospitalized survivors of MVAs or terrorist attacks
  ○ Debriefing versus
    – A different form of debriefing in civilian victims of violent crime
    – Psychoeducation in civilian victims of violent crime
  ○ An SSRI (escitalopram) versus
    – CT for hospitalized survivors of MVAs and terrorist attacks
    – PE for hospitalized survivors of MVAs and terrorist attacks
- Evidence was insufficient for reducing the severity of related psychological symptoms in the following cases:
  ○ CBT versus CBT plus hypnosis for reducing symptoms of anxiety or depression in civilian victims of nonsexual assault or MVAs
  ○ CBT plus hypnosis versus SC for reducing symptoms of anxiety or depression in civilian victims of nonsexual assault or MVAs
  ○ CT versus PE for reducing symptoms of anxiety or depression in civilian victims of nonsexual assault or MVAs
  ○ Debriefing versus a different form of debriefing for reducing symptoms of anxiety or depression in civilian victims of violent crime
  ○ Debriefing versus psychoeducation for reducing symptoms of depression in civilian victims of violent crime
- Evidence was unavailable (no studies other than high risk of bias) for reducing PTSD incidence, PTSD symptom severity, or the severity of related psychological symptoms for any other psychological or pharmacological interventions of interest.

### Detailed Synthesis: Psychological Versus Psychological Interventions

#### Battlemind Training

Two studies27,126 reported on Battlemind training, one of which was omitted from our main data synthesis for high risk of bias.27 Table 22 summarizes the characteristics of the one study meeting our inclusion criteria.126

Table 22 Findings and strength of evidence for the comparative effectiveness of early psychological interventions to prevent PTSD and reduce PTSD symptom severity

Intervention, Population | Outcome^a^ | Results | SOE^b^
Battlemind training, Military, mixed combat-related trauma types126 | PTSD symptom severity | Battlemind training no different than standard postdeployment debriefing at 4–6 month followup (PCL-C: data=NR); 1 trial (n=2,443) | Insufficient
Battlemind training, Military, mixed combat-related trauma types126 | Incidence of PTSD | Battlemind training no different than standard postdeployment debriefing at 4–6 month followup (PCL-C: data=NR); 1 trial (n=2,443) | Insufficient
CBT vs. CBT+Hypnosis, Civilian, mixed trauma types91 | Incidence of PTSD | CBT not significantly different from CBT+Hypnosis at the end of treatment (CAPS-2: 36% vs. 30%, p=NR) or at 6-month followup (CAPS-2: 42% vs. 40%, p=NR); 1 trial (n=63) | Insufficient
CBT vs. CBT+Hypnosis, Civilian, mixed trauma types91 | PTSD symptom severity | CBT+Hypnosis less than for CBT at the end of treatment (IES-I: 11.30 vs. 16.58, p<0.05) but not at 6-month followup (IES-I: 13.57 vs. 16.97, p=NR; 1 trial (n=63) | Insufficient
CBT vs. SC, Civilian, mixed trauma types with acute stress disorder89,91,124 | Incidence of PTSD | CBT not significantly different than SC at end of treatment (CAPS-2, CIDI-PTSD: RR, 0.27, 95% CI [0.05 to 1.29]; I^2^=71.8%) or at 6-month followup (CAPS-2, CIDI-PTSD: RR, 0.46, 95% CI [0.21 to 1.01]; I^2^=44.9%); 3 trials (n=105) | Low
CBT vs. SC, Civilian, mixed trauma types with acute stress disorder89,91,124 | PTSD symptom severity | Greater reduction for CBT than for SC on IES-I at the end of treatment (WMD, −7.85, 95% CI [-11.18 to −4.53]; I^2^=1.3%) and at 6-month followup (WMD, −8.19, 95% CI [−11.79 to −4.58]; I^2^=6.8%); 3 trials (n=105) Greater reduction for CBT than for SC on IES-A at the end of treatment (WMD, −14.04, 95% CI [−19.37 to −8.71]; I^2^=53.8%) and 6-month followup (WMD, −9.94, 95% CI [−15.06 to −4.83]; I^2^=44.0%); 3 trials (n=105) | Moderate
CBT+Hypnosis vs. SC, Civilian, mixed trauma types91 | Incidence of PTSD | CBT+Hypnosis not significantly different from SC at the end of treatment (CAPS-2: 30% vs. 50%, p=NR) or at 6-month followup (CAPS-2: 40% vs. 58%, p=NR); 1 trial (n=54) | Insufficient
CBT+Hypnosis vs. SC, Civilian, mixed trauma types91 | PTSD symptom severity | CBT+Hypnosis lower than SC at the end of treatment (IES-I: 11.30 vs. 19.83, p<0.005) and at 6-month followup (IES-I: 13.57 vs. 20.21, p<0.05); 1 trial (n=54) | Insufficient
CT vs. exposure therapy, Civilian, mixed trauma types122,123 | Incidence of PTSD | CT lower than PE at the end of treatment (CAPS-2: 33% vs. 63%, p=0.002) and at 6-month followup (CAPS-2: 37% vs. 63%, p=0.007); 1 trial (n=60)123 CT not significantly different from PE at 5-month followup (CAPS: 21.4% vs. 18.2%, p=NR)^c^; 1 trial (n=89)122 CT not significantly different from PE at 9-month followup (CAPS: 21.2% vs. 22.9%, p=NR)^c^; 1 trial (n=87)122 | Insufficient
CT vs. exposure therapy, Civilian, mixed trauma types122,123 | PTSD symptom severity | Greater reduction for CT than for PE at 6-month followup (CAPS-2: 49.8 vs. 32.1, p=0.03); 1 trial (n=60)123 CT not significantly different from PE at 5-month followup (CAPS: 29.5 vs. 28.6, p=NR)^c^; 1 trial (n=89)122 CT not significantly different from PE at 9-month followup (CAPS: 27.9 vs. 27.5, p=NR)^c^; 1 trial (n=87)122 | Insufficient
Emotional debriefing vs. educational debriefing, Civilian, mixed trauma types131 | Incidence of PTSD | No significant difference between the two forms of debriefing at 2-week, 6-week, or 6-month followup (SI-PTSD: data NR); 1 trial (n=155) | Insufficient
Emotional debriefing vs. educational debriefing, Civilian, mixed trauma types131 | PTSD symptom severity | No significant difference between emotional debriefing and educational debriefing at 6-month followup (SI-PTSD change scores: −7.1 and −6.4, respectively, p=0.33)^d^; 1 trial (n=155) | Insufficient
Psychoeducation vs. debriefing combined with psychoeducation, Civilian, crime victims129 | Incidence of PTSD | Psychoeducation not significantly different than debriefing combined with psychoeducation (PSS: 11% vs. 23%, p=NR) at 6-month followup^e^; 1 trial (n=106) | Insufficient
Psychoeducation vs. debriefing combined with psychoeducation, Civilian, crime victims129 | PTSD symptom severity | Psychoeducation not significantly different than debriefing combined with psychoeducation at 6-month followup (PSS, 10.9 vs. 13.8, p=NR; IES, 16.7 vs. 19.7, p=NR)^e^; 1 trial (n=106) | Insufficient
CT vs. SSRI (escitalopram) Civilian, mixed trauma types122 | Incidence of PTSD | CT lower than SSRI at 5-month and 9-month followup (CAPS: 18.2% vs. 61.9%, and 22.8% vs. 42.1%, respectively, p=NR); 1 trial (n=54)^f^ | Insufficient
CT vs. SSRI (escitalopram) Civilian, mixed trauma types122 | PTSD symptom severity | CT less than SSRI at 5-month and 9-month followup (CAPS: 29.5 vs. 48.7, and 27.9 vs. 47.2, respectively, p=NR); 1 trial (n=54)^f^ | Insufficient
PE vs. SSRI (escitalopram), Civilian, mixed trauma types122 | Incidence of PTSD | PE lower than SSRI at 5-month and 9-month followup (CAPS: 21.4% vs. 61.9% and 21.2% vs. 42.1%, respectively, p=NR); 1 trial (n=77)^g^ | Insufficient
PE vs. SSRI (escitalopram), Civilian, mixed trauma types122 | PTSD symptom severity | PE less than SSRI at 5-month and 9-month followup (CAPS: 28.6 vs. 48.7 and 27.5 vs. 47.2, respectively, p=NR); 1 trial (n=71)^g^ | Insufficient

CAPS/CAPS-2 = Clinician Administered PTSD Scale/Clinician Administered PTSD Scale-2; CBT = cognitive behavioral therapy; CBT+Hypnosis = CBT combined with hypnosis; CI = confidence interval; CIDI-PTSD = Composite International Diagnostic Interview PTSD; CT = cognitive therapy; IES = Impact of Event Scale; IES-A = Impact of Event-Avoidance subscale; IES-I = Impact of Event Scale-Intrusions subscale; n = subset of sample; NR = not reported; PCL-C = PCL-C = Posttraumatic Stress Disorder Checklist, Civilian Version; PE = prolonged exposure therapy; PSS = Posttraumatic Stress Scale; PTSD = posttraumatic stress disorder; RR = relative risk; SC = supportive counseling; SI-PTSD = Structured Interview for PTSD; SOE = strength of evidence; SSRI = selective serotonin reuptake inhibitor; WMD = weighted mean difference

a If the CAPS or CAPS-2 was the primary outcome measure, it is the only measure of PTSD symptom severity reported here. Additional outcome measures of PTSD symptom severity are reported in the subsection of the text for each intervention.

b For more detailed information about the rationale for SOE grading, please refer to Appendix G.

c Completers of 103 randomized.

d Adjusted for baseline.

e Because of very high overall attrition (i.e., greater than 40% at 11-month followup) in this study of psychoeducation and debriefing combined with psychoeducation, we considered all of its outcomes collected at that time point as having a high risk of bias and therefore do not report them here or in Appendix G.

f Completers of 63 randomized.

g Completers of 86 randomized.

The included study (Table 23) was conducted in the UK and compared an adapted version of Battlemind training with standard stress and homecoming briefs in male and female armed forces personnel returning from Afghanistan.126 Battlemind training is described as incorporating information about common postdeployment reactions and self-help, drawing on positive psychology and cognitive behavioral techniques to reframe difficulties that personnel may encounter.126 Treatment providers were not blinded with respect to treatment group assignment. The primary outcome measure was the PCL-C.

Table 23 Characteristics of the included Battlemind trial

Study and Risk of Bias, Prevention Type | Study Design, Intervention (n) | Treatment Duration (Followup Duration) | Population and Trauma Type | Primary Outcome Measure and Baseline Score | Mean Age and Age Range (Years) | Percentage Female
Mulligan et al., 2012^126^ Medium Universal | Recruitment assessors blinded RCT, Battlemind training (1,108) Standard care (1,335) | One 45-minute group session (4 to 6 months) | Mixed combat-related traumatic events | Median PCL-C total score, Battlemind training: 21 Standard care: 20 | NR | 1.7^a^

n = subset of sample; NR = not reported; PCL-C = Posttraumatic Stress Disorder Checklist, Civilian Version; RCT = randomized controlled trial

a Data not directly provided by the study authors. Data provided here are calculated by authors of this report.

Battlemind training was no more effective than standard postdeployment debriefing in reducing the severity of PTSD symptoms or the incidence of depression (Table 22). Most participants (> 65%) reported that they were “somewhat” or “very much” satisfied with the briefing and that they found it useful both at the end of treatment and at 4- and 6-month followup. Ratings of satisfaction and perceived utility did not differ significantly between groups.

#### CBT Versus CBT with Hypnosis

Table 24 summarizes the characteristics of the one study meeting our inclusion criteria.91 This government-funded RCT was conducted in Australia with civilian trauma survivors with ASD following a nonsexual assault or MVA. The subjects were randomized to six sessions of CBT (n=33) or CBT combined with hypnosis (CBT+Hypnosis, n=30).

Table 24 Characteristics of the included cognitive behavioral therapy trial

Study and Risk of Bias, Prevention Type | Study design, Intervention (n) | Treatment Duration (Followup Duration) | Population and Trauma Type | Primary Outcome Measure and Baseline Score | Mean Age and Age Range (Years) | Percentage Female
Bryant et al., 2005^91^ Medium Targeted | Unblinded RCT, CBT (33) CBT+Hypnosis (30) | Six 50-minute sessions (6 months) | Civilian; MVAs or nonsexual assault | CAPS-2, NR | 33^a^ (range NR) | 60.9

CAPS-2 = Clinician Administered PTSD Scale-2; CBT = cognitive behavioral therapy; CBT+Hypnosis = CBT combined with hypnosis; MVA = motor vehicle accident; n = subset of sample; NR = not reported; RCT = randomized controlled trial

a Data not directly provided by the study authors. Data provided here are calculated by authors of this report.

There was no significant difference in the incidence of PTSD between groups at the end of treatment or at 6-month followup, although PTSD symptom severity was lower in the CBT+Hypnosis group than the CBT group at the end of treatment (Table 22). There were no significant differences between the CBT and CBT+Hypnosis groups at the end of treatment or at 6-month followup, respectively, in severity of symptoms of depression (BDI-2: 13.24 vs. 11.37 and 14.61 vs. 13.57) or anxiety (BAI: 14.91 vs. 15.47 and 15.67 vs. 17.07).

#### CBT Versus SC

Three Australian studies directly compared the effectiveness of CBT versus SC.89,91,124 All subjects were civilian mixed trauma survivors who met the DSM-IV or Acute Stress Disorder Interview criteria for acute stress disorder. Duration of treatment ranged from 5 to 6 weeks. Each trial included assessments at the end of treatment and at 6-month followup. The primary outcome measure was the CAPS-2^91,124^ or the Composite International Diagnostic Interview PTSD (CIDI-PTSD) module.89

A fourth trial, otherwise meeting criteria for this section, was rated high risk of bias and omitted from our main data synthesis but included in our sensitivity analyses.87 Table 25 summarizes the characteristics of the three studies meeting our inclusion criteria.

Table 25 Characteristics of included cognitive behavioral therapy versus supportive counseling trials

Study and Risk of Bias, Prevention Type | Study design, Intervention (n) | Treatment Duration (Followup Duration) | Population and Trauma Type | Primary Outcome Measure and Baseline Score | Mean Age and Age Range (Years) | Percentage Female
Bryant et al., 1998^89^ Medium Targeted | Unblinded RCT, CBT (12) SC (12) | Five 90-minute weekly individual sessions (6 months) | Civilian; MVAs or industrial accidents | CIDI-PTSD, NR | 32.6^a^ (range NR) | 58.3
Bryant et al., 2003^124^ Medium Targeted | Unblinded RCT, CBT (12) SC (12) | Five 90-minute weekly individual sessions (6 months) | Civilian; MVAs or nonsexual assault | CAPS-2, NR | 31.2^a^ (range NR) | 66.7
Bryant et al., 2005^91^ Medium Targeted | Unblinded RCT, CBT (33) SC (24) | Six 50-minute sessions (6 months) | Civilian; MVAs or nonsexual assault | CAPS-2, NR | 34.0^a^ (range NR) | 60.9

CAPS-2 = Clinician Administered PTSD Scale-2; CBT = cognitive behavioral therapy; CIDI-PTSD = Composite International Diagnostic Interview PTSD Module; MVA = motor vehicle accident; n = subset of sample; NR = not reported; RCT = randomized controlled trial; SC = supportive counseling

a Data not directly provided by the study authors. Data provided here are calculated by authors of this report.

All three trials assessed the incidence of PTSD using either the CAPS-2^91,124^ or the CIDI-PTSD.89 We used random effects models to estimate the combined relative risk of PTSD at the end of treatment and at 6-month followup. Both analyses did not detect statistically significant differences between treatment groups (Table 22). Pooled findings of the risk of PTSD at the end of treatment rendered indeterminate results with wide confidence intervals (RR, 0.27; 95 CI%, 0.05 to 1.29; I^2^=71.8%; Figure 3). Similarly, at 6 months, no statistically significant difference between treatments could be detected (RR, 0.46; 95 CI%, 0.21 to 1.01; I^2^=44.9%; Figure 4). The results at 6 months, however, almost reached statistical significance and numerically favored patients treated with CBT than with SC. In a sensitivity analysis, we included one high-risk-of-bias trial.87 The findings indicated a statistically significantly lower risk of PTSD for patients treated with CBT than SC at the end of treatment (RR, 0.33; 95% CI, 0.12 to 0.86; I^2^=58.7%; Appendix H, Figure H1) as well as at 6-month followup (RR, 0.45; 95% CI, 0.25 to 0.82; I^2^=32.0%; Appendix H, Figure H2).

Figure 3 Mean change from baseline to end of treatment in PTSD incidence rates for CBT compared with SC

Figure 3 is titled “Mean change from baseline to end of treatment in PTSD incidence rates for CBT compared with SC.” The figure displays a forest plot reporting the combined relative risk of developing a PTSD diagnosis according to the CAPS-2 or the CIDI-PTSD in the CBT group versus the supportive counseling group. The risk of PTSD at the end of treatment did not differ significantly between treatment groups (relative risk, 0.27, 95% CI, 0.05 to 1.29). Overall I2 = 71.8%.

Figure 4 Mean change from baseline to 6-month followup in PTSD incidence rates for CBT compared with SC

Figure 4 is titled “Mean change from baseline to 6-month follow-up in PTSD incidence rates for CBT compared with SC.” The figure displays a forest plot reporting the combined relative risk of developing a PTSD diagnosis according to the CAPS-2 or the CIDI-PTSD in the CBT group versus the supportive counseling group. The risk of PTSD at 6-month follow-up did not differ significantly between treatment groups (relative risk, 0.46, 95% CI, 0.21 to 1.01). Overall I2 = 44.9%.

All three studies assessed PTSD symptom severity with the IES, which consists of two subscales: intrusion (IES-I) and avoidance (IES-A). Pooled results for PTSD symptom reduction found a statistically significantly greater reduction in both subscales at the end of treatment and 6 months for subjects treated with CBT than for those who received SC (Figures 5 through 8).

Figure 5 Mean change from baseline to end of treatment in IES-Avoidance subscale symptom scores for CBT compared with SC

Figure 5 is titled “Mean change from baseline to end of treatment in IES Avoidance Subscale symptom scores for CBT compared with SC.” The figure displays a forest plot reporting the change in weighted mean difference in IES Avoidance symptom scores between the CBT group and the supportive counseling group. The meta-analysis results show that the CBT group experienced a significantly greater reduction in IES Avoidance scores at the end of treatment compared to the supportive counseling group (weighted mean difference, −14.04, 95% CI, −19.37 to −8.71). Overall I2 = 53.8%.

Figure 6 Mean change from baseline to 6-month followup in IES-Avoidance subscale symptom scores for CBT compared with SC

Figure 6 is titled “Mean change from baseline to 6-month follow-up in IES Avoidance Subscale symptom scores for CBT compared with SC.” The figure displays a forest plot reporting the change in weighted mean difference in IES Avoidance symptom scores between the CBT group and the supportive counseling group. The meta-analysis results show that the CBT group experienced a significantly greater reduction in IES Avoidance scores at 6-month follow-up compared to the supportive counseling group (weighted mean difference, −9.94, 95% CI, −15.06 to −4.83). Overall I2 = 44.0%.

Figure 7 Mean change from baseline to end of treatment in IES-Intrusion subscale symptom scores for CBT compared with SC

Figure 7 is titled “Mean change from baseline to end of treatment of treatment in IES Intrusion Subscale symptom scores for CBT compared with SC.” The figure displays a forest plot reporting the change in weighted mean difference in IES Intrusion symptom scores between the CBT group and the supportive counseling group. The meta-analysis results show that the CBT group experienced a significantly greater reduction in IES Intrusion scores at the end of treatment compared to the supportive counseling group (weighted mean difference, −7.85, 95% CI, −11.18 to −4.53). Overall I2 = 1.3%.

Figure 8 Mean change from baseline to 6-month followup in IES-Intrusion subscale symptom scores for CBT compared with SC

Figure 8 is titled “Mean change from baseline to 6-month follow-up of treatment in IES Intrusion Subscale symptom scores for CBT compared with SC.” The figure displays a forest plot reporting the change in weighted mean difference in IES Intrusion symptom scores between the CBT group and the supportive counseling group. The meta-analysis results show that the CBT group experienced a significantly greater reduction in IES Intrusion scores at 6-month follow-up compared to the supportive counseling group (weighted mean difference, −8.19, 95% CI, −11.79 to −4.58). Overall I2 = 6.8%.

Our meta-analysis shows a significantly greater reduction in IES-A scores with moderate effect size and statistical heterogeneity at the end of treatment (WMD, −14.04, 95% −8.71; CI, −19.37, I^2^=53.8%; Figure 5), which was maintained but slightly smaller in magnitude at 6-month followup (WMD, −9.94; 95% CI, −15.06 to −4.83; I^2^=44.0%; Figure 6). Our sensitivity analysis (n=136) including a fourth, high-risk-of-bias trial found a slightly larger benefit at the end of treatment (WMD, −14.17; 95% CI, −17.82 to −10.51; I^2^=31.9%; Appendix H, Figure H3) and at 6-month followup (WMD,-11.49; 95% CI, −16.09 to −6.90; I^2^=52.7%; Appendix H, Figure H4).

Our meta-analysis shows a significantly greater reduction in IES-I scores with a modest effect size and statistical heterogeneity at the end of treatment (WMD, −7.85; 95% CI, −11.18, −4.53; I^2^=1.3%; Figure 7. Mean change from baseline to end of treatment in IES-Intrusion subscale symptom scores for CBT compared with SC), which was maintained and slightly larger in magnitude at 6-month followup (WMD, −8.19, 95% CI, −11.79 to −4.58; I^2^=6.8%; Figure 8). Our sensitivity analysis (n=136) including a fourth, high-risk-of-bias trial found a slightly larger benefit at the end of treatment (WMD, −8.39; 95% CI, −11.45 to −5.34; I^2^=0.0%; Appendix H, Figure H5) but a slightly smaller benefit at 6-month followup (WMD, −7.91; 95% CI, −10.85 to −4.98; I^2^=0.0%; Appendix H, Figure H6).

Taken together, consistent evidence (I^2^ range 0.0% to 53.8%) from three medium risk-of-bias trials and a fourth high-risk-of-bias trial supports a conclusion of greater reduction of PTSD symptom severity for patients treated with CBT than for those treated with SC (moderate SOE) (Table 22).

All three included trials (n=105) evaluated the effectiveness of CBT on coexisting psychiatric conditions.89,91,124 Three trials used the BDI or the BDI-2, two trials used the BAI,91,124 and one trial used the STAI.124

Our meta-analysis showed no statistically significant difference between CBT and SC on changes in anxiety symptoms at the end of treatment (SMD, −0.25; 95% CI, −0.64 to 0.13; I^2^=0.0%; Figure 9) or at 6-month followup (SMD, 95% CI, −0.28 to −0.67, 0.11; I^2^=0.0%; Figure 10). Our sensitivity analysis that included one high-risk-of-bias trial87 found a statistically significant difference between groups on changes in anxiety symptoms at the end of treatment (SMD, −0.39; 95% CI, −0.74 to −0.04; I^2^=2.2%; Appendix H, Figure H7) and at 6-month followup (SMD, −0.59; 95% CI, −1.16 to −0.01; I^2^=58.7%; Appendix H, Figure H8).

Figure 9 Mean change from baseline to end of treatment in anxiety symptom scores for CBT compared with SC

Figure 9 is titled “Mean change from baseline to end of treatment in anxiety symptom scores for CBT compared with SC.” The figure displays a forest plot reporting the change in standardized mean difference in anxiety symptom scores measured using the BAI or the STAI between the CBT group and the supportive counseling group. The meta-analysis results show no statistically significant difference in anxiety symptom score changes at the end of treatment in the CBT group compared to the supportive counseling group (standardized mean difference, −0.25, 95% CI, −0.64 to 0.13). Overall I2 = 0.0%.

Figure 10 Mean change from baseline to 6-month followup in anxiety symptom scores for CBT compared with SC

Figure 10 is titled “Mean change from baseline to 6-month follow-up in anxiety symptom scores for CBT compared with SC.” The figure displays a forest plot reporting the change in standardized mean difference in anxiety symptom scores measured using the BAI or the STAI between the CBT group and the supportive counseling group. The meta-analysis results show no statistically significant difference in anxiety symptom score changes at 6-month follow-up in the CBT group compared to the supportive counseling group (standardized mean difference, −0.28, 95% CI, −0.67 to 0.11). Overall I2 = 0.0%.

Similarly, the pooled results rendered no statistically significant differences on changes in depression symptoms between CBT and SC at the end of treatment (SMD, −0.15; 95% CI, −0.53 to 0.24; I^2^=0.0%; Figure 11) or at 6-month followup (SMD, −0.21; 95% CI, −0.70 to 0.27; I^2^=30%; Figure 12). Our sensitivity analyses that included one high-risk-of-bias trial87 did not render any statistically significant differences on change in depression symptoms (Appendix H, Figures H-9 and H-10).

Figure 11 Mean change from baseline to end of treatment in depression symptom scores for CBT compared with SC

Figure 11 is titled “Mean change from baseline to end of treatment in depression symptom scores for CBT compared with SC.” The figure displays a forest plot reporting the change in standardized mean difference in depression symptom scores measured using the BDI or the BDI-2 between the CBT group and the supportive counseling group. The meta-analysis results show no statistically significant difference in depression symptom score changes at the end of treatment in the CBT group compared to the supportive counseling group (standardized mean difference, −0.15, 95% CI, −0.53 to 0.24). Overall I2 = 0.0%.

Figure 12 Mean change from baseline to 6-month followup in depression symptom scores for CBT compared with SC

Figure 12 is titled “Mean change from baseline to 6-month follow-up in depression symptom scores for CBT compared with SC.” The figure displays a forest plot reporting the change in standardized mean difference in depression symptom scores measured using the BDI or the BDI-2 between the CBT group and the supportive counseling group. The meta-analysis results show no statistically significant difference in depression symptom score changes at the end of treatment in the CBT group compared to the supportive counseling group (standardized mean difference, −0.21, 95% CI, −0.70 to 0.27). Overall I2 = 30.0%.

#### CBT+Hypnosis Versus SC

Table 26 summarizes the characteristics of the one study meeting our inclusion criteria.91 This government-funded RCT was conducted in Australia with civilian trauma survivors with acute stress disorder following a nonsexual assault or MVA who were randomized to six sessions of CBT+Hypnosis (n=30) or SC (n=24). Additional details about this study can be found in the section on the efficacy of CBT.

Table 26 Characteristics of the included cognitive behavioral therapy+hypnosis versus supportive counseling trial

Study and Risk of Bias, Prevention Type | Study design, Intervention (n) | Treatment Duration (Followup Duration) | Population and Trauma Type | Primary Outcome Measure and Baseline Score | Mean Age and Age Range (Years) | Percentage Female
Bryant et al., 2005^91^ Medium Targeted | Unblinded RCT, CBT+Hypnosis (30) SC (24) | Six 50-minute sessions (6 months) | Civilian; MVA or nonsexual assault | CAPS-2, NR | 34^a^ (range NR) | 60.9

CAPS-2 = Clinician Administered PTSD Scale-2; CBT+Hypnosis = combined with hypnosis; cognitive behavioral therapy; MVA = motor vehicle accident; n = subset of sample; NR = not reported; RCT = randomized controlled trial; SC = supportive counseling

a Data not directly provided by the study authors. Data provided here are calculated by authors of this report.

There was no significant difference between the rates of PTSD for the CBT+Hypnosis and SC groups at the end of treatment or at 6-month followup (Table 22). PTSD symptom severity was lower in the CBT+Hypnosis group compared with the SC group at the end of treatment and at 6-month followup. There were no significant differences between the CBT+Hypnosis and SC groups in severity of depression (BDI-2, 11.37 vs. 14.96 and 13.57 vs. 16.29) at the end of treatment or followup. Similarly, there were no significant differences between these two groups on severity of anxiety (BAI, 15.47 vs. 20.25 and 17.07 vs. 21.13).

#### CT Versus PE

Table 27 summarizes the characteristics of the two studies meeting our inclusion criteria for evaluating the comparative effectiveness of CT and PE.122,123 Both studies compared CT with PE in civilian mixed trauma samples. The CT arm contained 30^123^ and 40^122^ subjects; the PE arm, 30^123^ and 63 subjects.122 Additional details about this study are in the section on the efficacy of cognitive therapy.

Table 27 Characteristics of included cognitive therapy versus exposure therapy trials

Study and Risk of Bias, Prevention Type | Study Design, Intervention (n) | Treatment Duration (Followup Duration) | Population and Trauma Type | Primary Outcome Measure and Baseline Score | Mean Age and Age Range (Years) | Percentage Female
Bryant et al., 2008^123^ Low Targeted | Outcome assessors blinded RCT, PE (30) CT (30) | Five weekly sessions (6 months) | Civilian mixed (MVA, “other trauma,” physical assault, and “other accident”) | CAPS-2 total score, PE: 70.6 CT: 66.8 | 35.8^a^ | 57.8^a^
Shalev et al., 2011^122^ Medium Targeted | Outcome assessors blinded RCT, PE (63) CT (40) | 12 weekly 1.5-hour individual sessions (5 and 9 months) | Civilian mixed (Terrorist attacks, MVAs, work or other accidents) | CAPS total score, PE: 73.59 CT: 71.78 | 39.8^a^ | 52

CAPS/CAPS-2 = Clinician Administered PTSD Scale/Clinician Administered PTSD Scale-2; CT = cognitive therapy; MVA = motor vehicle accident; n = subset of sample; NR = not reported; PE = prolonged exposure therapy; RCT = randomized controlled trial

a Data not directly provided by the study authors. Data provided here are calculated by authors of this report.

Compared with PE, CT was associated with a lower incidence of PTSD at the end of treatment and 6-month followup in one study,123 but it was not significantly different at 5-month or 9-month followup in the other study122 (Table 22). In the first study,123 after adjusting for pretreatment levels, CAPS-2 total score, IES-I and IES-A did not differ significantly between CT and PE (p=NS) at the end of treatment. However, at 6-month followup, the CT group had significantly higher CAPS-2 total (32.1 vs. 49.8, p=0.03), IES-I (11.4 vs. 18.6, p=0.02), and IES-A (12.8 vs. 19.2, p=0.03) scores. In the second study,122 the PE and CT groups did not differ significantly on CAPS total score at 5-month (28.6 vs. 29.5) or at 9-month (27.5 vs. 27.9) followup, reflecting no differences in the underlying subscales of re-experiencing, avoidance, and hyperarousal at either assessment time point. Likewise, the PSS-SR total score did not differ significantly between the PE and CT groups at either the 5-month (11.0 vs. 11.6) or 9-month (10.4 vs. 9.6) follow-up assessment.

One study measured depression and anxiety at the end of treatment and 6-month followup.123 There was no significant difference between the CT and PE groups on BDI-2 scores at the end of treatment or at 6-month followup (18.9 vs. 12.1 and 20.4 vs. 12.4, p’s=NS). Compared with the PE group, the CT group exhibited significantly higher BAI scores (23.4 vs. 13.4, p=0.008) at the end of treatment only.

#### Debriefing Versus Another Form of Debriefing

One RCT met our inclusion criteria (Table 27).131 It compared two forms of CISD: CISD minus the psychoeducational component (“emotional debriefing,” n=76) and CISD minus the emotional component (“educational debriefing,” n=79) (Table 28). Additional details about this study can be found in the section on the efficacy of debriefing.

Table 28 Characteristics of the included trial of debriefing versus another form of debriefing

Study and Risk of Bias, Prevention Type | Study Design, Intervention (n) | Treatment Duration (Followup Duration) | Population and Trauma Type | Primary Outcome Measure and Baseline Score | Mean Age and Age Range (Years) | Percentage Female
Sijbrandij et al., 2006^131^ Low Universal | Unblinded RCT, Emotional debriefing (76) Educational debriefing (79) | One 45- to 60-minute individual session (2 and 6 weeks; 6 months) | Civilian Assault or Accident | SI-PTSD, Emotional debriefing: 19.9 Educational debriefing: 19.9 | 40.4^a^ (range NR) | 48.7^a^

n = subset of sample; NR = not reported; RCT = randomized controlled trial; SI-PTSD = Structured Interview for PTSD

a Data not directly provided by the study authors. Data provided here are calculated by authors of this report.

The study reported that there was no significant difference between the two forms of debriefing on incidence of PTSD or the severity of PTSD symptoms (Table 22). There was no statistically significant difference between the two forms of debriefing in severity of depression or anxiety. At 6 months, HADS-Depression change scores were −1.6 and −1.5 (p=0.23) for emotional debriefing and educational debriefing, respectively. Similar results were obtained for anxiety: HADS-Anxiety change scores were −2.4 and −2.2 (p=0.96).

#### Psychoeducation Versus Debriefing Plus Psychoeducation

One government-funded study conducted in the UK with civilian crime victims compared psychoeducation (n= 54) with debriefing combined with psychoeducation (n=52) (Table 29).129 Additional details about this study are reported in the section on efficacy of debriefing. Because of very high overall attrition (i.e., greater than 40% at 11-month followup), we considered all outcomes collected at that time point as having a high risk of bias and therefore do not report them here.

Table 29 Characteristics of the included trial of psychoeducation versus debriefing plus psychoeducation

Study and Risk of Bias, Prevention Type | Study Design, Intervention (n) | Treatment Duration (Followup Duration) | Population and Trauma Type | Primary Outcome Measure and Baseline Score | Mean Age and Age Range (Years) | Percentage Female
Rose et al., 1999^129^ Medium Universal | Unblinded RCT, Psychoeducation (52) Debriefing + psychoeducation (54) | One 1-hour individual session (6 months)^a^ | Civilian crime victims (Actual or threatened physical or sexual assault; bag snatch) | PSS-SR, Psychoeducation: 16.0 Debriefing + psychoeducation: 16.8 | 35.9 (18–76)^b^ | 24.8^b^

n = subset of sample; PSS-SR = Post-traumatic Stress Disorder Scale-Self-Report; RCT = randomized controlled trial

a Because of very high overall attrition (i.e., greater than 40% at 11-month followup) in this study of psychoeducation and debriefing plus psychoeducation,129 we considered all outcomes collected at that time point as having a high risk of bias and therefore do not report them here or in Appendix G.

b Data not directly provided by the study authors. Data provided here are calculated by authors of this report.

The incidence of PTSD did not differ significantly between the psychoeducation and debriefing combined with psychoeducation groups at 6 months (Table 22). There was no significant difference in PTSD symptom severity at 6-month followup.129 In addition, there was no significant difference in the severity of depressive symptoms between psychoeducation and debriefing combined with psychoeducation at 6-month followup (BDI, 9.8 vs. 12.1; p=NR).129

### Comparative Effectiveness: Psychological Versus Pharmacological Interventions

#### Description of Included Studies

Table 30 summarizes the characteristics of the one study meeting our inclusion criteria.122

Table 30 Characteristics of the included psychological versus pharmacological intervention trial

Study and Risk of Bias, Prevention Type | Study Design, Intervention (n) | Treatment Duration (Followup Duration) | Population and Trauma Type | Primary Outcome Measure and Baseline Score | Mean Age and Age Range (Years) | Percentage Female
Shalev et al., 2012^122^ Medium Targeted | Outcome assessors blinded RCT, PE (63) CT (40) Escitalopram^a^ (23) | PE and CT, 12 weekly 90-minute individual sessions (9 months) Escitalopram and placebo, 10 mg twice daily (9 months) | Civilian mixed (Terrorist attacks, MVAs, work or other accidents) | CAPS total score, PE: 73.59 CT: 71.78 Escitalopram: 79.83 | 39.8^b^ | 56.3^b^

CAPS = Clinician Administered PTSD Scale; CT = cognitive therapy; mg = milligrams; MVA = motor vehicle accident; n = subset of sample; PE = prolonged exposure therapy; RCT = randomized controlled trial; WL = waitlist

a Subjects in the pharmacological arm were blinded as to whether they were receiving escitalopram or placebo.

b Data not directly provided by the study authors. Data provided here are calculated by authors of this report.

This RCT was conducted in Israel with a mixed civilian trauma sample of 242 individuals admitted for emergency services. Treatment arms included PE (n=63), CT (n=40), and escitalopram (n=23). Additional details about this study are in the section on the efficacy of cognitive therapy.

### Key Points

- The evidence is insufficient to determine the comparative effectiveness of CT over an SSRI (escitalopram) to prevent PTSD or to reduce PTSD symptoms severity for civilians exposed to a variety of traumatic events (MVAs, physical assault, work-or other-related accidents, terrorist attacks).
- The evidence is insufficient to determine the comparative effectiveness of PE over an SSRI (escitalopram) to prevent PTSD or to reduce PTSD symptoms severity for civilians exposed to a variety of traumatic events (MVAs, physical assault, work-related or other accidents, terrorist attacks).

### Detailed Synthesis: Psychological Versus Pharmacological Interventions

#### CT Versus SSRI

The incidence of PTSD and the severity of PTSD symptoms were significantly higher (p=NR) in the SSRI (escitalopram) group than in the CT group at 5-month and 9-month followup (Table 22).

#### PE Versus SSRI

The incidence of PTSD and the severity of PTSD symptoms were significantly higher (p=NR) in the SSRI (escitalopram) group than in the PE group at 5-month and 9-month followup (Table 22).

### Comparative Effectiveness: Psychological Versus Emerging Interventions

No studies met inclusion criteria for this part of KQ 1.

### Comparative Effectiveness: Pharmacological Versus Pharmacological Interventions

A high-risk-of-bias RCT pilot study that otherwise met inclusion criteria compared the effectiveness of a 14-day treatment with propranolol (n=17) versus gabapentin (n=14) in patients admitted to a level 1 surgical trauma center after a severe physical injury requiring specialized, emergent care (see more detailed description in the Detailed Synthesis: Pharmacological Interventions section).47 There was no difference in effectiveness between propranolol and gabapentin as measured by PTSD severity (at 1 month, 4 months, or 8 months) or by rates of PTSD or Major Depressive Disorder at 4-month followup.

### Comparative Effectiveness: Pharmacological Versus Emerging Interventions

No studies met inclusion criteria for this part of KQ 1.

### Comparative Effectiveness: Emerging Versus Emerging Interventions

No studies met inclusion criteria for this part of KQ 1.

## KQ 2 Impact of Timing, Intensity, or Dosing

### Description of Included Studies

Two studies met eligibility criteria for KQ 2;^134,135^ Two studies that otherwise met eligibility criteria were omitted from the main data synthesis for high risk of bias.98,115 The studies covered a variety of populations, such as civil crime victims, critically ill patients, soldiers exposed to combat, and severely injured patients. Interventions included CISD, psychoeducation, psychotherapeutic treatment, trauma risk management, and pharmacological sedation. One study135 was funded by a foundation, and we could not determine the funding source for the second included study.134

### Key Points

- For robbery victims, the evidence was inconclusive whether immediate debriefing compared with delayed debriefing leads to fewer posttraumatic symptoms (insufficient SOE).
- For critically ill patients, the evidence was inconclusive whether light sedation compared with deep sedation leads to differences in posttraumatic symptoms, anxiety, and depression after hospital discharge (insufficient SOE).
- No studies of the impact of timing, intensity, or dosing on the risk of harms of interventions met our eligibility criteria.

### Detailed Synthesis

Table 31 summarizes the available evidence of the impact of timing, intensity, or dosing on the effectiveness of interventions.

Table 31 Findings and strength of evidence of the impact of timing, intensity, and dosing on the effectiveness of interventions

Population, Treatment | Impact of Timing | Impact of Intensity | Impact of Dosing | SOE^a^
Robbery victims, Debriefing (CISD)134 | Fewer posttraumatic symptoms with early vs. delayed CISD (PDS: 5.6 vs. 14.3; p<0.001); 1 trial (N=77) Lower PTSD symptom severity with early vs. delayed CISD (PDS: 6.9 vs. 33.1; p<0.001); 1 trial (N=77) | No evidence | Not applicable | Insufficient
Critically ill patients, Pharmacological sedation135 | No evidence | Not applicable | Similar incidence rates of PTSD with light and deep sedation (PCL: 10% vs. 9%, p=0.83); 1 trial (N=137) Similar rates of PTSD symptom severity ranks with light and deep sedation (IES-R and PCL: PTSD scores NR, p=0.07); 1 trial (N=137) | Insufficient

CISD = Critical Incident Stress Debriefing; IES-R = Impact of Event Scale-Revised: N = entire sample; NR = not reported; PCL = PTSD Checklist; PDS = Posttraumatic Stress Diagnostic Scale; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial; SOE = strength of evidence

a For more detailed information about the rationale for SOE grading, please refer to Appendix G.

#### Impact of Timing of Interventions

One study (Table 32) assessed the impact of timing on the effectiveness of debriefing (CISD) to prevent PTSD.134 This RCT was conducted with 77 Australian civilians who had been exposed to a first-time robbery at their place of employment. Victims were not eligible to enter the study if they had experienced physical injuries, were threatened with a gun, or had received prior treatment or prevention of stress-related symptoms. The funding source was not reported. Eligible victims were randomly assigned to immediate debriefing (within 10 hours of the robbery) or to delayed debriefing (48 hours or more after the robbery). Debriefings were conducted individually or in small groups. After 2 weeks, victims who received immediate debriefing had statistically significantly fewer symptoms on the PDS and significantly lower symptom severity than those in the delayed debriefing group (Table 31). Because of the lack of an inactive control group in this study, no conclusions about a greater efficacy of early debriefing can be drawn. It is conceivable that the difference between immediate and delayed intervention can be attributed to harmful effects of delayed debriefing relative to no beneficial effects of immediate debriefing.

Table 32 Characteristics of studies on impact of timing

Study and Risk of Bias, Prevention Type | Study Design, Intervention | Timing of Treatment After Trauma (N) | Population and Trauma Type | Primary Outcome Measure and Baseline Score | Mean Age and Age Range (Years) | Percentage Female
Campfield et al., 2001^134^ Medium Universal | Unblinded RCT, CISD | Immediate CISD: <10 hours (36) Delayed CISD: >48 hours (41) | Civilian crime victims (robbery) | PDS total score and symptom severity score Baseline: NR | 22.82^a^ (18–32) | 54.5

CISD = Critical Incident Stress Debriefing; n = subset of sample; NR = not reported; PDS = Posttraumatic Stress Diagnostic Scale; RCT = randomized controlled trial

a Data not directly provided by the study authors. Data provided here are calculated by authors of this report.

#### Impact of Intensity of Intervention

The only available evidence on the impact of the intensity on the effectiveness of interventions were two high-risk-of-bias studies, which are summarized below.

#### Impact of Dosing of Pharmacological Interventions

One study (Table 33) assessed the impact of the doses of sedating medications on symptoms of PTSD, anxiety, and depression in critically ill patients.135 This outcome assessor-blinded Swiss RCT (funded by the Swiss National Science Foundation) assigned 137 critically ill patients with endotracheal intubation to receive light sedation (i.e., sedated to be tranquil or lightly sleeping) or deep sedation (i.e., sedated to the point of being asleep but able to awaken upon physical stimulation) with midazolam and morphine. The primary endpoints were self-reported PTSD, anxiety, or depressive symptoms 4 weeks after discharge. At the 4-week followup, a similar proportion of patients in the light and deep sedation group met symptom criteria for the diagnosis of PTSD (10% vs. 9%; p=0.83) as assessed on the PTSD Checklist and the IES-R (Table 31). Likewise, patients in both treatment groups exhibited similar rates of anxiety (HADS-A: ADS-A: 12% vs. 12%) and depression (HADS-D: 8% vs. 4%), respectively. Overall, almost 20 percent of patients enrolled in this study died during the hospital stay.

Table 33 Characteristics of the study on the depth of sedation

Study and Risk of Bias | Study Design, Intervention (n) | Treatment Duration (Followup Duration) | Population and Trauma Type | Primary Outcome Measure and Baseline Score | Age Mean (Years) | Percentage Female
Treggiari et al., 2009^135^ Medium Universal | Single-blinded RCT; Light sedation (69) Deep sedation (68) | Not applicable (4 weeks postdischarge) | Civilian medical; Mechanical ventilation | IES-R and PCL: Not applicable | 61.4^a^ | 23.5^a^

IES-R = Impact of Event Scale-Revised; n = subset of sample; PCL = PTSD Checklist; RCT = randomized controlled trial

a Data not directly provided by the study authors. Data provided here are calculated by authors of this report.

### High-Risk-of-Bias Studies

Two studies rated high risk of bias otherwise met our eligibility criteria.98,115 Because of the lack of other evidence for this key question, we briefly summarize characteristics and main findings of these studies.

#### Impact of Intensity of Intervention

A German RCT (N=113) compared the effectiveness of inpatient psychotherapy in severely injured patients with a combination of inpatient and continued outpatient psychotherapy.115 After 1 year of followup of completers only, the long-term therapy group had numerically fewer posttraumatic, depressive, and anxiety symptoms than patients receiving inpatient psychotherapeutic treatment only. Differences did not reach statistical significance. Only 41 percent of all randomized patients completed the follow-up assessments.

A British nonrandomized parallel-group comparison trial compared Trauma Risk Management (TRiM) in two different groups of 180 males (Army infantry and Marine commandos) at different stages of implementation (TriM naïve and TriM experienced).98 Subjects in the TRiM-experienced group reported lower levels of psychological distress than subjects in the TRiM-naïve group. Differences did not reach statistical significance.

## KQ 3 Subgroup Analyses

### Description of Included Studies

Eight studies met eligibility criteria for KQ 3;^27,107,120,126,128,129,131,134^ Two of the eight were rated high risk of bias and omitted from the main data synthesis, but they are discussed separately below.27,107 The six studies with low131 or medium risk of bias involved survivors of a variety of trauma types: medical illness (breast cancer), violent crime, intentional and unintentional injuries, and combat. Interventions included psychological debriefing, emotional debriefing, psychoeducation, CISD, PE, a British adaptation of Battlemind training, and a self-help workbook. Three studies were funded by national government sources128,129,131 and one by a private foundation;120 two did not identify their funding source.126,134

### Key Points

- For violent crime victims, the effect of early psychological interventions (debriefing, immediate vs. delayed debriefing) on PTSD symptoms did not differ between men and women at 2 weeks and 6 months (low SOE).129,134
- For violent crime victims, the effect of a debriefing intervention on depressive symptoms did not differ between men and women at 6 months (insufficient SOE).129
- For women with newly diagnosed breast cancer and survivors of civilian assault or accident, there were inconsistent findings on whether baseline severity of PTSD symptoms modified the effect of debriefing and a self-help workbook on PTSD symptoms (insufficient SOE).120,131
- For victims of violent crime, the effect of a debriefing intervention on PTSD symptoms did not differ between those with or without previous depression or a history of child abuse (insufficient SOE).129
- For United Kingdom military service members after combat deployment, the effect of Battlemind training on PTSD symptoms did not differ by the severity of combat exposure (insufficient SOE).126
- For survivors of mixed civilian trauma, PE was effective in reducing PTSD symptoms among survivors of sexual assault but not physical assault or motor vehicle collisions (insufficient SOE).128
- No study that met our inclusion criteria conducted subgroup analyses by ethnic or racial groups.

### Detailed Synthesis

Table 34 summarizes the main findings on subgroups.

Table 34 Summary of evidence about subgroups

Subgroup; Interventions | PTSD Symptoms | Depression Symptoms | Quality of Life | SOE^a^
Demographic groups: sex; CBT, CISD | Sex did not modify the effect of early interventions; 2 trials (N=157; N=77)129,134 | Sex did not modify the effect of early interventions; 1 trial (N=157)129 | No evidence | PTSD symptoms; Low for no effect of sex Depression symptoms or quality of life: insufficient
Type of trauma; PE | Modified PE reduced PTSD symptoms among survivors of sexual, but not physical, assault and not among MVA survivors; 1 trial (N=137)128 | No evidence | No evidence | Insufficient
Psychiatric diagnosis: previous depression; Debriefing | Previous depression did not modify effect of debriefing; 1 trial (N=157)129 | Previous depression did not modify effect of debriefing; 1 trial (N=157)129 | No evidence | Insufficient
History of child abuse^b^; Debriefing | History of child abuse did not modify effect of debriefing; 1 trial (N=157)129 | History of child abuse did not modify the effect of debriefing; 1 trial (N=157)129 | No evidence | Insufficient
Severity of exposure to trauma^b^; Battlemind training, standard postdeployment briefing | Severity of combat exposure did not modify the effect of Battlemind training; 1 trial (n=2, 443)126 | No evidence | No evidence | Insufficient
Baseline severity of distress^b^; Debriefing, self-help workbook | Inconsistent findings; 2 trials (N=49; N=236);120,131 one reported that high baseline arousal symptoms increased PTSD symptoms among those randomized to debriefing while the other reported that a self-help workbook reduced PTSD symptoms to a greater extent in those with high baseline PTSD symptom severity | No evidence | No evidence | Insufficient

CBT = cognitive behavioral therapy; CISD = Critical Incident Stress Debriefing; MVA = motor vehicle accident; N = entire sample; n = subset of sample; PE= prolonged exposure therapy; PTSD = posttraumatic stress disorder; SOE = strength of evidence

a For more detailed information about the rationale for SOE grading, please refer to Appendix G.

b Personal risk factor for PTSD.

Of the six studies that were rated as low or medium risk of bias, two reported subgroup analyses by demographic groups (sex),129,134 one by type of trauma,128 one by severity of trauma exposure,126 one by history of depression,129 one by history of child abuse,129 and two by severity of baseline distress120,131 (Table 34). The number of subgroup analyses conducted ranged from one134 to nine.129

All studies except one128 used a test of interaction (intervention by group or intervention by time by group) for their subgroup analyses. Two studies120,129 reported that the subgroup analyses were not prespecified, and four studies126,128,131,134 did not state whether the subgroup analyses were prespecified or post hoc. Only one of the six studies adjusted for multiple comparisons128 or reported the magnitude of the effect within levels (categories) of the subgroups being analyzed. None reported confidence intervals around estimated effects.

### Subgroups by Demographic Characteristics

#### Sex

Two trials evaluated whether sex modified the effect of early psychological interventions on PTSD symptoms; one trial (N=157) tested debriefing versus psychoeducation among victims of violent crime,129 and the other (N=77) tested immediate versus delayed debriefing for robbery victims (Table 35).134 These two trials reported consistent findings that the effect of early psychological interventions in reducing PTSD symptoms did not differ between men and women (Table 33).134 However, neither study reported the magnitude of the estimated effect (i.e., the coefficient of the interaction term) or the precision of the estimate.

Table 35 Characteristics of included trials for subgroup analyses

Study and Risk of Bias Subgroups Analyzed | Study Design, Intervention (n) | Treatment Duration (Followup Duration) | Population and Trauma Type | Primary Outcome Measure and Baseline Score | Mean Age and Age Range (Years) | Percentage Female
Beatty et al., 2010^120^ Medium Severity of baseline distress (high vs. low)^a^ | Unblinded RCT, SHB (25) Information only (24) | NR (3 and 6 months) | Women newly diagnosed with breast cancer (within previous month) | PSS-SR: 10.76 (pooled for both groups) | 55.2 (range NR) | 100
Campfield et al., 2001^134^ Medium Sex | Unblinded RCT, <10 hour (36) >48 hour (41) | One session, median duration 1–2 hours (2 and 4 days; 2 weeks) | Crime victims (robbery) | PDS total score, NR | 22.82^b^ (18–32) | 55
Mulligan et al., 2011^126^ Medium Severity of combat exposure | Unblinded RCT, Battlemind training (797) Standard postdeployment briefing (819) | One large group session lasting < 1 hour (4 to 6 months) | UK military service members; combat trauma | PCL-C, Battlemind: 21 Standard briefing: 20 | NR | 1.7^b^
Rose et al., 1999^129^ Medium Sex; previous depression, history of child abuse | Unblinded RCT, Debriefing (54) Psycho-education (52) Assessment (51) | One individual session of 1 hour (6 months)^c^ | Crime victims (actual or threatened physical or sexual assault; bag snatch) | IES, Debriefing: 28.5 Psychoeducation: 24.2 Assessment: 28.0 PSS-SR, Debrief: 16.8 Psychoeducation: 16.0 Assessment: 15.6 | 35.9^b^ (18–76) | 24.8c
Rothbaum et al., 2012^128^ Medium Type of trauma | Unblinded RCT, Modified (early) PE (69) Assessment only (68) | Three individual 1-hour sessions (1 and 3 months) | Physical and sexual assault, or MVA | PSS-I, NR | 31.5 (range NR) | 65
Sijbrandij et al., 2006^131^ Low Severity of baseline distress, based on presence of 3 PTSD symptom clusters at baseline^d^ | Unblinded RCT, Emotional debriefing (76) Educational debriefing (79) No debriefing (81) | One individual, 45- to 60-minute session (2 and 6 weeks; 6 months) | Assault or accident | SI-PTSD, Emotional debriefing: 19.9 Educational debriefing: 19.9 No debriefing: 17.7 | 40.4^b^ (range NR) | 48.7^c^

DSM-IV = Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition; IES = Impact of Event Scale; MVA = motor vehicle accident; n = subset of sample; NR = not reported; PCL-C = PTSD Checklist, Civilian version; PDS = Posttraumatic Stress Diagnostic Scale; PSS-I = Posttraumatic Stress Diagnostic Scale-Interview version; PSS-SR = Posttraumatic Stress Diagnostic Scale-Self Report version; PE = prolonged exposure therapy; PSS-I = PTSD Symptom Scale-Interview version; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial; SHB = self-help book; SI-PTSD = Structured Interview for PTSD; UK = United Kingdom

a Baseline distress was based on dichotomous (above median vs. below median) baseline score for each outcome. For example, for PTSD, baseline distress is based on dichotomized PTSD score at baseline.

b Data not directly provided by the study authors. Data provided here are calculated by authors of this report.

c Because of very high overall attrition (i.e., greater than 40% at 11-month followup) in this study of debriefing and psychoeducation, we considered all outcomes collected at that time point as having a high risk of bias and therefore do not report them here or in Appendix G.129

d Presence of each PTSD symptom cluster was based on DSM-IV criteria. For reexperiencing, one of five DSM-IV criteria at baseline was required; for arousal, two of five were required; and for avoidance/numbing, three of seven were required. Severity was defined as high vs. low for each of the three PTSD symptom clusters (reexperiencing, arousal, and avoidance), where high is defined as meeting DSM-IV criteria for that cluster.

One study129 reported no differences between men and women in the effects of early intervention on depressive symptoms. Based on this single study, we concluded that the evidence was insufficient to determine if there are differences between men and women in reducing depressive symptoms. The evidence was insufficient for all other outcomes.

#### Age and Ethnic and Racial Groups

No study addressed effectiveness of interventions in subgroups defined by age, race, or ethnicity.

#### Subgroups by Type of Trauma

One study128 reported that type of trauma modified the effect of modified PE, initiated less than 1 day after trauma, on PTSD symptoms. Survivors of sexual assault, but not survivors of physical assault or MVAs, had clinically and statistically significant declines in PTSD symptoms compared with those in the assessment-only group (Table 34). An overall group by trauma type by time interaction effect was not assessed. Because this was the only study that reported a subgroup analysis by trauma type, there is insufficient evidence that the effect of modified PE on PTSD symptoms was different among survivors of sexual assault and survivors of other trauma types.

#### Subgroups by Psychiatric Comorbidity

##### Previous Depression

One study reported that previous depression did not modify the effect of the debriefing for PTSD symptoms or depression symptoms (Table 34).129 For their models for PTSD symptoms and depression symptoms as outcomes, they did not report either estimated magnitude of effect for the interaction terms (intervention-by-time-by-previous depression) or precision of those estimates. The evidence was insufficient to determine the impact of previous depression on the incidence of PTSD or PTSD symptom severity.

##### Previous Anxiety Disorder Other Than PTSD

No study addressed effectiveness of interventions in subgroups defined by previous anxiety disorder other than PTSD.

#### Personal Risk Factors for Developing PTSD

##### History of Child Abuse

Rose and colleagues reported that history of child abuse did not modify the effect of debriefing for PTSD symptoms or symptoms of depression (Table 34).129 The authors did not report the estimated magnitude of effects for the intervention by time or by history of child abuse interaction terms or the precision of their estimates.

##### Severity of Trauma Exposure

One study126 reported that the severity of combat exposure, entered into regression models as either linear or quadratic interaction terms, did not modify the effect of Battlemind training that was adapted for use in the UK (Table 34). The magnitude of interaction effects and their precision were not reported. The evidence was insufficient to conclude whether there are differences in the effect of Battlemind training across varying levels of severity of trauma exposure.

##### Baseline Severity of Distress

Two trials (one low risk of bias) performed subgroup analyses on baseline severity of distress.120,131 Sijbrandij and colleagues evaluated the impact of debriefing on PTSD symptoms, depressive symptoms, and anxiety symptoms, among survivors of a single traumatic event, of any kind, that occurred 2 weeks before study entry.131 They reported a significant (p=0.005) interaction for intervention by time by level of baseline arousal symptoms (high versus low): at 6 weeks, individuals in the debriefing group had increased PTSD symptoms compared with controls in the high baseline hyperarousal group but not in the low baseline hyperarousal group (Table 34). The authors did not report magnitude of the effect or precision. Beatty and colleagues evaluated the impact of a psychoeducational SHB on PTSD symptoms, among women with a recent diagnosis of breast cancer.120 For PTSD symptoms, the interaction for intervention by baseline PTSD severity was significant (p<0.01) at 3 months. Compared with controls, the women with high baseline symptoms who received the SHB experienced decreased PTSD symptoms to a greater extent than did women with low baseline PTSD symptoms. The magnitude of the interaction effect and its precision were not reported. The discrepant findings between these two trials may arise from differences in any or all of the following: (1) composition of the sample (including type of trauma and percentage of women), (2) intervention (debriefing vs. workbook), (3) timing of followup assessment, (4) definition of baseline distress, or (5) measure of PTSD symptoms.

### High-Risk-of-Bias Studies

The two studies omitted from the main data synthesis for high risk of bias are briefly described here.27,107

#### Exposure to Combat-Related Events

Adler and colleagues randomly assigned, at the platoon level, U.S. soldiers who had been deployed to Iraq to stress education (n=527), Battlemind debriefing (n=582), small group Battlemind training (n=562), and large group Battlemind training (n=616).27 Attrition was very high (53.9%) at the follow-up survey at 4 months, primarily because of Army reassignment of personnel; the only difference between the baseline and follow-up samples was a higher loss to followup among noncommissioned officers than junior-ranking soldiers. They reported that the interaction between intervention and exposure to combat-related events (entered as a quadratic term) was strong (with PTSD symptoms as the outcome). Among soldiers with low levels of combat exposure, PTSD symptoms did not differ for soldiers randomized to any of the four interventions. However, among soldiers with very high levels of combat exposure, all three of the active interventions resulted in substantially lower PTSD symptoms at 4 months than stress education.

#### Sex

Krauseneck and colleagues,107 previously described in KQ 1, conducted a prospective cohort study of the effect of beta-adrenergic blockade with metoprolol on traumatic memories and PTSD symptoms among cardiac surgery patients 1 day before surgery and at 1 week and 6 months after surgery. Baseline and treatment medical characteristics (such as duration of surgery) did not differ between those who did or did not receive metoprolol. The authors did not report on psychological characteristics that might confound the association between beta-blockers and PTSD symptoms upon followup. For PTSD symptoms, they reported a significant interaction of treatment (metoprolol vs. no metoprolol) by time by sex: at 6 months, women treated with metoprolol had lower PTSD symptoms than women not treated with metoprolol, whereas men treated with metoprolol had the same PTSD symptoms as men not treated with metoprolol.

## KQ 4 Risks of Harms

### Description of Included Studies

Overall, we identified four studies assessing harms for early interventions to prevent PTSD.84,93,131,135 Two otherwise eligible studies were rated high risk of bias and omitted from the main data synthesis but are discussed below.84,93 The two included studies involved civilian medical trauma, assault or accident,131 and mechanical ventilation.135 Interventions for these two studies involved different forms of psychological debriefing (emotional or educational)131 and use of light versus deep sedation.135

### Key Points

- For patients with early hyperarousal, the evidence was inconclusive whether emotional debriefing leads to increased PTSD symptoms compared with no debriefing (insufficient SOE).
- For critically ill patients, the evidence was inconclusive whether there was a difference in mortality between light and deep sedation groups (insufficient SOE).

### Detailed Synthesis

Table 36 summarizes the available evidence of the absolute and comparative risks of harms from early interventions to prevent PTSD for the two studies with either low or medium risk of bias. For absolute risk, the SOE was determined to be insufficient because the data are from a single study and results are mixed across assessment points. For comparative risk, the SOE was found to be insufficient because the data are from a relatively small sample from a single study.

Table 36 Findings and strength of evidence about harms

Intervention, Population | Outcome | Results | SOE^a^
Emotional debriefing vs. educational debriefing vs. no debriefing, Civilian medical (psychological trauma)131 | Absolute risk: PTSD severity (in subgroup with hyperarousal) | For patients with early hyperarousal, the evidence was inconclusive whether emotional debriefing leads to increased PTSD symptoms compared with no debriefing; 1 trial (N=236). | Insufficient
Light sedation vs. deep sedation), Mechanical ventilation135 | Comparative risk: Mortality | The evidence was inconclusive whether there was a difference in mortality between light and deep sedation groups; 1 trial (N=137). | Insufficient
Light sedation vs. deep sedation), Mechanical ventilation135 | Comparative risk: Incidence of adverse events | The evidence was inconclusive whether there was a difference in the incidence of organ dysfunction, hypertension, or tachycardia between light and deep sedation groups; 1 trial (N=137). | Insufficient

N = entire sample; PTSD = posttraumatic stress disorder; SOE = strength of evidence

a For more detailed information about the rationale for SOE grading, please refer to Appendix G.

One trial provided limited data about the absolute risk of early interventions to prevent the onset of PTSD,131 while a second study provided limited data about the comparative risks of such interventions.135 Table 37 summarizes the characteristics of these studies.

Table 37 Characteristics of the included studies evaluating risk of harms from interventions to prevent PTSD

Study and Risk of Bias, Prevention Type | Study Design, Intervention (n) | Treatment Duration (Followup Duration) | Population and Trauma Type | Primary Outcome Measure and Baseline Score | Mean Age and Age Range (Years) | Percentage Female
Sijbrandij et al., 2006^131^ Low Universal | Unblinded RCT, Emotional debriefing (76) Educational debriefing (79) No debriefing (81) | One 45- to 60-minute session (6 months) | Civilian medical, psychological trauma | SI-PTSD Emotional debriefing: 19.9 Educational debriefing: 19.9; Control 17.7 | 40.4^a^ (range NR) | 48.7^a^
Treggiari et al., 2009^135^ Medium Universal | Single-blinded RCT; Light sedation (69) Deep sedation (68) | 7 days (1 month) | Civilian medical, mechanical ventilation | IES-R & PCL: not applicable | 61.4^a^ (range NR) | 23.5^a^

IES-R = Impact of Event Scale-Revised; n = subset of sample; NR = not reported; PCL = PTSD Checklist; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial; SI-PTSD = Structured Interview for PTSD

a Data not directly provided by the study authors. Data provided here are calculated by authors of this report.

One trial (low risk of bias), previously described in KQ 1, was conducted in 236 adult Dutch civilians who had experienced psychological trauma (Table 37).131 Eligible patients were randomly assigned to one of three groups: (1) emotional debriefing, (2) educational debriefing, or no debriefing within 2 weeks of the trauma. In a subgroup analysis, the authors reported that for participants with early hyperarousal, those receiving emotional debriefing experienced higher PTSD scores than the control group at 6 weeks (test for interaction, p=0.005) (Table 36). This difference was not found at the two other assessment points (2 weeks or 6 months), and no other differences between the groups were noted.

A second study (medium risk of bias), previously described in KQ 2, provided data relevant to comparative risks (Table 37).135 In this randomized open label study of 137 adult Swiss patients being placed on mechanical ventilation for at least 12 hours, patients were randomly assigned to receive either light or deep sedation. There were no differences in mortality (14% ICU deaths in each arm; 18% vs. 17% death during stay hospital stay, p=0.65) or in the incidence of adverse events (as measured by organ dysfunction, hypertension, and tachycardia) (Table 36).

### High-Risk-of-Bias Studies

Two studies otherwise meeting our eligibility criteria were omitted for high risk of bias.84,93

#### Critical Incident Stress Debriefing

The other study was a nonrandomized retrospective cohort study in the Netherlands with high potential for selection bias; it compared the effectiveness of one session of debriefing (n=46) with no debriefing (n=59) for police officer first responders to a large plane crash.93 At 18-month followup, but not at 8-month followup, the officers who had been debriefed were significantly more likely to exhibit disaster-related hyperarousal symptoms than those not debriefed.

#### Critical Incident Stress Debriefing and Stress Management

One tested the comparative effectiveness of CISD versus a stress management class versus a group that received no intervention but completed assessment tools at the follow-up periods.84 More information about this study’s characteristics is available above in the KQ 3 (Subgroup Analyses) section. At 4-month followup, CISD was not more distressing or arousing than a stress management class or no intervention.