# References

1 American Psychiatric Association. Diagnostic and statistical manual of mental disorders: DSM-IV-TR. American Psychiatric Publishing, Inc. 2000.
2 Brady KT, Killeen TK, Brewerton T, et al. Comorbidity of psychiatric disorders and posttraumatic stress disorder. J Clin Psychiatry. 2000;61(Suppl 7):22-32. [pmid: 10795606].
3 Resnick HS, Kilpatrick DG, Dansky BS, et al. Prevalence of civilian trauma and posttraumatic stress disorder in a representative national sample of women. J Consult Clin Psychol. Dec. 1993;61(6):984-91. [pmid: 8113499].
4 Kessler RC, Sonnega A, Bromet E, et al. Posttraumatic stress disorder in the National Comorbidity Survey. Arch Gen Psychiatry. Dec. 1995;52(12):1048-60. [pmid: 7492257].
5 Norris F, Sloane LB. The epidemiology of trauma and PTSD. Friedman MJ, Keane TM, Resick PA, editors. Handbook of PTSD: Science and practice. New York, NY. Guilford Press. 2007:78-98.
6 Vrana S, Lauterbach D. Prevalence of traumatic events and post-traumatic psychological symptoms in a nonclinical sample of college students. J Trauma Stress. Apr. 1994;7(2):289-302. [pmid: 8012748].
7 Breslau N, Davis GC, Andreski P, et al. Traumatic events and posttraumatic stress disorder in an urban population of young adults. Arch Gen Psychiatry. Mar. 1991;48(3):216-22. [pmid: 1996917].
8 Norris FH. Epidemiology of trauma: frequency and impact of different potentially traumatic events on different demographic groups. J Consult Clin Psychol. Jun. 1992;60(3):409-18. [pmid: 1619095].
9 Brewin CR, Dalgleish T, Joseph S. A dual representation theory of posttraumatic stress disorder. Psychol Rev. Oct. 1996;103(4):670-86. [pmid: 8888651].
10 Ozer EJ, Best SR, Lipsey TL, et al. Predictors of posttraumatic stress disorder and symptoms in adults: a meta-analysis. Psychol Bull. Jan. 2003;129(1):52-73. [pmid: 12555794].
11 Bryant RA, Harvey AG, Guthrie RM, et al. A prospective study of psychophysiological arousal, acute stress disorder, and posttraumatic stress disorder. J Abnorm Psychol. May. 2000;109(2):341-4. [pmid: 10895573].
12 Pitman RK. Post-traumatic stress disorder, hormones, and memory. Biol Psychiatry. Jul. 1989;26(3):221-3. [pmid: 2545287].
13 McCleery JM, Harvey AG. Integration of psychological and biological approaches to trauma memory: implications for pharmacological prevention of PTSD. J Trauma Stress. Dec. 2004;17(6):485-96. [pmid: 15730067].
14 Bryant RA. Early predictors of posttraumatic stress disorder. Biol Psychiatry. May. 1. 2003;53(9):789-95. [pmid: 12725971].
15 Shalev AY. Treating survivors in the immediate aftermath of traumatic events. Yehuda R, editor. Treating trauma survivors with PTSD. 1st ed. Washington, DC. American Psychiatric Publishing, Inc. 2002:157-88.
16 Fletcher S, Creamer M, Forbes D. Preventing post traumatic stress disorder: are drugs the answer?. Aust N Z J Psychiatry. Dec. 2010;44(12):1064-71. [pmid: 21070102].
17 National Comorbidity Survey. NCS-R appendix tables: Table 1. Lifetime prevalence of DSM-IV/WMH-CIDI disorders by sex and cohort. Table 2. Twelve-month prevalence of DSM-IV/WMH-CIDI disorders by sex and cohort. 2007. www.hcp.med.harvard.edu/ncs/publications.php.
18 Kessler RC, Berglund P, Demler O, et al. Lifetime prevalence and age-of-onset distributions of DSM-IV disorders in the National Comorbidity Survey Replication. Arch Gen Psychiatry. Jun. 2005;62(6):593-602. [pmid: 15939837].
19 National Institutes of Mental Health. The numbers count: Mental disorders in America Year not provided. www.nimh.nih.gov/health/publications/the-numbers-count-mental-disorders-in-america/index.shtml. Accessed October 12, 2012.
20 Dohrenwend BP, Turner JB, Turse NA, et al. The psychological risks of Vietnam for U.S. veterans: a revisit with new data and methods. Science. Aug. 18. 2006;313(5789):979-82. [pmid: 16917066].
21 Seal KH, Bertenthal D, Miner CR, et al. Bringing the war back home: mental health disorders among 103,788 US veterans returning from Iraq and Afghanistan seen at Department of Veterans Affairs facilities. Arch Intern Med. Mar. 12. 2007;167(5):476-82. [pmid: 17353495].
22 Tanielian T, Jaycox LH, editors. Invisible wounds of war: psychological and cognitive injuries, their consequences, and services to assist recovery. Santa Monica, CA. RAND Corporation. 2008.
23 Institute of Medicine. Treatment of PTSD: assessment of the evidence. Washington, DC. National Academies Press. 2008.
24 Wood DP, Murphy J, McLay R, et al. Cost effectiveness of virtual reality graded exposure therapy with physiological monitoring for the treatment of combat related post traumatic stress disorder. Stud Health Technol Inform. 2009;144:223-9. [pmid: 19592768].
25 Kessler RC. Posttraumatic stress disorder: the burden to the individual and to society. J Clin Psychiatry. Suppl 5. 2000;61:4-12. discussion 3–4. [pmid: 10761674].
26 Feldner MT, Monson CM, Friedman MJ. A critical analysis of approaches to targeted PTSD prevention: current status and theoretically derived future directions. Behav Modif. Jan. 2007;31(1):80-116. [pmid: 17179532].
27 Adler AB, Bliese PD, McGurk D, et al. Battlemind debriefing and battlemind training as early interventions with soldiers returning from iraq: Randomization by platoon. J Consult Clin Psychol. Oct. 2009;77(5):928-40. [pmid: 19803572].
28 Foa EB, Keane TM, Friedman MJ, et al., editors. Effective treatments for PTSD: Practice guidelines from the International Society for Traumatic Stress Studies. 2nd ed. New York. Guilford Press. 2009.
29 Sones HM, Thorp SR, Raskind M. Prevention of posttraumatic stress disorder. Psychiatr Clin North Am. Mar. 2011;34(1):79-94. [pmid: 21333841].
30 Resick PA, Schnicke MK. Cognitive processing therapy for sexual assault victims. J Consult Clin Psychol. Oct. 1992;60(5):748-56. [pmid: 1401390].
31 Mitchell JT. When disaster strikes...the critical incident stress debriefing process. JEMS. Jan. 1983;8(1):36-9. [pmid: 10258348].
32 Barboza K. Critical incident stress debriefing (CISD): Efficacy in question. NSPB. 2005;3(2):49-70.
33 Boudreaux ED, McCabe B. Emergency psychiatry: critical incident stress management: I. Interventions and effectiveness. Psychiatr Serv. Sep. 2000;51(9):1095-7. [pmid: 10970908].
34 Gray MJ, Maguen S, Litz BT. Acute psychological impact of disaster and large-scale tauma: limitations of traditional interventions and future practice recommendations. Prehosp Disaster Med. Jan-Mar. 2004;19(1):64-72. [pmid: 15453161].
35 Mitchell JT, Everly GS, Mitchell DJ. The hidden victims of disasters and vehicular accidents: The problem and recommended solutions. Hickling EJ, Blanchard EB, editors. The international handbook of road traffic accidents and psychological trauma: Current understanding, treatment and law. New York, NY. Elsevier Science. 1999;30:141-53.
36 van Emmerik AA, Kamphuis JH, Hulsbosch AM, et al. Single session debriefing after psychological trauma: a meta-analysis. Lancet. Sep. 7. 2002;360(9335):766-71. [pmid: 12241834].
37 Litz BT, Gray MJ, Bryant RA, et al. Early intervention for trauma: Current status and future directions. Clin Psychol Sci Prac. 2002;9(2):112-34.
38 Rose S, Bisson JI, Churchill R, et al. Psychological debriefing for preventing post traumatic stress disorder (PTSD). Cochrane Database of Systematic Reviews. [Online version]. 2009;(2). Art. No.: CD000560.
39 Friedman MJ. Post traumatic stress disorder: The latest assessment and treatment strategies. 3rd ed. Kansas City, MO. Compact Clinicals. 2003.
40 Stuart S. Interpersonal Psychotherapy: A Guide to the Basics. Psychiatric Annals. 2006;36(8):542-50.
41 Ruzek JI, Brymer MJ, Jacobs AK, et al. Psychological first aid. JMHC. 2007;29(1):17-49.
42 Brymer M, Jacobs A, Layne C, et al. Psychological first aid: Field operations guide. 2nd ed. 2006.
43 Bajor LA, Ticlea AN, Osser DN. The Psychopharmacology Algorithm Project at the Harvard South Shore Program: an update on posttraumatic stress disorder. Harv Rev Psychiatry. Sep–Oct. 2011;19(5):240-58. [pmid: 21916826].
44 Boehnlein JK, Kinzie JD. Pharmacologic reduction of CNS noradrenergic activity in PTSD: the case for clonidine and prazosin. J Psychiatr Pract. Mar. 2007;13(2):72-8. [pmid: 17414682].
45 Ravindran LN, Stein MB. Pharmacotherapy of post-traumatic stress disorder. Curr Top Behav Neurosci. 2010;2:505-25. [pmid: 21309124].
46 Berigan TR. Gabapentin in the Treatment of Posttraumatic Stress Disorder. Prim Care Companion J Clin Psychiatry. Jun. 2000;2(3):105. [pmid: 15014658].
47 Stein MB, Kerridge C, Dimsdale JE, et al. Pharmacotherapy to prevent PTSD: Results from a randomized controlled proof-of-concept trial in physically injured patients. J Trauma Stress. Dec. 2007;20(6):923-32. [pmid: 18157888].
48 Nutt DJ. The psychobiology of posttraumatic stress disorder. J Clin Psychiatry. Suppl 5. 2000;61:24-9. discussion 30–2. [pmid: 10761676].
49 Braun P, Greenberg D, Dasberg H, et al. Core symptoms of posttraumatic stress disorder unimproved by alprazolam treatment. J Clin Psychiatry. Jun. 1990;51(6):236-8. [pmid: 2189869].
50 Southwick SM, Davis LL, Aikins DE, et al. Neurobiological alterations associated with PTSD. Friedman MJ, Keane TM, Resick PA, editors. Handbook of PTSD: Science and practice. New York, NY. Guilford Press. 2007:166-89.
51 Pitman RK, Sanders KM, Zusman RM, et al. Pilot study of secondary prevention of posttraumatic stress disorder with propranolol. Biol Psychiatry. Jan. 15. 2002;51(2):189-92. [pmid: 11822998].
52 Hoge EA, Worthington JJ, Nagurney JT, et al. Effect of acute posttrauma propranolol on PTSD outcome and physiological responses during script-driven imagery. CNS Neurosci Ther. 2011. Jan. 10. [pmid: 22070357].
53 Reist C, Duffy JG, Fujimoto K, et al. beta-Adrenergic blockade and emotional memory in PTSD. Int J Neuropsychopharmacol. Dec. 2001;4(4):377-83. [pmid: 11806863].
54 Albucher RC, Liberzon I. Psychopharmacological treatment in PTSD: a critical review. J Psychiatr Res. Nov–Dec. 2002;36(6):355-67. [pmid: 12393304].
55 Bryant RA, Creamer M, O’Donnell M, et al. A study of the protective function of acute morphine administration on subsequent posttraumatic stress disorder. Biol Psychiatry. 2009;65(5):438-40. [pmid: 19058787].
56 Holbrook TL, Galarneau MR, Dye JL, et al. Morphine Use after Combat Injury in Iraq and Post-Traumatic Stress Disorder. N Engl J Med. Jan. 2010;362(2):110-7. [pmid: 20071700].
57 Zatzick DF, Rivara FP, Nathens AB, et al. A nationwide US study of post-traumatic stress after hospitalization for physical injury. Psychol Med. Oct. 2007;37(10):1469-80. [pmid: 17559704].
58 Norman SB, Stein MB, Dimsdale JE, et al. Pain in the aftermath of trauma is a risk factor for post-traumatic stress disorder. Psychol Med. Apr. 2008;38(4):533-42. [pmid: 17825121].
59 McGaugh JL, Introini-Collison IB, Nagahara AH. Memory-enhancing effects of posttraining naloxone: involvement of beta-noradrenergic influences in the amygdaloid complex. Brain Res. Apr. 12. 1988;446(1):37-49. [pmid: 2836028].
60 McGaugh JL. Memory consolidation and the amygdala: a systems perspective. Trends Neurosci. Sep. 2002;25(9):456. [pmid: 12183206].
61 Asnis GM, Kohn SR, Henderson M, et al. SSRIs versus non-SSRIs in post-traumatic stress disorder: an update with recommendations. Drugs. 2004;64(4):383-404. [pmid: 14969574].
62 Pollack MH, Hoge EA, Worthington JJ, et al. Eszopiclone for the treatment of posttraumatic stress disorder and associated insomnia: a randomized, double-blind, placebo-controlled trial. J Clin Psychiatry. Jul. 2011;72(7):892-7. [pmid: 21367352].
63 Pitman RK, van der Kolk BA, Orr SP, et al. Naloxone-reversible analgesic response to combat-related stimuli in posttraumatic stress disorder. A pilot study. Arch Gen Psychiatry. Jun. 1990;47(6):541-4. [pmid: 2350206].
64 Bills LJ, Kreisler K. Treatment of flashbacks with naltrexone. Am J Psychiatry. Sep. 1993;150(9):1430. [pmid: 8352362].
65 Glover H. A preliminary trial of nalmefene for the treatment of emotional numbing in combat veterans with post-traumatic stress disorder. Isr J Psychiatry Relat Sci. 1993;30(4):255-63. [pmid: 8163362].
66 Rosenkranz JA, Grace AA. Cellular mechanisms of infralimbic and prelimbic prefrontal cortical inhibition and dopaminergic modulation of basolateral amygdala neurons in vivo. J Neurosci. Jan. 1. 2002;22(1):324-37. [pmid: 11756516].
67 Raskind MA. Pharmacologic treatment of PTSD. Shiromani PJ, editor. Post-traumatic stress disorder: Basic science and clinical practice. Humana Press. 2009:337-61.
68 Friedman MJ, Marmar CR, Baker DG, et al. Randomized, double-blind comparison of sertraline and placebo for posttraumatic stress disorder in a Department of Veterans Affairs setting. J Clin Psychiatry. May. 2007;68(5):711-20. [pmid: 17503980].
69 Matar MA, Cohen H, Kaplan Z, et al. The effect of early poststressor intervention with sertraline on behavioral responses in an animal model of post-traumatic stress disorder. Neuropsychopharmacology. Dec. 2006;31(12):2610-8. [pmid: 16794565].
70 Davidson J, Rothbaum BO, Tucker P, et al. Venlafaxine extended release in posttraumatic stress disorder: a sertraline- and placebo-controlled study. J Clin Psychopharmacol. Jun. 2006;26(3):259-67. [pmid: 16702890].
71 Davidson J, Baldwin D, Stein DJ, et al. Treatment of posttraumatic stress disorder with venlafaxine extended release: a 6-month randomized controlled trial. Arch Gen Psychiatry. Oct. 2006;63(10):1158-65. [pmid: 17015818].
72 National Institutes of Health. What is complementary and alternative medicine? D347. Bethesda, MD. 2008. http://nccam.nih.gov/health/whatiscam/D347.pdf.
73 Woltmann E, Grogan-Kaylor A, Perron B, et al. Comparative effectiveness of collaborative chronic care models for mental health conditions across primary, specialty, and behavioral health care settings: systematic review and meta-analysis. Am J Psychiatry. Aug. 1. 2012;169(8):790-804. [pmid: 22772364].
74 Institute of Medicine. Treatment for Posttraumatic Stress Disorder in Military and Veteran Populations: Initial Assessment. The National Academies Press. 2012.
75 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. J Clin Epidemiol. Oct. 2009;62(10):1006-12. [pmid: 19631508].
76 Agency for Healthcare Research and Quality. Methods guide for effectiveness and comparative effectiveness reviews. AHRQ. Rockville, MD. August. 2011. Chapters available at www.effectivehealthcare.ahrq.gov.
77 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. Agency for Healthcare Research and Quality Methods Guide for Comparative Effectiveness Reviews. Rockville, MC. Quality AfHRa. March. 2012. www.effectivehealthcare.ahrq.gov/. AHRQ Publication No. 12-EHC047-EF.
78 Sutton AJ, Abrams KR, Jones DR, et al. Methods for Meta-Analysis in Medical Research. (Wiley Series in Probability and Statistics - Applied Probability and Statistics Section). London. Wiley. 2000.
79 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. Jun. 15. 2002;21(11):1539-58. [pmid: 12111919].
80 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. Sep. 6. 2003;327(7414):557-60. [pmid: 12958120].
81 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
82 Atkins DC, Chang S, Gartlehner G, et al. Chapter 6: Assessing the applicability of studies when comparing medical interventions. Agency for Healthcare Research and Quality. Rockville, MD. 2011. AHRQ Publication No. 11-EHC019-EF.
83 Acierno R, Rheingold AA, Resnick HS, et al. Preliminary evaluation of a video-based intervention for older adult victims of violence. J Trauma Stress. Dec. 2004;17(6):535-41. [pmid: 15730073].
84 Adler AB, Litz BT, Castro CA, et al. A group randomized trial of critical incident stress debriefing provided to U.S. peacekeepers. J Trauma Stress. Jun. 2008;21(3):253-63. [pmid: 18553407].
85 Eid J, Johnsen BH, Weisaeth L. The effects of group psychological debriefing on acute stress reactions following a traffic accident: a quasi-experimental approach. Int J Emerg Ment Health. Summer. 2001;3(3):145-54. [pmid: 11642192].
86 Brom D, Kleber RJ, Hofman MC. Victims of traffic accidents: incidence and prevention of post-traumatic stress disorder. J Clin Psychol. 1993;(2):131-40. [pmid: 8486794].
87 Bryant RA, Sackville T, Dang ST, et al. Treating acute stress disorder: an evaluation of cognitive behavior therapy and supportive counseling techniques. Am J Psychiatry. Nov. 1999;156(11):1780-6. [pmid: 10553743].
88 Bryant RA, Moulds ML, Nixon RV. Cognitive behaviour therapy of acute stress disorder: a four-year follow-up. Behav Res Ther. Apr. 2003;41(4):489-94. [pmid: 12643970].
89 Bryant RA, Harvey AG, Dang ST, et al. Treatment of acute stress disorder: a comparison of cognitive-behavioral therapy and supportive counseling. J Consult Clin Psychol. Oct. 1998;66(5):862-6. [pmid: 9803707].
90 Bryant RA, Moulds ML, Nixon RD, et al. Hypnotherapy and cognitive behaviour therapy of acute stress disorder: a 3-year follow-up. Behav Res Ther. Sep. 2006;44(9):1331-5. [pmid: 16368074].
91 Bryant RA, Moulds ML, Guthrie RM, et al. The additive benefit of hypnosis and cognitive-behavioral therapy in treating acute stress disorder. J Consult Clin Psychol. Apr. 2005;73(2):334-40. [pmid: 15796641].
92 Bugg A, Turpin G, Mason S, et al. A randomised controlled trial of the effectiveness of writing as a self-help intervention for traumatic injury patients at risk of developing post-traumatic stress disorder. Behav Res Ther. Jan. 2009;47(1):6-12. [pmid: 19012880].
93 Carlier IVE, Lamberts RD, Van Uchelen AJ, et al. Disaster-related post-traumatic stress in police officers: a field study of the impact of debriefing. Stress Medicine. 1998;14(3):143-8.
94 Crespo M, Arinero M. Assessment of the efficacy of a psychological treatment for women victims of violence by their intimate male partner. Span J Psychol. Nov. 2010;13(2):849-63. [pmid: 20977033].
95 Deahl M, Srinivasan M, Jones N, et al. Preventing psychological trauma in soldiers: the role of operational stress training and psychological debriefing. Br J Med Psychol. Mar. 2000;73(Pt 1):77-85. [pmid: 10759052].
96 Foa EB, Hearst-Ikeda D, Perry KJ. Evaluation of a brief cognitive-behavioral program for the prevention of chronic PTSD in recent assault victims. J Consult Clin Psychol. Dec. 1995;63(6):948-55. [pmid: 8543717].
97 Foa EB, Zoellner LA, Feeny NC. An evaluation of three brief programs for facilitating recovery after assault. J Trauma Stress. Feb. 2006;19(1):29-43. [pmid: 16568461].
98 Frappell-Cooke W, Gulina M, Green K, et al. Does trauma risk management reduce psychological distress in deployed troops?. Occup Med (Lond). Dec. 2010;60(8):645-50. [pmid: 20889815].
99 Freyth C, Elsesser K, Lohrmann T, et al. Effects of additional prolonged exposure to psychoeducation and relaxation in acute stress disorder. J Anxiety Disord. Dec. 2010;24(8):909-17. [pmid: 20650600].
100 Gelpin E, Bonne O, Peri T, et al. Treatment of recent trauma survivors with benzodiazepines: a prospective study. J Clin Psychiatry. Sep. 1996;57(9):390-4. [pmid: 9746445].
101 Gidron Y, Gal R, Freedman S, et al. Translating research findings to PTSD prevention: results of a randomized-controlled pilot study. J Trauma Stress. Oct. 2001;14(4):773-80. [pmid: 11776423].
102 Grainger RD, Levin C, Allen-Byrd L, et al. An empirical evaluation of eye movement desensitization and reprocessing (EMDR) with survivors of a natural disaster. J Trauma Stress. Oct. 1997;10(4):665-71. [pmid: 9391949].
103 Hobbs M, Mayou R, Harrison B, et al. A randomised controlled trial of psychological debriefing for victims of road traffic accidents. BMJ. Dec. 7. 1996;313(7070):1438-9. [pmid: 8973231].
104 Holmes A, Hodgins G, Adey S, et al. Trial of interpersonal counselling after major physical trauma. Aust N Z J Psychiatry. Nov. 2007;41(11):926-33. [pmid: 17924246].
105 Jotzo M, Poets CF. Helping parents cope with the trauma of premature birth: an evaluation of a trauma-preventive psychological intervention. Pediatrics. 2005;(4):915-9. [pmid: 15805364].
106 Kenardy J, Thompson K, Le Brocque R, et al. Information-provision intervention for children and their parents following pediatric accidental injury. Eur Child Adolesc Psychiatry. Aug. 2008;17(5):316-25. [pmid: 18350366].
107 Krauseneck T, Padberg F, Roozendaal B, et al. A β-adrenergic antagonist reduces traumatic memories and PTSD symptoms in female but not in male patients after cardiac surgery. Psychol Med. 2010;40(5):861-9. [pmid: 19691871].
108 Peres JF, Foerster B, Santana LG, et al. Police officers under attack: resilience implications of an fMRI study. J Psychiatr Res. Jun. 2011;45(6):727-34. [pmid: 21159352].
109 Peris A, Bonizzoli M, Iozzelli D, et al. Early intra-intensive care unit psychological intervention promotes recovery from post traumatic stress disorders, anxiety and depression symptoms in critically ill patients. Critical Care. 2011;15(1):R41-48. [pmid: 21272307].
110 Resnick HS, Acierno RE, Holmes MM, et al. Prevention of post-rape psychopathology: preliminary findings of a controlled acute rape treatment study. J Anxiety Disord. 1999;13(4):359-70. [pmid: 10504107].
111 Richards D. A field study of critical incident stress debriefing versus critical incident stress management. J Ment Health. 2001;10(3):351-62.
112 Rothbaum BO, Houry D, Heekin MH, et al. A pilot study of an exposure-based intervention in the ED designed to prevent posttraumatic stress disorder. Am J Emerg Med. 2008;26(3):326-30. [pmid: 18358945].
113 Schelling G, Kilger E, Roozendaal B, et al. Stress doses of hydrocortisone, traumatic memories, and symptoms of posttraumatic stress disorder in patients after cardiac surgery: a randomized study. Biol Psychiatry. Mar. 15. 2004;55(6):627-33. [pmid: 15013832].
114 Schelling G, Briegel J, Roozendaal B, et al. The effect of stress doses of hydrocortisone during septic shock on posttraumatic stress disorder in survivors. Biol Psychiatry. Dec. 15. 2001;50(12):978-85. [pmid: 11750894].
115 Tecic T, Schneider A, Althaus A, et al. Early short-term inpatient psychotherapeutic treatment versus continued outpatient psychotherapy on psychosocial outcome: a randomized controlled trial in trauma patients. J Trauma. Feb. 2011;70(2):433-41. [pmid: 21057336].
116 Vaiva G, Ducrocq F, Jezequel K, et al. Immediate treatment with propranolol decreases posttraumatic stress disorder two months after trauma. Biol Psychiatry. 2003;54(9):947-9. [pmid: 14573324].
117 Vijayakumar L, Kumar MS. Trained volunteer-delivered mental health support to those bereaved by Asian tsunami--an evaluation. Int J Soc Psychiatry. Jul. 2008;54(4):293-302. [pmid: 18720890].
118 Zohar J, Yahalom H, Kozlovsky N, et al. High dose hydrocortisone immediately after trauma may alter the trajectory of PTSD: interplay between clinical and animal studies. Eur Neuropsychopharmacol. 2011;21(11):796-809. [pmid: 21741804].
119 Zatzick D, Jurkovich G, Rivara F, et al. A randomized stepped care intervention trial targeting posttraumatic stress disorder for surgically hospitalized injury survivors. Seattle, WA. University of Washington. In press. 1-29.
120 Beatty LJ, Koczwara B, Rice J, et al. A randomised controlled trial to evaluate the effects of a self-help workbook intervention on distress, coping and quality of life after breast cancer diagnosis. Med J Aust. Sep. 6. 2010;193(5 Suppl):S68-73. [pmid: 21542450].
121 Gamble J, Creedy D, Moyle W, et al. Effectiveness of a counseling intervention after a traumatic childbirth: a randomized controlled trial. Birth. Mar. 2005;32(1):11-9. [pmid: 15725200].
122 Shalev AY, Ankri YLE, Israeli-Shalev Y, et al. Prevention of posttraumatic stress disorder by early treatment: results from the Jerusalem Trauma Outreach and Prevention Study. Arch Gen Psychiatry. Feb. 2012;69(2):166-76. [pmid: 21969418].
123 Bryant RA, Mastrodomenico J, Felmingham KL, et al. Treatment of acute stress disorder: a randomized controlled trial. Arch Gen Psychiatry. Jun. 2008;65(6):659-67. [pmid: 18519824].
124 Bryant RA, Moulds M, Guthrie R, et al. Treating acute stress disorder following mild traumatic brain injury. Am J Psychiatry. Mar. 2003;160(3):585-7. [pmid: 12611847].
125 Melnyk BM, Alpert-Gillis L, Feinstein NF, et al. Creating opportunities for parent empowerment: program effects on the mental health/coping outcomes of critically ill young children and their mothers. Pediatrics. Jun. 2004;113(6):e597-607. [pmid: 15173543].
126 Mulligan K, Fear NT, Jones N, et al. Postdeployment Battlemind training for the U.K. armed forces: A cluster randomized controlled trial. J Consult Clin Psychol. 2012;80(3):331-41. [pmid: 22409642].
127 O’Donnell ML, Lau W, Tipping S, et al. Stepped early psychological intervention for posttraumatic stress disorder, other anxiety disorders, and depression following serious injury. J Trauma Stress. Apr. 2012;25(2):125-33. [pmid: 22522725].
128 Rothbaum BO, Kearns MC, Price M, et al. Early Intervention May Prevent the Development of Posttraumatic Stress Disorder: A Randomized Pilot Civilian Study with Modified Prolonged Exposure. Biol Psychiatry. 2012. Jul. 3. [pmid: 22766415].
129 Rose S, Brewin CR, Andrews B, et al. A randomized controlled trial of individual psychological debriefing for victims of violent crime. Psychol Med. Jul. 1999;29(4):793-9. [pmid: 10473306].
130 Ryding EL, Wiren E, Johansson G, et al. Group counseling for mothers after emergency cesarean section: a randomized controlled trial of intervention. Birth. Dec. 2004;31(4):247-53. [pmid: 15566336].
131 Sijbrandij M, Olff M, Reitsma JB, et al. Emotional or educational debriefing after psychological trauma. Randomised controlled trial. Br J Psychiatry. Aug. 2006;189:150-5. [pmid: 16880485].
132 Weis F, Kilger E, Roozendaal B, et al. Stress doses of hydrocortisone reduce chronic stress symptoms and improve health-related quality of life in high-risk patients after cardiac surgery: a randomized study. J Thorac Cardiovasc Surg. Feb. 2006;131(2):277-82. [pmid: 16434254].
133 Wong EC, Marshall GN, Miles JN. Randomized controlled trial of a psychoeducational video intervention for traumatic injury survivors. Los Angeles, CA. RAND Corporation. Under review.
134 Campfield KM, Hills AM. Effect of timing of critical incident stress debriefing (CISD) on posttraumatic symptoms. J Trauma Stress. Apr. 2001;14(2):327-40. [pmid: 11469160].
135 Treggiari MM, Romand JA, Yanez ND, et al. Randomized trial of light versus deep sedation on mental health after critical illness. Crit Care Med. Sep. 2009;37(9):2527-34. [pmid: 19602975].
136 Management of Post-Traumatic Stress Working Group. VA/DoD clinical practice guideline for management of post-traumatic stress. 2010. www.healthquality.va.gov/ptsd/PTSD-FULL-2010a.pdf.
137 Boscarino JA, Adams RE, Figley CR. A prospective cohort study of the effectiveness of employer-sponsored crisis interventions after a major disaster. Int J Emerg Ment Health. Winter. 2005;7(1):9-22. [pmid: 15869077].
138 Boscarino JA, Adams RE, Foa EB, et al. A propensity score analysis of brief worksite crisis interventions after the World Trade Center disaster: implications for intervention and research. Med Care. May. 2006;44(5):454-62. [pmid: 16641664].
139 Everly GS Jr, Suzanne BP, Dianne K, et al. Introduction to and Overview of Group Psychological First Aid. Brief Treatment and Crisis Intervention. 2006;6(2):130.
140 Schafer A, Snider L, van Ommeren M. Psychological first aid pilot: Haiti emergency response. Intervention. 2010;8(3):245-54.
141 Bryant RA, Friedman MJ, Spiegel D, et al. A review of acute stress disorder in DSM-5. Depress Anxiety. Sep. 2011;28(9):802-17. [pmid: 21910186].
142 Boscarino JA, Kirchner HL, Hoffman SN, et al. Predicting Future PTSD using a Modified New York Risk Score: Implications for Patient Screening and Management. Minerva Psichiatr. Mar. 2012;53(1):47-59. [pmid: 22408285].