# Methods

The methods for this comparative effectiveness review (CER) follow the methods suggested in the Agency for Healthcare Research and Quality (AHRQ) “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (www.effectivehealthcare.ahrq.gov/methodsguide.cfm). The main sections in this chapter reflect the elements of the protocol established for the CER; certain methods map to the PRISMA (Preferred Reporting Items for Systematic Reviews and Meta-Analyses).75 All methods and analyses were determined a priori.

## Topic Refinement and Review Protocol

This topic was nominated by a member of the American Psychological Association, which aims to use high-quality evidence syntheses to inform guideline development. During the topic development and refinement processes, we engaged in a public process to develop a draft and final protocol for the CER process. We generated an analytic framework, preliminary Key Questions (KQs), and preliminary inclusion/exclusion criteria in the form of PICOTS (populations, interventions, comparators, outcomes, timing, settings). The processes were guided by the information provided by the topic nominator, a scan of the literature, methods and content experts, and Key Informants. We worked with four Key Informants during the topic refinement, all of whom subsequently served as members of our Technical Expert Panel (TEP) for this report. The TEP consisted of five individuals in total. Key Informants and TEP members participated in conference calls and discussions through email to review the analytic framework, KQs, and PICOTS; discussed the preliminary assessment of the literature; provided input on the information and categories included in evidence tables; and provided input on the data analysis plan.

Our KQs were posted for public comment on AHRQ’s Effective Health Care Web site from January 4, 2012, through February 1, 2012; we put them into final form after review of the comments and discussion with the TEP. We made minimal revisions to the KQs based on comments from the public, primarily for clarity and readability. We then drafted a protocol for this CER and refined the protocol in consultation with AHRQ and the TEP before it was posted on the Effective Health Care Web site on June 6, 2012. Additionally, we made amendments to the protocol and posted those on July 27, 2012, September 27, 2012, and November 8, 2012.

## Literature Search Strategy

### Search Strategy

To identify articles relevant to each KQ, we searched PubMed^®^, the Cochrane Library, EMBASE, PILOTS (Published International Literature on Traumatic Stress), International Pharmaceutical Abstracts, PsycINFO^®^, and Web of Science. The full search strategy is presented in Appendix B. We used either Medical Subject Headings (MeSH) or major headings as search terms when available or key words when appropriate, focusing on terms to describe the relevant populations and interventions of interest. We reviewed our search strategy with the TEP and incorporated their input. Searches were run by an experienced information scientist serving as the Evidence-based Practice Center (EPC) librarian.

We limited the electronic searches to English-language and human-only studies. Sources were searched from January 1, 1980, to January 5, 2012. We selected the start date based on the introduction and definition of PTSD as a clinical entity, the earliest publication date of relevant studies found in previous systematic reviews, and expert opinion about when the earliest literature on this topic was published.

We manually searched reference lists of pertinent reviews, included trials, and background articles on this topic to look for any relevant citations that our searches might have missed. We imported all citations into an EndNote^®^ X4 electronic database.

We also searched for unpublished studies relevant to this review using ClinicalTrials.gov, the Web site for the U.S. Food and Drug Administration, the World Health Organization’s International Clinical Trials Registry, Grey Matters, and OpenGrey. In addition, the Scientific Resource Center requested scientific information packets (SIPs) from the relevant pharmaceutical companies, asking for any unpublished studies or data relevant for this CER. SIPs allow an opportunity for pharmaceutical companies to provide the EPC with both published and unpublished data that they believe should be considered for the review. Studies from the SIPs would be included in the post-peer/public review report.

In cases in which relevant information was unclear or not reported, we contacted authors to get additional or unpublished information. When successful, this information was included in the findings.

We conducted an updated literature search (of the same databases searched initially) concurrent with the peer review process. Any literature suggested by peer reviewers or the public was investigated and, if appropriate, incorporated into the final review. We determined appropriateness for inclusion in the review by the same methods described in this chapter.

### Inclusion and Exclusion Criteria

We developed eligibility (inclusion and exclusion) criteria with respect to patient PICOTS and study designs and durations for each KQ (Table 3). For studies to be eligible, the intervention had to be administered within 3 months of the traumatic event.

Table 3 Eligibility criteria for studies of PTSD prevention

Category | Inclusion | Exclusion
Population | Adults (ages 18 or older) exposed to psychological trauma. Types of trauma include interpersonal or domestic violence or abuse; sexual abuse or assault; rape; combat- or military-related trauma; crime-related events; terrorism; slavery; natural disasters; injury; life-threatening illness; captivity; life-threatening medical procedures; witnessing a traumatic event; refugee trauma; prisoner of war-related trauma; and asylum seeking-related trauma Subgroups of interest include:; - Demographic groups (defined by age, ethnic and/or racial groups, and sex); - Populations with psychiatric comorbidities; - Populations with different personal risks of developing PTSD | Children, people with PTSD
Interventions | Psychological interventions including:; - Cognitive behavioral therapy; - Cognitive processing therapy; - Cognitive therapy (including cognitive restructuring therapy); - Coping skills therapy (including stress inoculation therapy); - Debriefing interventions (including critical incident stress debriefing and critical incident stress management); - Exposure-based therapies (including imaginal and in vivo exposure); - Eye movement desensitization and reprocessing; - Interpersonal therapy; - Psychoeducation; - Psychological first aid; - Other clearly defined psychological interventions; Pharmacological interventions including:; - Alpha blockers (prazosin); - Anticonvulsants (topiramate, tiagabine, lamotrigine, carbamazepine, divalproex, and gabapentin); - Benzodiazepines (alprazolam, diazepam, lorazepam, clonazepam, and temazepam); - Beta blockers (propanolol); - Monoamine oxidase inhibitors (phenelzine, isocarboxazid, selegiline, and tranylcypromine); - Narcotics (morphine); - Nonbenzodiazepine sedative and hypnotics (zolpidem, eszopiclone, rozerem, and zaleplon); - Opioid antagonists (naltrexone); - Other second-generation antidepressants (bupropion, mirtazapine, nefazodone, and trazodone); - Second-generation (atypical) antipsychotics (olanzapine and risperidone); - Selective serotonin reuptake inhibitors (escitalopram, fluoxetine, fluvoxamine, paroxetine, and sertraline); - Serotonin and norepinephrine reuptake inhibitors (duloxetine, desvenlafaxine and venlafaxine); - Steroids (hydrocortisone); - Tricyclic antidepressants (imipramine, amitriptyline and desipramine); - Other clearly defined pharmacological interventions; Emerging interventions including:; - Complementary and alternative medicine approaches (including dietary supplements, yoga, and guided imagery); - New models of health care delivery (including collaborative care); - Other clearly defined emerging interventions | Psychological or pharmacological interventions not listed as included Any intervention that has not been administered within 3 months of the traumatic event
Comparators | - Psychological treatments (listed above); - Pharmacological treatments (listed above); - Combination of psychological and pharmacological treatments; - Emerging treatments (listed above); - Usual care or supportive control; - No active intervention (e.g., wait list, placebo) | Psychological or pharmacological interventions not listed as included
Outcomes | - Incidence of PTSD; - Incidence and severity of PTSD symptoms: assessor-rated or self-rated symptoms (e.g., sleep disturbance, anxiety); - Incidence and severity of coexisting conditions (e.g., depression, anxiety disorders, substance use, abuse, or dependence); - Quality of interpersonal or social functioning; - Quality of life; - Return to work or duty or ability to work; - Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide); - Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide); - Resilience; - Perceived utility (subjective sense of helpfulness of the intervention); - Adverse events: overall adverse events, withdrawals attributed to adverse events, and specific adverse events (including, but not limited to, worsening of anxiety or agitation, increased distress, headaches, gastrointestinal effects, effects on blood pressure, heart rate, sexual side effects, sedation or insomnia, treatment-associated hypomania or mania, medication dependence or misuse, disturbed sleep, weight gain, metabolic side effects, and mortality); - Dropout rate (overall dropout rate, dropout because of adverse effects, dropout because of lack of efficacy)
Publication language | English | All other languages
Time period | 1980–present; searches to be updated after draft report goes out for peer review
Settings | - Outpatient and inpatient primary care; - Specialty mental health care settings; - Community settings (e.g., churches, community health centers, rape crisis centers); - Military settings
Geography | No limits
Timing | Intervention must be administered any time ranging from immediately to 3 months after exposure to a traumatic event No limit for duration of followup
Admissible evidence for KQ 1 through KQ 4 | Original research For KQs 1 through 4, eligible study designs include: Randomized controlled trials Prospective controlled cohort studies For KQs 2 through 4 when outcomes of interest are focused on harms, additional eligible study designs are: Retrospective controlled cohort studies Case control studies | - Case series; - Case reports; - Systematic reviews and meta-analyses; - Nonsystematic reviews; - Editorials; - Letters to the editor; - Studies with historical, rather than concurrent, control groups; - Pre-post studies without a separate control group

KQ = Key Question; PTSD = posttraumatic stress disorder

### Study Selection

We developed and pilot-tested literature review forms for abstract and full-text reviews. Two trained members of the research team independently reviewed all titles and abstracts (identified through searches) for eligibility against our inclusion/exclusion criteria. Studies marked for possible inclusion by either reviewer underwent a full-text review. For studies that lacked adequate information to determine inclusion or exclusion, we retrieved the full text and then made the determination. If the necessary information in full-text articles was unclear or missing, we contacted authors of the publications. All results were tracked in an EndNote® database.

We retrieved the full text of all articles included during the title and abstract review phase. Two trained members of the research team independently reviewed each full-text article for inclusion or exclusion based on the eligibility criteria described above. If both reviewers agreed that a study did not meet the eligibility criteria, we excluded it. If the reviewers disagreed, they resolved conflicts by discussion and consensus or by consulting a third, senior member of the review team. All results were tracked in an EndNote database. We recorded the principal reason that each excluded full-text publication did not satisfy the eligibility criteria (Appendix D).

### Data Extraction

For studies that met our inclusion criteria and were of low or medium risk of bias, we extracted important information into evidence tables. We designed, pilot tested, and used structured data extraction forms to gather pertinent information from each article; this included characteristics of study populations, settings, interventions, comparators, study designs, methods, and results. Trained reviewers extracted the relevant data from each included article into the data extraction forms. All data abstractions were reviewed for completeness and accuracy by a second more senior member of the team. We recorded intention-to-treat (ITT) results if available. All data abstraction was performed using Microsoft Excel® software. Evidence tables containing all extracted data of included studies are presented in Appendix E.

We did not extract complete data from studies that we rated as high risk of bias.76

## Risk-of-Bias Assessment of Individual Studies

To assess the risk of bias (internal validity) of studies for major outcomes of interest, we used predefined criteria based on guidance from the AHRQ “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.”76 We assessed selection bias, confounding, performance bias, detection bias, and attrition bias; we included questions about adequacy of randomization, allocation concealment, similarity of groups at baseline, blinding, attrition, whether ITT analysis was used, method of handling dropouts, and treatment fidelity. We rated the studies as low, medium, or high risk of bias.77 If RCTs were rated as high risk of bias because of flawed randomization, we viewed them as prospective cohort studies and determined their risk of bias based on criteria for observational studies.

In general terms, a study categorized as low risk of bias implies confidence that results represent the true treatment effects. A study with medium risk of bias is susceptible to some risk of bias but probably not enough to invalidate its results. Studies with a medium risk of bias did not meet all criteria required for low risk of bias. These studies had some flaws in design or execution (e.g., imbalanced recruitment, high attrition) but they provided enough information to allow readers to determine that these flaws did not likely cause major bias. Missing information often led to ratings of medium as opposed to low risk of bias. A study assessed as high risk of bias has significant flaws of various types (e.g., stemming from serious errors in design, conduct, or analysis) that may invalidate its results. Examples include poor randomization for randomized controlled trials or failure to control for confounding for observational studies, as well as overall attrition ≥ 20% or differential attrition ≥ 15% without appropriate handling of missing data such as the use of intention-to-treat analyses. The protocol specified our a priori decision to consider studies with a high risk of bias for synthesis in this review only if we could not answer the KQs with the available studies with low or medium risk of bias.

Two independent reviewers assessed the risk of bias for each study; one of the two reviewers was always an experienced or senior investigator. Disagreements between the two reviewers were resolved by discussion and consensus or by consulting a third member of the team. We omitted studies deemed high risk of bias by two reviewers from our main data synthesis and main analyses; we included them only in sensitivity analyses. Appendix F details the criteria used for evaluating the risk of bias of all included studies and explains the rationale for high risk of bias ratings.

## Data Synthesis

Because of the ongoing controversy about whether different interventions are efficacious at all, we assessed both evidence for the efficacy (i.e., is an intervention efficacious compared with no active treatment such as a waitlist or placebo) and the comparative effectiveness. We used this approach because our preliminary searches as well as input from experts during the topic refinement process suggested that we would find little head-to-head comparative evidence and that we might need to rely on indirect evidence to attempt to make conclusions about comparative effectiveness.

We conducted quantitative synthesis using meta-analyses of outcomes reported by multiple studies that were sufficiently homogeneous to justify combining their results. When quantitative synthesis was not appropriate (e.g., because of clinical heterogeneity, insufficient numbers of similar studies, or insufficiency or variation in outcome reporting), we synthesized the data qualitatively.

We used random-effects models to estimate pooled effects.78 For continuous outcomes (e.g., scales for symptom reduction), we used weighted mean differences (WMD). If we had to combine multiple scales in one meta-analysis, we used the standardized mean difference (SMD), Cohen’s d. For binary outcomes we calculated the relative risk of PTSD between groups. For each meta-analysis, we conducted sensitivity analyses by adding studies that we had rated as high risk of bias. We calculated the chi-squared statistic and the I^2^ statistic to assess statistical heterogeneity in effects between studies.79,80 We examined potential sources of heterogeneity by analysis of subgroups defined by subject population and variation in interventions or controls. Heterogeneity was also explored through sensitivity analyses.

For KQ 3 (subgroup analyses), we evaluated only those studies that conducted subgroup analyses on the original data. We did not perform separate stratified analyses based on subgroups because the potential for introducing confounding bias was greater than the potential insight that those analyses might yield. For example, the percentage of females in a study is likely to be associated with the type of trauma exposure. We did not perform meta-regression because the number of studies was too small.

We assessed publication bias using funnel plots. Quantitative pairwise meta-analyses were conducted using Stata^®^ version 11.1, StataCorp., Texas, USA.

## Strength of the Body of Evidence

We graded the strength of evidence (SOE) based on the guidance established for the Evidence-based Practice Center program.81 Developed to grade the overall strength of a body of evidence, this approach incorporates four key domains: risk of bias (includes study design and aggregate quality), consistency, directness, and precision of the evidence. It also considers other optional domains that may be relevant for some scenarios, such as a dose-response association, plausible confounding that would decrease the observed effect, strength of association (magnitude of effect), and publication bias. Table 4 defines the grades of evidence that we assigned.

Table 4 Definitions of the grades of overall strength of evidence

Grade | Definition
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit estimation of an effect.

Source: Owens et al., 2010^81^

We graded the SOE with respect to eight outcomes viewed as critical for decisionmaking (Table 5). We selected these outcomes a priori with input from the TEP.

Table 5 Outcomes viewed as critical for decisionmaking

Effectiveness of Interventions
- Incidence of PTSD; - Severity of PTSD symptoms (if worsening of symptoms, outcome is relevant for adverse effects); - Quality of life; - Return to work or active duty; - Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide); - Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide); - Incidence and severity of depressive or anxiety symptoms
Harms of Interventions
- Overall rate of harms; - Dropout rate because of harms

PTSD = posttraumatic stress disorder

Two reviewers assessed each domain for each key outcome and determined an overall SOE grade based on domain ratings, and for each assessment, one of the two reviewers was always an experienced or senior investigator. In the event of disagreements on the domain or overall grade, they resolved differences by consensus discussion or by consulting with a third, senior investigator.

The principal focus in the results is on outcomes viewed as critical for decisionmaking, but we also comment on other outcomes of interest.

Appendix G includes tables showing our assessments for each domain and resulting SOE grades for each outcome, organized by KQ and intervention/comparison pair.

## Applicability

We assessed applicability of the evidence following guidance from the “Methods Guide for Comparative Effectiveness Reviews.”82 We used the PICOTS framework to explore factors that affect applicability. Some factors identified a priori that may limit the applicability of evidence include the following: age of enrolled populations, sex of enrolled populations, race or ethnicity of enrolled populations, few studies enrolling subjects with exposure to certain types of trauma, or few studies distinguishing or reporting the type of traumatic exposure for a heterogeneous population. Throughout the report, we use the terms “efficacy” and “comparative effectiveness.” By efficacy, we mean the efficacy or effectiveness of an intervention tested against some type of inactive control (e.g., placebo or waitlist). By comparative effectiveness we mean the efficacy or effectiveness of an intervention compared with another intervention of interest. In this report, we did not distinguish between explanatory (i.e., efficacy) and pragmatic (i.e., effectiveness) studies.

## Peer Review and Public Commentary

An external peer review was performed on this report. Peer Reviewers were charged with commenting on the content, structure, and format of the evidence report, providing additional relevant citations, and pointing out issues related to how we conceptualized the topic and analyzed the evidence. Our Peer Reviewers (listed in the front matter) gave us permission to acknowledge their review of the draft. We compiled all comments and addressed each one individually, revising the text as appropriate. AHRQ also provided review from its own staff. In addition, the Scientific Resource Center placed the draft report on the AHRQ Web site (www.effectivehealthcare.ahrq.gov/) for public review.