# Introduction

## Background

### The Condition

Posttraumatic stress disorder (PTSD) may develop following exposure to a traumatic event. According to the fourth edition of the Diagnostic and Statistical Manual of Mental Disorders, Text Revision (DSM-IV-TR),1 the essential feature of PTSD is the development of characteristic symptoms following exposure to an extreme traumatic stressor. The stressor may include having direct personal experience of an event that involves actual or threatened death or serious injury or other threat to one’s physical integrity; witnessing an event that involves death, injury, or a threat to the physical integrity of another person; or learning about unexpected or violent death, serious harm, or threat of death or injury experienced by a family member or other close associate. The DSM-IV-TR also requires that the person’s response to the event involve intense fear, helplessness, or horror. Table 1 lists the full DSM-IV-TR criteria.

Table 1 Diagnostic criteria (DSM-IV-TR) for posttraumatic stress disorder

Criterion | Symptom or Description
Criterion A: Trauma (both) | - Traumatic event that involved actual or threatened death, serious injury, or threat to physical integrity; - Intense response of fear, helplessness, or horror
Criterion B: Reexperiencing symptoms (one or more) | - Intrusive recollections of events; - Recurrent distressing dreams of the event; - Acting or feeling as if the traumatic event were recurring; - Distress at internal or external reminders of the trauma; - Physiological reaction to internal or external reminders
Criterion C: Persistent avoidance and numbing (three or more) | - Avoidance of thoughts, feelings, or conversations associated with trauma; - Avoidance of activities, places, or people that arouse recollections of trauma; - Failure to recall an important aspect of trauma; - Loss of interest or participation in significant activities; - Detachment from others; - Restricted range of affect; - Lost sense of the future
Criterion D: Hyperarousal (two or more) | - Difficulty falling or staying asleep; - Irritability or outburst of anger; - Difficulty concentrating; - Hypervigilance; - Exaggerated startle response
Criterion E: Duration of disturbance | - Duration of disturbance symptoms is more than 1 month
Criterion F: Clinically significant distress or impairment | - Disturbance causes clinically significant distress or impairment in social, occupational, or other important areas of function

DSM-IV-TR = Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition, Text Revision

Some traumatic events that are directly experienced or to which one can be exposed include military combat, violent personal assault, being taken hostage, a terrorist attack, torture, natural or man-made disasters, and being diagnosed with a life-threatening illness.1 PTSD is also highly comorbid with other psychiatric disorders; data from epidemiologic studies have found that a majority of adults with PTSD have another psychiatric disorder, mostly notably substance use disorders and major depressive disorder.2 Subgroups of people with PTSD who could have different responses to various treatments include military personnel or veterans, people with comorbid conditions, groups defined by sex, first responders, refugees, disaster victims, racial and ethnic minorities, and those with different PTSD symptoms.

### Prevalence of Traumatic Events

Studies suggest that adults experience a broad range of traumatic events throughout their lives. The frequency of these events may vary by the group studied, for example, civilian versus noncivilian samples. Studies conducted in the 1990s attempted to identify and describe the prevalence of traumatic events in nonclinical samples. Resnick et al. found that lifetime exposure to any type of traumatic event was 69 percent in a sample of 4,008 adult U.S. women.3 The National Comorbidity Survey indicated that 60 percent of men and 51 percent of women reported experiencing at least one traumatic event in their lifetimes.4

Most of the research has focused on assessing the burden of trauma in different populations. Not surprisingly, studies among groups at risk of occupational exposure to trauma, such as police officers, firefighters, and military service members, have shown high rates of trauma exposure.5 Several studies of the prevalence of traumatic events among college students all showed that exposure to traumatic events was relatively common, with lifetime prevalence ranging from 39 to 84 percent.6–8

### Development of PTSD and Rationale for Early Intervention To Prevent PTSD

Many theories focus on the role of disturbances in memory (e.g., problems with memory formation, retrieval, bias, and saliency); they argue that alterations in the normal processes of memory are key to understanding the development and maintenance of PTSD. One of these theories suggests that when trauma-related experiences are not properly integrated into memory, individuals may re-experience symptoms of PTSD.9

Intense affect during a traumatic event and its accompanying physiological arousal have been associated with the development of PTSD.10,11 Dissociation or detachment during the event has also been found to be a significant predictor of PTSD.10 In extreme threat situations, strong affect can result in dissociation which prevents trauma-related information from being fully consolidated within memory. Incomplete memory consolidation may cause an individual to retain a limited amount of information about the event, make the memory less accessible, or both. The ability to access full or complete trauma-related memories is a core feature of several psychological theories of PTSD prevention and/or treatment.

Stress hormones released during exposure to a traumatic event have also been implicated in the development of PTSD. Heightened peri-traumatic noradrenergic activity may enhance consolidation of memory for the event.12 Central noradrenergic activity also has other effects on information processing, for example narrowing attentional focus.13 Thus, peri-traumatic hyperarousal might lead to explicit memory for a traumatic event which is strongly consolidated but relatively poor in quality, thus contributing to some of the symptoms of PTSD.

Cognitive theories of PTSD are based on the concept that information associated with a traumatic event is inconsistent with the information contained in an individual’s core schema about themselves, others, and the world. An individual exposed to a traumatic event tries to make sense of the experience but has difficulty fully integrating it into his or her existing schema. Over time, this disintegration manifests itself in the symptoms and behaviors classified as PTSD. Maladaptive beliefs related to the traumatic event have also been identified as a risk factor for the development of PTSD.14

The implications of these various theories provide a rationale for myriad early intervention strategies, which for this review we consider to be those provided within 3 months of the trauma. We chose to define early interventions as those offered within the first 3 months post-trauma for two reasons. One, because the onset of symptoms of PTSD usually occurs within 3 months after the traumatic event15 and two, because in order to meet the diagnostic criteria for PTSD, symptoms must be present for at least 1 month. By focusing on interventions that occur within 3 months post-trauma, we are allowing sufficient time for posttraumatic symptoms to develop and identifying interventions offered during the period of time when people could have symptoms of PTSD, but not yet meet the diagnostic criteria for PTSD. Variability of types of trauma, contexts in which trauma occur, and individual differences of those exposed to traumatic events are likely to prohibit a “one size fits all” model for early intervention.

### Burden and Cost of PTSD

Shortly after exposure to trauma, many people experience some of the symptoms of PTSD. In most people, those symptoms resolve spontaneously in the first several weeks after the trauma. However, in approximately 10 percent to 20 percent of those exposed to trauma, PTSD symptoms persist and are associated with impairment in social or occupational functioning.5 Although approximately 50 percent of those diagnosed with PTSD improve without treatment in 1 year, 10 percent to 20 percent develop a chronic unremitting course.16

The 2000 National Comorbidity Survey-Replication (NCS-R) estimated lifetime prevalence of PTSD among trauma-exposed adults in the United States to be 6.8 percent (9.7% in women and 3.4% in men) and current (12-month) prevalence to be 3.6 percent (5.2% in women and 1.8% in men), or more than 7.7 million American adults per year.17–19 Some demographic or occupational groups, such as military personnel, are at higher risk of PTSD because of higher rates of exposure to trauma.

Estimates from the National Vietnam Veterans Readjustment Survey (NVVRS) found a lifetime PTSD prevalence estimate of 18.7 percent and a current PTSD prevalence estimate of 9.1 percent20 among Vietnam veterans. Surveys of military personnel returning from operations in Afghanistan and Iraq have yielded estimates ranging from 6.2 percent for U.S. service members who fought in Afghanistan to 12.6 percent for those who fought in Iraq.21 In addition to lives lost from increased risk of suicide, PTSD is associated with high medical costs and high social costs because PTSD is a strong risk factor for crime, poor work performance and associated job losses, and familial discord. The economic cost of the PTSD and depression cases among Operation Enduring Freedom/Operation Iraqi Freedom veterans alone (including medical care, foregone productivity, and lives lost through suicide) is estimated at $4 billion to $6 billion over 2 years.22

Many people with PTSD do not seek treatment. Among those who do, many receive inadequate treatment or care that is not empirically based.17,23 Several PTSD outcome studies demonstrate the cost-effectiveness of early diagnosis and appropriate treatment, especially when compared with the cost of inadequate or ineffective treatment occurring prior to a correct diagnosis.24 In addition to consequences related to PTSD, people affected by these disorders have higher rates of psychiatric comorbidity, suffer decreased role functioning such as work impairment (on average, 3.6 days of work impairment per month), and experience many different adverse life-course consequences (e.g., reduced educational attainment, work earnings, marriage attainment, and child rearing).25

## Prevention Strategies

The first generation of research on PTSD prevention focused primarily on universal prevention (i.e., the delivery of interventions to all people exposed to trauma, regardless of symptoms or risk of developing PTSD). However, based on evidence that 1) debriefing interventions for all people exposed to particular traumas did not reduce PTSD and 2) most people exposed to trauma experience symptoms of PTSD but do not develop PTSD and its attendant functional impairment, a new model of PTSD prevention, targeted prevention, has generated a second generation of PTSD prevention research. The goal of targeted prevention is to identify, from among all people exposed to trauma, those individuals who are at high risk of developing the disorder of PTSD and then intervene only with those at high risk.26

Interventions to prevent PTSD and reduce symptoms of PTSD involve various psychological and pharmacological approaches; they also include emerging interventions such as approaches from complementary and alternative medicine (CAM). These interventions have been used both separately and in combination with one another.

### Psychological Interventions

Specific psychological interventions that have been studied for the prevention of adult PTSD are described below and include the following: Battlemind training; trauma-focused cognitive behavioral therapy (CBT); cognitive processing therapy (CPT); cognitive therapy, or cognitive restructuring; coping skills therapy, including stress inoculation therapy; debriefing interventions, including critical incident stress debriefing (CISD) and critical incident stress management (CISM); exposure-based therapies; eye movement desensitization and reprocessing (EMDR); interpersonal therapy (IPT); psychoeducation; and psychological first aid (PFA). These therapies are designed to prevent the onset of PTSD and development of trauma-related stress symptoms soon after exposure to a traumatic event.

#### Battlemind Training

Postdeployment Battlemind training is an early intervention program designed by the U.S. Army to assist soldiers with reintegration and transition to home life following combat.27 Battlemind training is based on research from the Walter Reed Army Institute of Research and takes a cognitive- and skills-based approach to educating military personnel about postdeployment transition. Additionally, Battlemind training encourages military personnel to seek support from military peers and leaders.

#### Cognitive Behavioral Therapy

CBT uses principles of learning and conditioning to treat psychological disorders and includes components from both behavioral and cognitive therapy. In trauma-focused CBT, components such as exposure, cognitive restructuring, and various coping skills have been used either alone or in combination with one another. Most forms of trauma-focused CBT are brief and involve weekly sessions lasting 60 to 90 minutes, although the number of sessions varies across studies. CBT can be administered as either group or individual therapy.23,28,29

#### Cognitive Processing Therapy

CPT, a type of cognitive restructuring, includes psychoeducation, written exposures about the traumatic event, and cognitive restructuring addressing the beliefs about the event’s meaning and the implications of the trauma for one’s life.30 The treatment is based on the idea that affective states, such as a depressed mood, can interfere with emotional and cognitive processing of the trauma memory, which can lead to traumatic symptomatology. Cognitive processing therapy is generally delivered over 12 sessions lasting 60 to 90 minutes.

#### Cognitive Therapy

Cognitive therapy, or cognitive restructuring, is based on the theory that the interpretation of the event, rather than the event itself, determines an individual’s mood. It aims to facilitate relearning thoughts and beliefs generated from a traumatic event, increase awareness of dysfunctional trauma-related thoughts, and correct or replace those thoughts with more adaptive or more rational cognitions (or both). Cognitive restructuring generally takes place over 8 to 12 sessions lasting 60 to 90 minutes.23,28

#### Coping Skills Therapy

Coping skills therapy may include components such as stress inoculation therapy, assertiveness training, biofeedback (including brainwave neurofeedback), or relaxation training. All may use techniques such as education, muscle relaxation training, breathing retraining, role playing, etc., to manage anxiety or correct misunderstandings conditioned at the time of trauma. The therapy is designed to increase coping skills for current situations. Most types of coping skills therapies require at least eight 60- to 90-minute sessions; more comprehensive interventions such as stress inoculation therapy require 10 to 14 sessions.23,28

#### Debriefing Interventions, Critical Incident Stress Debriefing, and Critical Incident Stress Management

Debriefing interventions aim to educate victims about normal reactions to trauma and to encourage them to share their experiences and emotional responses to the event. Debriefing is a universal prevention strategy, typically offered in a single session within hours or days following the event. Although several variations of these single-session interventions have been tested, the most common form of psychological debriefing is CISD.31

CISD is a preventive intervention originally developed for use with individuals indirectly exposed to traumatic events because of their occupation, such as firefighters or emergency medical personnel. CISD is administered in a single 3- to 4-hour session by a team composed of individuals familiar with the organization (e.g., officers within a police department) and mental health professionals.32,33 In addition to helping normalize individuals’ responses to stress and encouraging them to talk about their experiences and reactions, the team teaches coping skills and offers additional resources for those who may need them.34 By design, the CISD approach is flexible and loosely structured.

CISD was not designed to prevent PTSD; nonetheless, it has been applied directly to victims of trauma despite evidence that it may be ineffective for that purpose and actually may have harmful effects.35–37 A 2002 update of a previous 1997 Cochrane Review assessed the effectiveness of brief, single-session psychological debriefing for managing psychological distress after trauma and preventing PTSD and concluded that there is no current evidence that psychological debriefing is a useful treatment for the prevention of PTSD and that compulsory debriefing of victims of trauma should cease.38

CISD has expanded to become CISM, a multicomponent, comprehensive crisis intervention program; it aims to reduce the severity of and related impairment associated with traumatic stress.35 CISM incorporates additional methods such as preincident training for people with high-risk occupations, one-on-one individual crisis support, demobilizing (i.e., giving information about coping and stress to large groups of emergency workers as they rotate off duty), and defusing (i.e., small-group interventions during which participants are asked to explore and discuss the incident and their emotional reactions to it).32 CISM also has a family support component whereby family members of the emergency personnel are debriefed. Lastly, additional procedures involve referring people for psychological services.35

#### Exposure-Based Therapy

Exposure-based therapy involves confrontation with frightening stimuli, which is continued until anxiety is reduced. The exposure is based on mental imagery from memory or introduced in scenes presented by the therapist (imaginal exposure). In some cases, exposure is from the actual scene or similar events in life (in vivo exposure). The aim is to extinguish the conditioned emotional response to traumatic stimuli (i.e., for the subject to learn that nothing “bad” will happen when encountering trauma-related cues). This eventually reduces or eliminates avoidance of feared situations and the affect associated with them. Exposure therapy is typically conducted for 8 to 12 weekly or biweekly sessions lasting 60 to 90 minutes.23,24,28

#### Eye Movement Desensitization and Reprocessing

EMDR combines imaginal exposure with the concurrent induction of saccadic eye movements (quick, simultaneous movements of both eyes in the same direction) that are believed to help reprogram brain function so that the emotional impact of trauma can be resolved. In the EMDR process, the individual is instructed to imagine a traumatic memory, engage in negative cognition, and then articulate an incompatible positive cognition (e.g., personal worth). The clinician asks the individual to contemplate the memory while focusing on rapid movement of clinicians’ fingers. After 10 to 12 eye movements (back and forth), the clinician asks the individual to rate the strength of the memory and his or her belief in the positive cognition. Although earlier versions of EMDR consisted of 1 to 3 sessions, current standards consist of 8 to 12 90-minute weekly sessions.23,39

#### Interpersonal Therapy

Interpersonal therapy is a time-limited, dynamically informed psychotherapy that aims to alleviate patients’ suffering and improve their interpersonal functioning. This type of therapy focuses specifically on interpersonal relationships and aims to help patients either improve their interpersonal relationships or change their expectations about them. In addition, it aims to help patients improve their social support so they can better manage their current interpersonal distress. Interpersonal therapy generally requires 10 to 20 weekly sessions in the acute phase followed by a time unlimited maintenance phase.40

#### Psychoeducation

Psychoeducation uses structured or semistructured forms of patient information designed to teach individuals about a range of health-related issues. Post-trauma prevention psychoeducation can focus on variety of issues; these include the typical responses one might experience after exposure to a traumatic event, characteristic symptoms and early warning signs of illness, self-care, coping skills, relapse prevention, community resources, and guidelines for when to seek treatment. Psychoeducation can be offered in different forms including individual or group information sessions, brochures, books, videos, and other forms of media.

#### Psychological First Aid

PFA is a systematic set of helping actions aimed at reducing initial post-trauma distress and supporting short- and long-term adaptive functioning. PFA is designed as an initial component of a comprehensive disaster or trauma response. It is constructed around eight core actions: (1) contact and engagement, (2) safety and comfort, (3) stabilization, (4) information gathering, (5) practical assistance, (6) connection with social supports, (7) information on coping support, and (8) linkage with collaborative services.41

PFA is concept driven; its application requires assessment and clinical judgment by the provider given the complexity of presentations, variability of context, need, and logistical constraints. PFA is intended for use by disaster mental health responders, counselors, and others who may provide immediate support for trauma survivors. Two of PFA’s major advantages are that it is highly portable and designed for delivery anywhere recent trauma survivors can be found—such as shelters, schools, hospitals, homes, staging areas, feeding locations, family assistance centers, and other community settings. The principles of PFA can also be applied immediately following a traumatic event in nondisaster field settings, including hospital trauma centers, rape crisis centers, and war zones.42

#### Supportive Counseling

Supportive therapy is a type of psychological intervention that aims to help an individual function better by providing personal support. In general, change is not the goal of supportive counseling. Supportive counseling allows an individual to reflect on his or her life situation in an environment where he or she feels accepted and therefore better able to cope.

### Pharmacological Interventions

Various neurobiological pathways have been implicated in the development of PTSD. Accordingly, pharmacotherapy has been tried as a preventive intervention for PTSD. Several drugs have been studied for the treatment and prevention of PTSD including selective serotonin reuptake inhibitors (SSRIs), serotonin and norepinephrine reuptake inhibitors (SNRIs), other second-generation antidepressants, tricyclic antidepressants (TCAs), monoamine oxidase inhibitors (MAOIs), beta-blockers, alpha-blockers, benzodiazepines, anticonvulsants, nonbenzodiazepine sedatives/hypnotics, atypical antipsychotics, narcotic medication, steroids, and opioid antagonists.13,29,43

#### Alpha Blockers

Some symptoms of PTSD are related to central nervous system adrenergic hyperarousal.44 Medications targeting central noradrenergic dysregulation may be effective in preventing or treating symptoms of PTSD. Studies have demonstrated effectiveness of alpha-1 and alpha-2 adrenoreceptor agonists in treating sleep disturbances, especially nightmares, and general symptoms of hyperarousal associated with PTSD.43

#### Anticonvulsants

Several anticonvulsant medications have been used to treat symptoms of PTSD.45 Gabapentin has several pharmacological and pharmacokinetic properties that make it a potentially useful medication for treating and preventing PTSD.46,47 Similar to benzodiazepines, gabapentin may exert its effects through its structural relationship to GABA (gamma-aminobutyric acid), playing an important role in decreasing excitatory input (glutamate) at the N-methyl-d-aspartate (NMDA) and alpha-amino-3-hydroxy-5-methyl-4-isoxazolepropionic acid (AMPA) receptors, thought to play a role in sensory transmission important in the psychobiology of PTSD.48

#### Benzodiazepines

Benzodiazepines enhance the effect of the neurotransmitter GABA and can produce sedative, hypnotic, anxiolytic, anticonvulsant, muscle relaxant, and amnesic effects. These properties make benzodiazepines useful in mediating symptoms of anxiety. Benzodiazepine use in PTSD is directed largely toward symptomatic management of hyperarousal-related symptoms such as sleep disturbances; these agents have not been shown to treat PTSD effectively.45,49

#### Beta-Blockers

A large body of research suggests that PTSD is associated with hyper-reactivity of the sympathetic nervous system, specifically the noradrenergic system. Heart rate is elevated in the peritraumatic event period among people exposed to trauma who develop PTSD; stress-induced norepinephrine levels are higher among people with PTSD; and corticotrophin-releasing factor, which stimulates release of norepinephrine, is elevated in people with PTSD.50 Propranolol, a beta-adrenergic antagonist that crosses the blood-brain barrier, has been evaluated in several studies for its ability to prevent PTSD.47,51,52 So far results have failed to show any clear benefit of propranolol compared with placebo in reducing physiological reactivity during traumatic imagery, severity of PTSD symptoms, or the rate of the PTSD diagnostic outcome. In addition, significant controversy exists about the use of propranolol for PTSD prevention because of its ability to attenuate the emotional response and memory of a traumatic event. Studies have shown that propranolol not only decreases emotional memory but also episodic memory for the traumatic event.53 This effect leads to various ethical concerns, considering that the long-term implications of emotional and episodic memories are not yet well understood.

#### Monoamine Oxidase Inhibitors

MAOIs increase the concentration of amines in the cytoplasm and the synaptic terminals of neural cells. This accumulation of amines is believed to be responsible for their therapeutic action. In this context, the therapeutic effects of MAOIs might be mediated by the same mechanisms that are responsible for the efficacy of the tricyclic agents. Consequently, elevated levels of catecholamines and serotonin are thought to be able to correct abnormalities in the central nervous system that trauma has altered.54

#### Narcotics

The opiate analgesic, morphine, has shown promise in preventing PTSD in people experiencing physical injury from a traumatic event.55,56 Researchers who have studied the protective effects of morphine administration in preventing PTSD have proposed two primary hypotheses. One is that pain relief as part of trauma care has a protective effect against the development of PTSD.56–58 The other is that opiates may interfere with or prevent memory consolidation through a beta-adrenergic mechanism.59,60 These studies highlight and support the importance of pain control in physically injured people, but the potential role of opiates in preventing PTSD following severe psychological trauma in the absence of painful physical injury remains unclear.

#### Nonbenzodiazepine Sedatives or Hypnotics

Similar to benzodiazepines, nonbenzodiazepines enhance the effect of the neurotransmitter GABA; they can produce sedative, hypnotic, anxiolytic, anticonvulsant, muscle-relaxant, and amnesic effects. Trials of nonbenzodiaepines (buspirone and eszopiclone) have reported that these medications have been effective in reducing symptoms of PTSD.61,62

#### Opioid Antagonists

Abnormalities in the endogenous opioid system may underlie PTSD symptomatology; high comorbidity between PTSD and substance abuse might also suggest involvement of common pathways in the pathophysiology of these disorders.63 These considerations raise the possibility that opioid antagonists might have a role in the treatment of PTSD. Some studies have provided evidence to support this conclusion.64,65

#### Other Second-Generation Antidepressants

Bupropion, nefazodone, and trazodone are believed to work through their effects on serotonin, norepinephrine, and dopamine, which are neurotransmitters related to fear, anxiety, and mood. Their primary mechanism of action is unknown. Bupropion is a relatively weak inhibitor of the neuronal uptake of norepinephrine, serotonin, and dopamine; nefazodone is believed to inhibit neuronal uptake of serotonin and norepinephrine. Trazodone appears to produce its primary effect by selectively inhibiting serotonin reuptake, but it also causes adrenoreceptor subsensitivity and induces significant changes in 5-hydroxytryptamine (5-HT) presynaptic receptor adrenoreceptors.

#### Second-Generation (Atypical) Antipsychotics

Atypical antipsychotics improve psychotic symptoms by blocking D2 receptors and decreasing dopamine activity in the central nervous system.54 Neurobiological studies have examined the role of dopamine in the amygdala and other limbic structures implicated in PTSD symptomatology; they suggest that dopaminergic transmission might have a modulatory role in the function of these structures.66

#### Selective Serotonin Reuptake Inhibitors

SSRIs are currently the most widely used drugs to treat PTSD. SSRIs have been shown to be modestly effective for civilian trauma-related PTSD but no more effective than placebo for PTSD in military veterans.67,68 As with beta blockers, such as propranolol, SSRIs may diminish the more severe clinical sequelae following a stress exposure, possibly through nonspecific effects on other monoamines, through neuroprotective effects in the brain, or through increases in neurotrophic factors that can block the down-regulation of brain-derived neurotrophic factors.69

#### Serotonin and Norepinephrine Reuptake Inhibitors

Like the SSRIs, SNRIs act on neurotransmitters related to fear, anxiety, and mood by inhibiting the reuptake of the neurotransmitters serotonin and norepinephrine. This increases the extracellular concentrations of serotonin and norepinephrine and, therefore, an increase in neurotransmission. The SNRI venlafaxine has been shown to be effective for treating PTSD.70,71

#### Steroids

A substantial body of research has suggested that alterations in the hypothalamic-pituitary-adrenal (HPA) axis are associated with PTSD. Much of the research suggests increased sensitivity of the HPA negative feedback loop between the release of corticotropin-releasing factor (CRF) from the hypothalamus and release of cortisol from the adrenal cortex, resulting in high levels of CRF and low levels of cortisol among people with PTSD.50 This finding has led to the hypothesis that exogenous administration of cortisol shortly after trauma may prevent PTSD by preventing development of HPA axis dysregulation.

#### Tricyclic Antidepressants

TCAs block the reuptake of norepinephrine and serotonin to varying degrees. Central catecholamines and serotonin are involved in modulating arousal level and stress response and in regulating mood and anxiety. Aspects of PTSD (e.g., fear and arousal) suggest dysregulation in one or more of these functions in the etiology of PTSD; this provides a neurobiological rationale for the efficacy of pharmacological interventions that affect these systems.54 Because the majority of TCAs are active in several neurotransmitter systems, their efficacy in PTSD could be mediated by their effect in increasing serotoninergic transmission, modulating alpha-2 adrenergic function, affecting monoamine transporters, or influencing secondary messenger systems or some combination of these effects.

Table 2 provides a summary of the medications used to prevent PTSD. Currently, the U.S. Food and Drug Administration has not approved any pharmacological interventions for the prevention of PTSD.

Table 2 Medications studied for the prevention or treatment of PTSD

Class | Drug
Alpha blockers | Prazosin
Anticonvulsants | Topiramate, tiagabine, lamotrigine, carbamazepine, divalproex, and gabapentin
Benzodiazepines | Alprazolam, diazepam, lorazepam, clonazepam, and temazepam
Beta blockers | Propranolol
Monoamine oxidase inhibitors | Phenelzine, isocarboxazid, selegiline, and tranylcypromine
Narcotic medication | Morphine
Nonbenzodiazepine sedatives or hypnotics | Zolpidem, eszopiclone, rozerem, and zaleplon
Opioid antagonists | Naltrexone
Other second-generation antidepressants | Bupropion, mirtazapine, nefazodone, and trazodone
Second-generation (atypical) antipsychotics | Olanzapine and risperidone
Selective serotonin reuptake inhibitors | Escitalopram, fluoxetine, fluvoxamine, paroxetine, and sertraline
Serotonin and norepinephrine reuptake inhibitors | Duloxetine, desvenlafaxine, and venlafaxine
Steroids | Hydrocortisone
Tricyclic antidepressants | Imipramine, amitriptyline, and desipramine

PTSD = posttraumatic stress disorder

### Emerging Interventions

In addition to traditional psychological and pharmacological interventions, a growing number of interventions and approaches derived from CAM, such as dietary supplements, yoga, and guided imagery,72 or from different practice models of partnerships between mental health and other medical specialties, such as collaborative care,73 are emerging. Use of such practices to prevent PTSD is relatively novel. Thus, their efficacy remains unclear.

## Prevention Intervention Outcomes

Two primary outcomes in the prevention of PTSD are (1) incidence of PTSD diagnosis and (2) severity of PTSD symptoms that are assessed by both clinician-rated and self-reported measures. Appendix A, at the end of this report, describes each of the PTSD measures in detail. Some commonly used instruments are listed in the Methods section of this report.

In addition to preventing PTSD and reducing the severity of PTSD symptoms, other outcomes used in practice for evaluating the management of patients at risk of or with the diagnosis of PTSD include incidence and severity of comorbid psychiatric symptoms and conditions; quality of life; return to work or active duty; incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide); incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide); and perceived utility (subjective sense of helpfulness of the intervention).

## Scope and Key Questions

### Scope of the Review

Psychological trauma is common and leads to PTSD in a substantial number of adults exposed to trauma. Prevention of PTSD or reduction of PTSD symptom severity can potentially reduce a significant burden of individual and societal suffering. Despite evidence that some interventions are not effective for the prevention of PTSD, or might even cause harm, they are still widely used. Such use indicates that uncertainty and controversy still exist within the field about providing an intervention that intuitively seems as if it should help and that not enough consideration is given to scientific evidence when weighing intervention benefits and harms.

This review compares the efficacy, effectiveness, and harms of psychological, pharmacological, and emerging interventions for the prevention of PTSD and the reduction of PTSD symptom severity in adults. Highlighting the timeliness and relevance of this topic, the Institute of Medicine (IOM) and various Federal agencies (e.g., the U.S. Department of Veterans Affairs [VA] Health Administration) have identified PTSD as a priority area for quality improvement and comparative effectiveness research.17,23,74 Increased attention on prevention of PTSD is based, in part, on evidence of higher rates of PTSD among service members returning from operations in Afghanistan and Iraq than previously reported and their increased need for mental health services.22

Although most of the newer research on PTSD prevention has focused on targeted prevention, our report focuses on both universal and targeted prevention interventions. There have been several meta-analyses reporting that debriefing, the most widely studied universal prevention intervention, does not reduce PTSD. However, debriefing is not the only universal prevention intervention. Findings from studies of other psychological interventions using the universal prevention model, such as Battlemind training, an intervention developed for returning military service members, have been reported but never evaluated by a systematic review. Studies of medications, based on the universal prevention approach, have also been reported but never evaluated by a systematic review. Therefore, in this report, we included studies of both universal prevention as well as studies using the targeted prevention approach.

Our report focuses on interventions that have been used in clinical practice for the prevention of PTSD; they may or may not include interventions currently used to treat PTSD. We also address the clinical importance of effect modifiers or subgroup status that may affect the impact of traumatic exposure; these include sex, comorbidities, refugee status, and military or civilian status.

Our report is limited to adults who were exposed to psychological trauma and who received an intervention designed to prevent the development of PTSD within the first 3 months after the trauma (i.e., early in the clinical situation). This report does not address treatment of individuals who have been diagnosed with PTSD.

### Key Questions

We approach each Key Question (KQ) by considering the relevant Populations, Interventions, Comparators, Outcomes, Timing, and Settings (PICOTS). In this review, we address the following four KQs:

KQ 1 For adults exposed to psychological trauma, what is the efficacy or comparative effectiveness (or both) of early interventions to prevent PTSD or to improve health outcomes?
KQ 2 For adults exposed to psychological trauma, does timing, intensity, or dosage of intervention have an impact on the effectiveness or harms of approaches to prevent PTSD or to improve health outcomes?
KQ 3 For adults exposed to psychological trauma, how does efficacy, effectiveness, or harms of early interventions to prevent PTSD differ for characteristics of traumatic exposure or subpopulations with respect to:
  - Demographic groups (defined by age, ethnic and racial groups, and sex),
  - Psychiatric comorbidities, or
  - Personal risk factors for developing PTSD (e.g., having a diagnosis of acute stress disorder vs. not having the diagnosis)?
KQ 4 For adults exposed to psychological trauma, what are the absolute and comparative risks of harms from early interventions to prevent PTSD?

Figure 1 depicts the analytic framework for the comparative effectiveness of psychological and pharmacological interventions for the prevention of PTSD in adults following exposure to a traumatic event. KQs are displayed within the context of the PICOTS described in the previous section. Beginning with a population of adults exposed to psychological trauma, the figure illustrates the general and comparative effects of early preventive interventions on incidence of PTSD and health outcomes, including incidence and severity of trauma-related symptoms; incidence and severity of coexisting conditions; quality of life; quality of interpersonal and social functioning; ability to return to work or active duty; incidence of self-injurious or suicidal thoughts, attempts, or behaviors including suicide; incidence of aggressive or homicidal thoughts, attempts, or behaviors including homicide; perceived utility; and resilience (KQ 1). Timing, intensity, and dosage of intervention as potential moderators of these interventions are explored in KQ 2. Characteristics of traumatic exposure and subgroups within the overall population identified based on age, sex, race and ethnicity, psychiatric comorbidities, and personal risk factors (e.g., a history of child abuse) of PTSD as effect modifiers of these interventions are explored in KQ 3. Finally, KQ 4 addresses the absolute and comparative risks of harms and adverse events from these interventions.

Figure 1 Analytic framework for comparative effectiveness of interventions to prevent PTSD in adults after exposure to psychological trauma

KQ = Key Question; PTSD = posttraumatic stress disorder

Figure 1: This figure depicts the analytic framework for the comparative effectiveness of psychological, pharmacological, and emerging interventions to prevent posttraumatic stress disorder (PTSD) in adults following exposure to psychological trauma. The Key Questions are displayed within the context of the population, intervention, comparator, outcome, timing, and setting described in the previous section. Beginning with a population of adults exposed to psychological trauma, the figure illustrates the efficacy and comparative effects of early preventive interventions on incidence of PTSD or health outcomes, including incidence and severity of trauma-related symptoms, incidence and severity of comorbid conditions, quality of life, quality of interpersonal or social functioning, ability to return to work or duty, incidence of self-injurious or suicidal thoughts, attempts, or behaviors including suicide, incidence of aggressive or homicidal thoughts, attempts, or behaviors including homicide, perceived utility of intervention, and resilience (Key Question 1). Timing, intensity, and dosage of intervention as potential moderators of these interventions are explored in Key Question 2. Characteristics of traumatic exposure and subgroups within the overall population identified based on age, sex, race and ethnicity, psychiatric comorbidities, and personal risk factors of PTSD as potential moderators of these interventions are explored in Key Question 3. Finally, Key Question 4 addresses the absolute and comparative risks of harms and adverse events from these interventions.

## Organization of This Report

The remainder of this report describes our methods, presents the results of our synthesis of the literature, discusses our conclusions, and provides other information relevant to the interpretation of this work. The Methods section describes our scientific approach for this comparative effectiveness review in detail. The Results section presents our findings for all four of the KQs and includes summary tables. In the Discussion section, we summarize the findings, present the strength of the evidence for critical comparisons or outcomes, and discuss the implications for clinical practice and further research. A complete list of references, acronyms, and abbreviations follows the Discussion section.

This report contains the following appendixes: Appendix A contains detailed descriptions of each of the PTSD measures used in all studies included at the full text level. Appendix B contains the exact search strings we used in our literature searches. Appendix C documents the full-text review and data abstraction forms, including our criteria for rating risk of bias of individual studies. Studies excluded at the stage of reviewing full-text articles with reasons for exclusion are presented in Appendix D. Evidence tables appear in Appendix E. Appendix F lists studies rated high risk of bias and reasons for excluding them from relevant KQ analyses. Strength of evidence tables appear in Appendix G. Quantitative sensitivity analyses are presented in Appendix H. Appendix I lists acronyms used in the report.