# Peer Reviewers

Prior to publication of the final evidence report, the EPC sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential non-financial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential non-financial conflicts of interest identified.

The list of Peer Reviewers follows:

- Naomi Breslau, Ph.D.
  Professor of Epidemiology
  Michigan State University
  East Lansing, MI
- Christine Courtois, Ph.D.
  Principal and Founder of Courtois & Associates, P.C.
  Trauma Treatment, Life Transitions, and Wellness Services
  Washington, DC
- Jonathan R. Davidson, M.D.
  Professor Emeritus, Psychiatry-Psychiatry & Behavioral Sciences
  Director, Anxiety and Traumatic Stress Program
  Duke University Medical Center
  Durham, NC
- Brett Litz, Ph.D.
  Professor, Department of Psychiatry, Boston University School of Medicine and
  Psychology Department at Boston University
  Director, Mental Health Core of the Massachusetts Veterans
  Epidemiological Research and Information Center
  V.A. Boston Healthcare System
  Boston, MA
- Barbara O. Rothbaum, Ph.D.
  Department of Psychiatry
  Trauma and Anxiety Recovery Program (TARP)
  Emory University School of Medicine
  Atlanta, GA