# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Jonathan R. Davidson, M.D.
  Professor Emeritus, Psychiatry–Psychiatry & Behavioral Sciences
  Director, Anxiety and Traumatic Stress Program
  Duke University Medical Center
  Durham, NC
- Laura Fochtmann, M.D.
  Medical Editor, American Psychiatric Association Practice Guidelines
  Professor, Psychiatry and Director of the ECT Service
  Stony Brook University Medical Center
  Stony Brook, NY
- Matthew J. Friedman, M.D., Ph.D.
  Executive Director, National Center for Posttraumatic Stress Disorder
  U.S. Department of Veterans Affairs
  Professor of Psychiatry and of Pharmacology and Toxicology
  Dartmouth Medical School
  Hanover, NH
- Daniel I. Galper, Ph.D.
  Director of Research & Special Projects
  American Psychological Association
  Washington, DC
- Terence M. Keane, Ph.D.
  Professor, Psychiatry and Assistant Dean for Research
  Boston University School of Medicine
  Director, National Center for PTSD–Behavioral Sciences Division
  Associate Chief of Staff, Research & Development
  VA Boston Healthcare System
  Boston, MA