# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Christine Courtois, Ph.D.
  Principal and Founder of Courtois & Associates, PC
  Trauma Treatment, Life Transitions, and Wellness Services
  Washington, DC
- Jonathan R. Davidson, M.D.
  Professor Emeritus, Psychiatry-Psychiatry & Behavioral Sciences and
  Director, Anxiety and Traumatic Stress Program
  Duke University Medical Center
  Durham, NC
- Laura Fochtmann, M.D.
  Medical Editor, American Psychiatric Association Practice Guidelines
  Professor, Psychiatry and Director of the ECT Service
  Stony Brook University Medical Center
  Stony Brook, NY
- Matthew J. Friedman, M.D., Ph.D.
  Executive Director, National Center for Posttraumatic Stress Disorder
  U.S. Department of Veterans Affairs
  Professor, Psychiatry and Pharmacology and Toxicology
  Dartmouth Medical School
  Hanover, NH
- Daniel I. Galper, Ph.D.
  Director, Research & Special Projects
  American Psychological Association
  Washington, DC
- Rachel Kimerling, Ph.D.
  National Center for Posttraumatic Stress Disorder
  VA Palo Alto Health Care System
  Center for Health Care Evaluation
  Palo Alto, CA