# Acknowledgments

We gratefully acknowledge the support of various past and present AHRQ staff including: our current AHRQ Task Order Officer and the Director of the Evidence-based Practice Program, Stephanie Chang, M.D., M.P.H.; Margaret Coopey, R.N., M.G.A., M.P.S.; our former AHRQ Task Order Officers, Steven Fox, M.D., S.M., M.P.H., and Sonia Tyutyulkova, M.D., Ph.D.; and our Associate Editor, Margaret Maglione, M.P.P. We extend our appreciation to our Key Informants and members of our Technical Expert Panel (listed below), all of whom provided thoughtful advice and input during our research process.

The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC staff at RTI International and the University of North Carolina at Chapel Hill. We express our gratitude to the following individuals for their contributions to this project: Megan Van Noord, M.S.L.S., and Christiane Voisin, our EPC librarians; Sharon Barrell, M.A., editor; Loraine Monroe, our EPC publications specialist; Elizabeth Harden, M.P.H. and Andrea Yuen, B.S., who reviewed articles for eligibility and completed data abstractions; and Claire Baker, who aided us in retrieving full-text literature.