# Abbreviations and Acronyms

5-HT: 5-hydroxytryptamine
AHRQ: Agency for Healthcare Research and Quality
AMPA: alpha-amino-3-hydroxy-5-methyl-4-isoxazolepropionic acid
ASD: Acute stress disorder
ASDI: Acute Stress Disorder Interview
BAI: Beck Anxiety Inventory
BDI: Beck Depression Inventory
BDI-2: Beck Depression Inventory-2
BOCF: baseline observation carried forward
BPM: beats per minute
CABG: coronary artery bypass grafting
CAM: Complementary and alternative medicine
CAPS: Clinician Administered PTSD Scale
CAPS-2: Clinician Administered PTSD Scale-2
CBT: Cognitive behavioral therapy
CBT+Hypnosis: CBT combined with hypnosis
CC: Collaborative care
CER: comparative effectiveness review
CI: Confidence interval
CIDI-PTSD: Composite International Diagnostic Interview PTSD module
CINAHL: Cumulative Index to Nursing and Allied Health Literature
CISD: Critical incident stress debriefing
CISM: Critical incident stress management
COPD: Chronic obstructive pulmonary disease
COPE: Creating Opportunities for Parent Empowerment
CPT: Cognitive processing therapy
CR: Cognitive restructuring
CRF: corticotropin-releasing
CT: Cognitive therapy
DASS: Depression and Anxiety Stress Scales
DASS-21: Depression and Anxiety Stress Scales-21
DSM-IV-TR: Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition, Text Revision
Educ: educational
EMBASE: Excerpta Medica Database
EMDR: Eye movement desensitization and reprocessing therapy
EPDS: Edinburgh Postnatal Depression Scale
GABA: gamma-aminobutyric acid
GHQ-12: 12-item General Health Questionnaire
HADS-A: Hospital Anxiety and Depression Rating Scale-Anxiety subscale
HADS: Hospital Anxiety and Depression Rating Scale
HPA: hypothalamic-pituitary-adrenal
ICU: intensive care unit
IES: Impact of Event Scale
IES-A: Impact of Event Scale-Avoidance subscale
IES-I: Impact of Event Scale-Intrusion subscale
IES-R: Impact of Event Scale-Revised
IOM: Institute of Medicine
IPA: International Pharmaceutical Abstracts
IPT: Interpersonal therapy
ITT: intention-to-treat analysis
KQ: Key Question
LOCF: last observation carried forward
MAOIs: Monoamine oxidase inhibitors
MeSH: Medical Subject Headings
MIDI: Migraine Disability Index Post-Traumatic Stress Disorder
MINI-PTSD: Mini-International Neuropsychiatric Interview-Post-Traumatic Stress Disorder Module
MVA: Motor vehicle accidents
n: Number of participants
NA: not applicable
NCS-R: National Comorbidity Survey - Replication
NMDA: N-methyl-d-aspartate
NNT: number needed to treat
NR: not reported
NRCT: nonrandomized controlled trial
NS: not significant
NVVRS: National Vietnam Veterans Readjustment Survey
POD: post-operative day
PCL: Posttraumatic Stress Disorder Checklist
PCL-C: Posttraumatic Stress Disorder Checklist-Civilian Version
PDS: Posttraumatic Stress Diagnostic Scale
PE: Prolonged exposure therapy
PFA: Psychological first aid
PHQ-9: Patient Health Questionnaire, 9-item version
PHQ-Depression: Patient Health Questionnaire for Depression
PHSI-P: Post-Hospital Stress Index for Parents
PICOTS: Populations, Interventions, Comparators, Outcomes, Timing, and Settings
PILOTS: Published International Literature on Traumatic Stress
POMS: Profile of Mood States
PRISMA: Preferred Reporting Items for Systematic Review and Meta-analyses
PSDS-SR: Posttraumatic Stress Diagnostic Scale-Self Report
PSS: Posttraumatic Stress Scale
PSS-SR: Posttraumatic Stress Diagnostic Scale-Self Report
PTSD: Prevention of Posttraumatic Stress Disorder
PTSS-10: Posttraumatic Stress Symptom 10 Question Inventory
QOL: quality of life
RCT: randomized controlled trial
RR: relative risk
SC: Supportive counseling
SD: standard deviation
SE: standard error
SF-36: Medical Outcomes Study Health Survey – Short Form 36
SHB: Self-help booklet
SIPs: Scientific Information Packets
SI-PTSD: Structured Interview for PTSD
SMD: standardized mean difference
SNRIs: Serotonin and norepinephrine reuptake inhibitors
SOE: strength of evidence
SRC: Scientific Resource Center
SSRI: Selective serotonin reuptake inhibitor(s)
STAI: State-Trait Anxiety Inventory
TCAs: Tricyclic antidepressants
TEP: Technical Expert Panel
TISS: Therapeutic Intervention Scoring System
TRiM: Trauma Risk Management
UC: Usual care
VA/DoD: US Department of Veterans Affairs and Department of Defense
UK: United Kingdom
UN: United Nations
US: United States
USPSTF: U.S. Preventive Services Task Force
W-DEQ: Wijma Delivery Expectancy/Experience Questionnaire
WL: waitlist
WMD: Weighted mean difference
WTCD: World Trade Center Disasters
yr(s): year(s)