# Psychological, Pharmacological, and Emerging Interventions: Strength-of-Evidence Grades

## Key Question 1

Table G1 Cognitive behavioral therapy compared with an inactive comparator (usual care)

Outcome: Number of Studies; Number of Subjects; Design | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD at 6 months: 1; 46; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT vs. UC, CAPS, 9% vs. 55%, p<0.05 | Insufficient
Incidence of PTSD at 12 months: 1; 46; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT vs. UC, CAPS, 21% vs. 58%, p<0.05 | Insufficient
PTSD symptom severity at 6 months: 1; 46; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT vs. UC, CAPS total, 31.95 vs. 52.45, p<0.05 | Insufficient
PTSD symptom severity at 12 months: 1; 46; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT vs. UC, CAPS total, 25.26 vs. 52.50, p<0.05; Cohen’s d (95% CI) = 1.11 (0.34 to 1.88) | Insufficient
Incidence of major depression at 6 months: 1; 46; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT vs. UC, MINI MDE, 18% vs. 45%, p=NS | Insufficient
Incidence of major depression at 12 months: 1; 46; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT vs. UC, MINI MDE, 11% vs. 50%, p<0.05 | Insufficient
Incidence of an anxiety disorder at 6 months: 1; 46; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT vs. UC, MINI, 18% vs. 30%, p=NS | Insufficient
Incidence of an anxiety disorder at 12 months: 1; 46; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT vs. UC, MINI, 11% vs. 7%, p=NS | Insufficient
Depression symptom severity at 6 months: 1; 46; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT vs. UC, BDI, 12.24 vs. 31.20, p<0.05 | Insufficient
Depression symptom severity at 12 months: 1; 46; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT vs. UC, BDI, 13.95 vs. 29.00, p<0.05, Cohen’s d = 1.45 (0.69 to 2.21) | Insufficient
Anxiety symptom severity at 6 months: 1; 46; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT vs. UC, HADS-A, 6.38 vs. 11.87, p<0.05 | Insufficient
Anxiety symptom severity at 12 months: 1; 46; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT vs. UC, HADS-A, 7.84 vs. 11.00, p<0.05, Cohen’s d (95% CI) = 0.76 (0.06 to 1.46) | Insufficient
Quality of Life: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide) 0; 0 | NA | NA | NA | NA | NA | Insufficient
Perceived utility: 0; 0 | NA | NA | NA | NA | NA | Insufficient

a Downgraded due to lack of blinding

b Small sample size (< 300 observations)

Abbreviations: BDI = Beck Depression Inventory; CAPS = Clinician Administered PTSD Scale; CBT = Cognitive behavioral therapy; CI = confidence interval; HADS-A = Hospital Anxiety and Depression Scale-Anxiety subscale; MDE = Major Depressive Episode; MINI = Mini International Neuropsychiatric Interview; NA = not applicable; NS = not significant; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial; UC = Usual care

Table G2 Cognitive therapy compared with an inactive comparator (waitlist)

Outcome: Number of Studies; Number of Subjects; Design | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD at end of treatment: 1; 60; RCT | Low | Unknown, single study | Direct | Imprecise^b^ | CT vs. WL, CAPS-2, 63% vs. 77%, p=NR | Insufficient
Incidence of PTSD at 5 months: 1; 112; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CT vs. WL, CAPS, 20.0% vs. 58.7%, p=0.002 | Insufficient
PTSD symptom severity at end of treatment: 1; 60; RCT | Low | Unknown, single study | Direct | Imprecise^b^ | CT vs. WL, CAPS-2 total, 43.0 vs. 55.9, p=NR; IES-I, 17.7 vs. 22.1, p=NR; IES-A, 17.1 vs. 22.6, p=NR | Insufficient
PTSD symptom severity at 5 months: 1; 112; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CT vs. WL, CAPS total, 29.5 vs. 50.6, p=NR; CAPS re-experiencing, 6.9 vs. 11.8, p=NR; CAPS avoidance, 12.1 vs. 22.3, p=NR; CAPS hyperarousal, 10.5 vs. 16.5, p=NR; PSS-SR total, 11.6 vs. 22.1, p=NR | Insufficient
Depression symptom severity at end of treatment: 1; 60; RCT | Low | Unknown, single study | Direct | Imprecise^b^ | CT vs. WL, BDI-2, 18.9 vs. 21.9; p=NS | Insufficient
Anxiety symptom severity at end of treatment: 1; 60; RCT | Low | Unknown, single study | Direct | Imprecise^b^ | CT vs. WL, BAI, 23.4 vs. 19.6, p=NS | Insufficient
Incidence/severity of comorbid conditions: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide) 0; 0 | NA | NA | NA | NA | NA | Insufficient
Perceived utility: 0; 0 | NA | NA | NA | NA | NA | Insufficient

a No ITT; completer analysis of 133 randomized participants

b Small sample size (< 300 observations)

Abbreviations: BAI = Beck Anxiety Inventory; BDI-2 = Beck Depression Inventory-2; CAPS/CAPS-2 = Clinician Administered PTSD Scale/Clinician Administered PTSD Scale-2; CI = confidence interval; CT = Cognitive therapy; IES-A = Impact of Event-Avoidance subscale; IES-I = Impact of Event-Intrusion subscale; ITT = intent to treat analysis; NA = not applicable; NR = not reported; NS = not significant; PSS-SR = PTSD Symptom Scale-Self Report; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial; WL = Waitlist

Table G3 Debriefing compared with inactive control condition

Outcome: Number of Studies; Number of Subjects; Design | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD at 2 weeks: 1; 236; RCT | Low | Unknown, single study | Direct | Imprecise^a^ | Debriefing vs. control, SI-PTSD, data=NR^b^, p=NR | Insufficient
Incidence of PTSD at 6 weeks: 1; 236; RCT | Low | Unknown, single study | Direct | Imprecise^a^ | Debriefing vs. control, SI-PTSD, data=NR^b^, p=NR | Insufficient
Incidence of PTSD at 6 months: 2; 341; RCT | 1 Low; 1 Medium^c, d^ | Consistent | Direct | Imprecise^e^ | Debriefing vs. control, SI-PTSD, PSS-SR, data=NR^b^, p=NR Debriefing vs. Assessment only, 23% vs. 26%, p=NS | Low
PTSD symptom severity at 2 weeks: 1; 236; RCT | Low | Unknown, single study | Direct | Imprecise^a^ | Debriefing vs. control, SI-PTSD, Emotional debriefing (18.1), Educational debriefing (16.2), Control (15.9), p=NR^f^ | Insufficient
PTSD symptom severity at 6 weeks: 1; 236; RCT | Low | Unknown, single study | Direct | Imprecise^a^ | Debriefing vs. control, SI-PTSD, Emotional debriefing (14.4), Educational debriefing (11.9), Control (10.5), p=NR^f^ | Insufficient
PTSD symptom severity at 6 months: 2; 341; RCT | 1 Low; 1 Medium^c, d^ | Consistent | Direct | Imprecise^g^ | Debriefing vs. control, SI-PTSD, Emotional debriefing (10.2), Educational debriefing (9.3), Control (9.6), p=NR^f^ Debriefing vs. Assessment only, PSS-SR: 13.8 vs. 13.0, p=NR; IES: 19.7 vs. 23.3, p=NR | Low
Depression symptom severity at 2 weeks: 1; 236; RCT | Low | Unknown, single study | Direct | Imprecise^a^ | Debriefing vs. control, HADS-D, Emotional debriefing (5.7), Educational debriefing (4.7), Control (4.5), p=NR^f^ | Insufficient
Depression symptom severity at 6 weeks: 1; 236; RCT | Low | Unknown, single study | Direct | Imprecise^a^ | Debriefing vs. control, HADS-D, Emotional debriefing (4.3), Educational debriefing (3.3), Control (3.7), p=NR^f^ | Insufficient
Depression symptom severity at 6 months: 2; 341; RCT | 1 Low; 1 Medium^c, d^ | Consistent | Direct | Imprecise^g^ | Debriefing vs. control, HADS-D, Emotional debriefing (3.8), Educational debriefing (3.2), Control (3.2), p=NR^f^ Debriefing vs. Assessment only, BDI, 12.1 vs. 13.9, p=NS | Low
Anxiety symptom severity at 2 weeks: 1; 236; RCT | Low | Unknown, single study | Direct | Imprecise^a^ | Debriefing vs. control, HADS-A, Emotional debriefing (7.6), Educational debriefing (6.6), Control (6.4), p=NR^f^ | Insufficient
Anxiety symptom severity at 6 weeks: 1; 236; RCT | Low | Unknown, single study | Direct | Imprecise^a^ | Debriefing vs. control, HADS-A, Emotional debriefing (5.6), Educational debriefing (5.1), Control (4.7), p=NR^f^ | Insufficient
Anxiety symptom severity at 6 months: 1; 236; RCT | Low | Unknown, single study | Direct | Imprecise^a^ | Debriefing vs. control, HADS-A, Emotional debriefing (5.0), Educational debriefing (4.4), Control (4.6), p=NR^f^ | Insufficient
Incidence/severity of comorbid conditions: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide) 0; 0 | NA | NA | NA | NA | NA | Insufficient
Perceived utility at 6 months: 1; 105; RCT | Medium^c, h^ | Unknown, single study | Indirect | Imprecise^a^ | Debriefing vs. Assessment only, data=NR, p=NS | Low

a Small sample size (< 300 observations)

b Text states “no significant differences between the three intervention groups”; however, the data are reported only for the sample as a whole (week 2 = 5.4%, week 6 = 4.9%; 6 month = 4.8%) rather than by treatment group

c Groups differed on some baseline measures; completer analysis for follow-up assessments

d Due to very high overall attrition (i.e., greater than 40% at 11-month followup) in one of these studies, we considered all of its outcomes collected at that timepoint as having a high risk of bias and therefore do not report them

e One study stated that incidence was not different between treatment groups; however, no data were reported to support this statement

f Mixed-model analysis performed on entire sample indicated no group differences; however, no pairwise post-hoc comparisons were reported

g Different instruments used to assess symptoms

h Due to very high overall attrition (i.e., greater than 40% at 11-month followup) in this study, we considered all of its outcomes collected at that timepoint as having a high risk of bias and therefore do not report them

Abbreviations: BDI = Beck Depression Inventory; CAPS = Clinician Administered PTSD Scale; CI = confidence interval; HADS-A = Hospital Anxiety and Depression Scale-Anxiety subscale; HADS-D = Hospital Anxiety and Depression Scale-Depression subscale; IES = Impact of Event Scale; NA = not applicable; NR = not reported; NS = not significant; PSS-SR = Post-traumatic Symptom Scale - Self-Report; PTSD = posttraumatic stress disorder; RCT = Randomized control trial; SI-PTSD = Structured Interview for PTSD; UC = Usual care

Table G4 Prolonged exposure compared with inactive control condition

Outcome: Number of Studies; Number of Subjects; Design | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD at 4 weeks: 1; 137; RCT | Medium | Unknown, single study | Direct | Imprecise^b^ | PE vs. Assessment only, PSS-I, 41% vs. 51%, p=0.60 | Insufficient
Incidence of PTSD at end of treatment: 1; 60; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | PE vs. WL, CAPS-2, 33% vs. 77%, p<0.001 | Insufficient
Incidence of PTSD at 5 months: 1; 128; RCT | Medium^c^ | Unknown, single study | Direct | Imprecise^b^ | PE vs. WL, CAPS, 21.6% vs. 57.1%, p<0.003^d^ | Insufficient
PTSD symptom severity at end of treatment: 1; 60; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | PE vs. WL, CAPS-2 total, 31.5 vs. 55.9, p<0.001; IES-I, 12.4 vs. 22.1, p<0.002; IES-A, 11.7 vs. 22.6, p<0.001 | Insufficient
PTSD symptom severity at 5 months: 1; 135; RCT | | Unknown, single study | Direct | Imprecise^b^ | PE vs. WL, CAPS total, 28.6 vs. 50.6, p=NR; CAPS re-experiencing, 7.3 vs. 11.8, p=NR; CAPS avoidance, 11.4 vs. 22.3, p=NR; CAPS hyperarousal, 9.9 vs. 16.5, p=NR; PSS-SR total, 11.0 vs. 22.1, p=NR | Insufficient
Incidence of depression at 4 weeks: 1; 137 | Medium | Unknown, single study | Direct | Imprecise^b^ | PE vs. Assessment only, BDI-2 > 13, 49% vs. 68%, p=0.08 | Insufficient
Depression symptom severity at 4 weeks: 1; 137 | Medium | Unknown, single study | Direct | Imprecise^b^ | PE vs. Assessment only, BDI-2, 15.4 vs. 21.4, p<0.05 | Insufficient
Depression symptom severity at end of treatment: 1; 60; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | PE vs. WL, BDI-2, 12.1 vs. 21.9, p=0.03 | Insufficient
Anxiety symptom severity at end of treatment: 1; 60; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | PE vs. WL, BAI, 13.4 vs. 19.6, p=0.03 | Insufficient
Incidence of comorbid conditions: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide) 0; 0 | NA | NA | NA | NA | NA | Insufficient
Perceived utility: 0; 0 | NA | NA | NA | NA | NA | Insufficient

a Attrition was high for the study overall (> 20%) and differed across groups by > 15%

b Small sample size (< 300 observations)

c No ITT; completer analysis of 156 randomized participants; high attrition; differential attrition across groups

d Stratified pairwise comparison

Abbreviations: BAI = Beck Anxiety Inventory; BDI-2 = Beck Depression Inventory-2; CAPS/CAPS-2 = Clinician Administered PTSD Scale/Clinician Administered PTSD Scale-2; CI = confidence interval; CR = Cognitive restructuring; CT = Cognitive therapy; IES-A = Impact of Event-Avoidance subscale; IES-I = Impact of Event-Intrusion subscale; ITT = intent to treat analysis; NA = not applicable; NR = not reported; NS = not significant; PE = Prolonged exposure therapy; PSS-I = PTSD Symptom Scale-Interview; PSS-SR = PTSD Symptom Scale-Self-Report; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial; WL = Waitlist

Table G5 Psychoeducation compared with inactive control condition

Outcome: Number of Studies; Number of Subjects; Design | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD at 1 month: 1; 79; RCT | Medium^a, b^ | Unknown, single study | Direct | Imprecise^c^ | Psychoeducation vs. control, PCL, 46% vs. 51% | Insufficient
Incidence of PTSD at 6 months: 1; 103; RCT | Medium^a, b^ | Unknown, single study | Direct | Imprecise^c^ | Psychoeducation vs. Assessment only, PSS-SR, 11% vs. 26%, p=NR | Insufficient
PTSD symptom severity at 6 months: 1; 103; RCT | Medium^a, b^ | Unknown, single study | Direct | Imprecise^c^ | Psychoeducation vs. Assessment only, PSS-SR, 10.9 vs. 13.0, p=NR; IES, 16.7 vs. 23.3, p=NR | Insufficient
Depression symptom severity at 6 months: 1; 103; RCT | Medium^a, b^ | Unknown, single study | Direct | Imprecise^c^ | Psychoeducation vs. Assessment only, BDI, 9.8 vs. 13.9, p=NR | Insufficient
Incidence/severity of comorbid conditions: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Perceived utility: 0; 0 | NA | NA | NA | NA | NA | Insufficient

a Groups differed on some baseline measures; completer analysis for follow-up assessments

b Due to very high overall attrition (i.e., greater than 40% at 11-month followup) in this study, we considered all outcomes collected at that timepoint as having a high risk of bias and therefore do not report them

c Small sample size

Abbreviations: BDI = Beck Depression Inventory; CI = confidence interval; IES = Impact of Event Scale; NA = not applicable; NR = not reported; NS = Not significant; PCL = = PTSD Checklist; PSS-SR = Post-traumatic Stress Disorder Symptom Scale-Self-Report; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial

Table G6 Self Help Booklet compared with an inactive comparator (Information Booklet)

Outcome: Number of Studies; Number of Subjects; Design | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD: 0; 0 | NA | NA | NA | NA | NA | Insufficient
PTSD symptom severity at 3 month follow-up: 1; 49; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | SHB vs. Information only control, PSDS-SR, 5.43 vs. 9.46; PSDS-SR change, Cohen’s d = −0.59 vs. −0.16, p<0.05 | Insufficient
PTSD symptom severity at 6 month follow-up: 1; 49; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | SHB vs. Information only control, PSDS-SR, 6.78 vs. 8.98; PSDS-SR change, Cohen’s d = −0.47 vs. −0.13, p=NR | Insufficient
Depression symptom severity at 3 months: 1; 49; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | SHB vs. Information only control, DASS-Depression, 7.8 vs. 7.0, p=NR | Insufficient
Depression symptom severity at 6 months: 1; 49; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | SHB vs. Information only control, DASS-Depression, 8.1 vs. 6.4, p=NR | Insufficient
Anxiety symptom severity at 3 months: 1; 49; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | SHB vs. Information only control, DASS-Anxiety, 7.5 vs. 7.2, p=NR | Insufficient
Anxiety symptom severity at 6 months: 1; 49; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | SHB vs. Information only control, DASS-Anxiety, 8.0 vs. 7.0, p=NR | Insufficient
Incidence/severity of comorbid conditions: 0; 0 | NA | NA | NA | NB | NA | Insufficient
Quality of Life at 3 months: 1; 49; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | SHB vs. Information only control, Global QOL, 66.6 vs. 67.8, p=NR | Insufficient
Quality of Life at 6 months: 1; 49; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | SHB vs. Information only control, Global QOL, 69.0 vs. 72.2, p=NR | Insufficient
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide) 0; 0 | NA | NA | NA | NA | NA | Insufficient
Perceived utility: 0; 0 | NA | NA | NA | NA | NA | Insufficient

a Unblinded

b Small sample size (< 300 observations)

Abbreviations: CI = confidence interval; DASS = Depression Anxiety and Stress Scale-21; Info = Information booklet; NA = not applicable; NR = not reported; PSDS-SR = Posttraumatic Stress Diagnostic Scale-Self Report; PTSD = posttraumatic stress disorder; QOL = Quality of life (European Organisation for Research and Treatment of Cancer quality of life core questionnaire); RCT = randomized controlled trial; SHB = Self-help booklet

Table G7 Stepped collaborative care intervention compared with usual care

Outcome: Number of Studies; Number of Subjects; Design | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD at 12 months: 1; 207; RCT | Low | Unknown, single study | Direct | Imprecise^a^ | CC vs. UC, CAPS, OR (95% CI) = 1.39 (0.77 to 2.51), p<0.05 | Insufficient
PTSD symptom severity at 1 month; 1; 207; RCT | Low | Unknown, single study | Direct | Imprecise^a^ | CC vs. UC, PCL-C total, 50.2 vs. 51.1, p=NS | Insufficient
PTSD symptom severity at 3 months; 1; 207; RCT | Low | Unknown, single study | Direct | Imprecise^a^ | CC vs. UC, PCL-C total, 45.9 vs. 48.6, p=NS | Insufficient
PTSD symptom severity at 6 months: 1; 207; RCT | Low | Unknown, single study | Direct | Precise | CC vs. UC, CAPS total, 42.9 vs. 56.7, p<0.01 CC vs. UC, PCL-C total, 40.6 vs. 49.9, p<0.01 | Low
PTSD symptom severity at 9 months: 1; 207; RCT | Low | Unknown, single study | Direct | Precise | CC vs. UC, PCL-C total, 40.2 vs. 45.5, p<0.01; | Low
PTSD symptom severity at 12 months: 1; 207; RCT | Low | Unknown, single study | Direct | Precise | CC vs. UC, CAPS total, 38.6 vs. 47.2, p<0.05 CC vs. UC, CAPS group-by-time interaction, greater decrease in PTSD severity in CC (p<0.01) CC vs. UC, PCL-C total, 37.4 vs. 42.5, p<0.05 CC vs. UC, PCL-C group-by-time interaction, greater decrease in PTSD severity in CC (p<0.001) | Low
Severity of major depression at 12 months: 1; 207; RCT | Low | Unknown, single study | Direct | Imprecise^a^ | CC vs. UC, PHQ-9, 8.4 vs. 10.1, p=NS | Insufficient
Alcohol use at 12 months: 1; 207; RCT | Low | Unknown, single study | Direct | Imprecise^a^ | CC vs. UC, AUDIT, 2.0 vs. 2.4, p=NS | Insufficient
Functional impairment at 12 months: 1; 207; RCT | Low | Unknown, single study | Direct | Imprecise^a^ | CC vs. UC, SF-36, 43.7 vs. 41.2, p=NS | Insufficient

a Not statistically significant

Abbreviations: AUDIT = Alcohol Use Disorders Identification Test; CAPS = Clinician Administered PTSD Scale; CC = collaborative care; NA = not applicable; NS = not significant; OR = odds ratio; PCL-C = PTSD Checklist-Civilian Version; PHQ-9 = Patient Health Questionnaire-9 item version; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial; SF-36 = 36-item Medical Outcomes Study Short Form; UC = usual care

Table G8 Supportive counseling compared with inactive control condition

Outcome: Number of Studies; Number of Subjects; Design | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD at 4–6 weeks: 1; 103; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | SC vs. control, MINI-PTSD, 34% vs. 30%, p=NS, RR (95% CI) = 1.15 (0.66 to 2.02) | Insufficient
Incidence of PTSD at 3 months: 1; 103; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | SC vs. control, MINI-PTSD, 6% vs. 17%, p=NS, RR (95% CI) = 0.35 (0.10 to 1.23) | Insufficient
PTSD symptom severity at 1 month: 1; 174; RCT | Medium^a, c^ | Unknown, single study | Direct | Imprecise^b^ | SC vs. control, PHSI-P, 7.2 vs. 7.3, p=NR | Insufficient
PTSD symptom severity at 3 months: 1; 174; RCT | Medium^a, c^ | Unknown, single study | Direct | Imprecise^b^ | SC vs. control, PHSI-P, 6.4 vs. 7.5, p=NR | Insufficient
PTSD symptom severity at 6 months: 2; 336; RCT | Medium^a^ Medium^a^ | Consistent | Direct | Imprecise^d^ | SC vs. control, PHSI-P, 5.8 vs. 7.2, p=NS; IES, 12.0 vs. 15.5, p=NS | Insufficient
PTSD symptom severity at 12 months: 1; 174; RCT | Medium^a, c^ | Unknown, single study | Direct | Imprecise^b^ | SC vs. control, PHSI-P, 5.9 vs. 7.9, p<0.05 | Insufficient
Depression symptom severity at 4–6 weeks: 1; 103; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | SC vs. control, EPDS > 12, 32% vs. 34%, p=NR | Insufficient
Depression symptom severity at 1 month: 1; 174; RCT | Medium^a, c^ | Unknown, single study | Direct | Imprecise^b^ | SC vs. control, POMS depression subscale, 2.6 vs. 4.1, p<0.05 | Insufficient
Depression symptom severity at 3 months: 2; 277; RCT | Medium^a^ Medium^a, c^ | Inconsistent | Direct | Imprecise^b^, ^d^ | SC vs. control, DASS-Depression >13, 6% vs. 26%, RR (95% CI) = 0.23 (0.07 to 0.76); EPDS > 12, 8% vs. 32%, p=0.002, RR (95% CI) = 0.25 (0.09 to 0.69); POMS depression subscale, 3.3 vs. 4.2, p=NS | Low
Depression symptom severity at 6 months: 2; 277; RCT | Medium^a^ Medium^a, c^ | Inconsistent | Direct | Imprecise^b^, ^d^ | SC vs. control, POMS depression subscale, 2.0 vs. 3.9, p<0.05; EPDS, 6.0 vs. 6.0, p=NS | Low
Depression symptom severity at 12 months: 1; 174; RCT | Medium^a, c^ | Unknown, singe study | Direct | Imprecise^b^ | SC vs. control, POMS depression subscale: 2.5 vs. 3.6, p=NS | Insufficient
Anxiety symptom severity at 1 month: 1; 174; RCT | Medium^a, c^ | Unknown, single study | Direct | Imprecise^b^ | SC vs. control, STAI, 35.7 vs. 39.8, p=NS | Insufficient
Anxiety symptom severity at 3 months: 2; 277; RCT | Medium^a^ Medium^a, c^ | Consistent | Direct | Imprecise^b^, ^d^ | SC vs. control, DASS-Anxiety > 9, 2% vs. 11%, p=NR, RR (95% CI) = 0.18 (0.02 to 1.45); STAI, 38.4 vs. 40.7, p=NS | Low
Anxiety symptom severity at 6 months: 1; 174; RCT | Medium^a, c^ | Unknown, single study | Direct | Imprecise^b^ | SC vs. control, STAI, 36.0 vs. 39.1, p=NS | Low
Anxiety symptom severity at 12 months: 1; 174; RCT | Medium^a, c^ | Unknown, single study | Direct | Imprecise^b^ | SC vs. control, STAI, 35.8 vs. 40.9, p<0.01 | Insufficient
Quality of Life: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Perceived utility at 3 months: 1; 50 | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | 86% rated the perceived utility of SC as 8 or higher on a 10-point scale | Insufficient
Perceived utility at 6 months: 1; 58; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | 71% reported SC completely met their expectation, and 60% reported SC fulfilled the main purpose | Insufficient

a Completer analysis only

b Small sample size (< 300 observations)

c High (> 20%) attrition overall; high (> 15%) differential attrition between groups

Abbreviations: CI = confidence interval; DASS = Depression Anxiety and Stress Scale-21; EPDS = Edinburgh Postnatal Depression Scale; IES = Impact of Event Scale; MINI-PTSD = Mini-International Neuropsychiatric Interview-Post-Traumatic Stress Disorder; NA = not applicable; NR = not reported; NS = not significant; PHSI-P = Post-Hospital Stress Index for Parents; POMS = Profile of Mood States; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial; RR = relative risk; SC = Supportive counseling; STAI = State-Trait Anxiety Inventory

Table G9 Hydrocortisone compared with placebo

Outcome: Number of Studies, Number of Subjects; Design | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD: 1; 28; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | Hydrocortisone vs. placebo, PTSS-10, 7.1% vs. 21.4%, p=NR | Insufficient
PTSD symptom severity at 6 months^a^: 1; 28; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | Hydrocortisone vs. placebo, PTSS-10 median rank, 15.5 vs. 25.5, p=0.03 | Insufficient
Incidence and severity of psychological symptoms at 6 months: 1; 28; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | Hydrocortisone vs. placebo, Unnamed structured and validated questionnaire, no significant difference between groups in number and type of traumatic memories, p≤0.33 | Insufficient
Incidence/severity of comorbid conditions: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life at 6 months: 1; 28; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | Hydrocortisone vs. placebo, SF-36 physical function, 85 vs. 38, p=0.01; Pain, 25 vs. 0, p=0.01; general health perception, 72 vs. 60, p<0.01; vitality, 58 vs. 40, p<0.01; mental health, 80 vs. 64, p=0.01 | Insufficient
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide) 0; 0 | NA | NA | NA | NA | NA | Insufficient

a Groups different at baseline on some measures; high (> 20%) overall attrition

b Small sample size (< 300 observations)

Abbreviations: CI = confidence interval; NA = not applicable; NR = not reported; PTSD = posttraumatic stress disorder; PTSS-10 = Posttraumatic Stress Symptom 10 Question Inventory; RCT = randomized controlled trial; SF-36 = Medical Outcomes Study Health Survey – Short Form-36

Table G10 SSRI (Escitalopram) compared with inactive control condition

Outcome: Number of Studies, Number of Subjects; Design | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD at 5 months: 1; 39; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | Escitalopram vs. placebo, CAPS, 55.6% vs. 61.9%, OR (95% CI) = 0.77 (0.21 to 2.77), p=NS^c^ Escitalopram vs. WL, CAPS, 61.9% vs. 58.2%, p=NS | Insufficient
Incidence of PTSD 9 months: 1; 36; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | Escitalopram vs. placebo, CAPS, 42.1% vs. 47.1%, p=NR | Insufficient
PTSD symptom severity at 5 months: 1; 39; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | Escitalopram vs. placebo, CAPS total, 48.7 vs. 47.1, p=NR Escitalopram vs. WL, CAPS total, 48.7 vs. 50.6, p=NR | Insufficient
PTSD symptom severity at 9 months: 1; 36; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | Escitalopram vs. placebo, CAPS total, 47.1 vs. 45.7, p=NR | Insufficient
Incidence and severity of psychological symptoms: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence/severity of comorbid conditions: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Perceived utility: 0; 0 | NA | NA | NA | NA | NA | Insufficient

a High (> 20%) overall attrition; completer analysis only of 46 randomized

b Small sample size (< 300 observations)

c Stratified pairwise comparison

Abbreviations: CAPS = Clinician Administered PTSD Scale; CI = confidence interval; CT = Cognitive therapy; NA = not applicable; NR = not reported; NS = not significant; OR = odds ratio; PSS-SR = PTSD Symptom Scale-Self Report; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial; SSRI = Selective serotonin reuptake inhibitor; WL = waitlist

Table G11 Battlemind training compared with a standard post-deployment brief

Outcome: Number of Studies; Number of Subjects; Design | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
PTSD symptom severity at 4–6 months: 1; 2,443; RCT | Medium | Unknown, single study | Direct | Imprecise | Battlemind training not different than standard care, PCL-C, coefficient (SE) = −0.00 (0.02), p=NR | Insufficient
Incidence of major or other depression at 4–6 months: 1; 2,443; RCT | Medium | Unknown, single study | Direct | Imprecise | Battlemind training not different than standard care, PHQ-9, Adjusted OR (95% CI) = 1.12 (0.71 to 1.77), p=NR | Insufficient
Quality of Life: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Perceived utility at end of treatment: 1; 1,741; RCT | Medium | Unknown, single study | Direct | Imprecise | Battlemind training not different than standard care, 75.4% vs. 75.8%, p=0.76 | Insufficient
Perceived utility at 4–6 months: 1; 1,069; RCT | Medium | Unknown, single study | Direct | Imprecise | Battlemind training not different than standard care, 68.7% vs. 65.7%, p=0.35 | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable; NR = not reported; OR = odds ratio; PCL-C = PTSD Checklist-Civilian Version; PHQ-9 = Patient Health Questionnaire-9 item version; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial; SE = standard error

Table G12 Cognitive behavioral therapy compared with cognitive behavioral therapy + hypnosis

Outcome: Number of Studies; Number of Subjects; Design | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD at end of treatment: 1; 63; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT vs. CBT+Hypnosis, CAPS-2, 36% vs. 30%, p=NR | Insufficient
Incidence of PTSD at 6 months: 1; 63; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT vs. CBT+Hypnosis, CAPS-2, 42% vs. 40%, p=NR | Insufficient
PTSD symptom severity at end of treatment: 1; 63; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT vs. CBT+Hypnosis, IES-I, 16.58 vs. 11.30, p<0.05; G^c^ = 1.55 vs. 2.23 | Insufficient
PTSD symptom severity at 6 months: 1; 63; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT vs. CBT+Hypnosis, IES-I, 16.97 vs. 13.57, p=NR; G^c^ = 1.72 vs. 1.69 | Insufficient
Depression symptom severity at end of treatment: 1; 63; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT vs. CBT+Hypnosis, BDI-2, 13.24 vs. 11.37, p=NR | Insufficient
Depression symptom severity at 6 months: 1; 63; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT vs. CBT+Hypnosis, BDI-2, 14.61 vs. 13.57, p=NR | Insufficient
Anxiety symptom severity at end of treatment: 1; 63; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT vs. CBT+Hypnosis, BAI, 14.91 vs. 15.47, p=NR | Insufficient
Anxiety symptom severity at 6 months: 1; 63; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT vs. CBT+Hypnosis, BAI, 15.67 vs. 17.07, p=NR | Insufficient
Incidence/severity of comorbid conditions: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide) 0; 0 | NA | NA | NA | NA | NA | Insufficient
Perceived utility: 0; 0 | NA | NA | NA | NA | NA | Insufficient

a High (> 20%) overall attrition; high (> 15%) differential attrition between groups

b Small sample size

c Hodges G effect size

Abbreviations: BAI = Beck Anxiety Inventory; BDI-2 = Beck Depression Inventory-2; CAPS-2 = Clinician Administered PTSD Scale-2; CBT = Cognitive behavioral therapy; CBT+Hypnosis = CBT combined with hypnosis; CI = confidence interval; IES-I = Impact of Event-Intrusion subscale; NA = not applicable; NR = not reported; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial

Table G13 Cognitive behavioral therapy compared with supportive counseling

Outcome: Number of Studies; Number of Subjects; Design | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD at end of treatment: 3; 105; RCT | Medium^a^ | Consistent | Direct | Imprecise^b^ | CIDI-PTSD, CAPS, RR (95% CI) = 0.27 (0.05 to 1.29) favors CBT | Low
Incidence of PTSD at 6 months: 3; 105; RCT | Medium^a^ | Consistent | Direct | Imprecise^c^ | CIDI-PTSD, CAPS, RR (95% CI) = 0.46 (0.21 to 1.01) favors CBT | Low
PTSD symptom reduction at end of treatment: 3; 105; RCT | Medium^a^ | Consistent | Direct | Precise^d^ | IES-I, WMD −7.85 (−11.18 to −4.53) favors CBT | Moderate
PTSD symptom reduction at 6 months: 3; 105; RCT | Medium^a^ | Consistent | Direct | Precise^e^ | IES-I, WMD −8.19 (−11.79 to −4.58) favors CBT | Moderate
PTSD symptom reduction at end of treatment: 3; 105; RCT | Medium^a^ | Consistent | Direct | Precise^f^ | IES-A, WMD −14.04 (−19.37 to −8.71) favors CBT | Moderate
PTSD symptom reduction at 6 months: 3; 105; RCT | Medium^a^ | Consistent | Direct | Precise^g^ | IES-A, WMD −9.94 (−15.06 to −4.83) favors CBT | Moderate
Depression symptom reduction at end of treatment: 3; 105; RCT | Medium^a^ | Inconsistent | Direct | Imprecise^h^ | BDI-2, SMD −0.15 (−0.53 to 0.24) | Low
Depression symptom reduction at 6months: 3; 105; RCT | Medium^a^ | Inconsistent | Direct | Imprecise^i^ | BDI-2, SMD −0.21 (−0.70 to 0.27) | Low
Anxiety symptom reduction at end of treatment: 3; 105; RCT | Medium^a^ | Consistent | Direct | Imprecise^j^ | BAI, STAI, SMD −0.25 (−0.64 to 0.13) | Moderate
Anxiety symptom reduction at 6 months: 3; 105; RCT | Medium^a^ | Consistent | Direct | Imprecise^k^ | BAI, STAI, SMD −0.28 (−0.67 to 0.11) | Moderate
Incidence/severity of comorbid conditions: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide) 0; 0 | NA | NA | NA | NA | NA | Insufficient
Perceived utility: 0; 0 | NA | NA | NA | NA | NA | Insufficient

a Reasons for downgrading include lack of reporting on number of treatment sessions completed (1 study), high (> 20%) overall attrition rate (1 study), unclear randomization scheme (1 study)

b Although the direction of effects was consistent, the meta-analysis had considerable statistical heterogeneity (I^2^=71.8%), reflecting the fact that two of the three medium risk of bias trials found large magnitudes of benefit but one medium risk of bias study found no difference between treatment groups. When we repeated the analysis including an additional high risk of bias study that found a small benefit, the heterogeneity was reduced (I^2^=58.78%). Even though the direction of effect was consistent across trials, we rated the findings as imprecise and thus graded the SOE as low rather than moderate.

c Although the direction of effects was consistent, the meta-analysis had considerable statistical heterogeneity (I^2^=44.9%), reflecting the fact that two of the three medium risk of bias trials found large magnitudes of benefit but one medium risk of bias study found no difference between treatment groups. When we repeated the analysis including an additional high risk of bias study that found a small benefit, the heterogeneity was reduced (I^2^=32.0%). Even though the direction of effect was consistent across trials, we rated the findings as imprecise and thus graded the SOE as low rather than moderate.

d The analysis found very low statistical heterogeneity (I^2^=1.3%) and a subsequent sensitivity analysis (n=136) including one high risk of bias study indicated a slightly larger benefit of CBT (WMD, −8.39; 95% CI, −11.45 to −5.34) with no statistical heterogeneity (I^2^=0.0%), increasing our confidence in the finding of a moderate effect size and finding a consistent, precise result.

e The analysis found very low statistical heterogeneity (I^2^=6.8%). A subsequent sensitivity analysis (n=136) including one high risk of bias study indicated a slightly smaller benefit of CBT (WMD, −7.91; 95% CI, −10.85 to −4.98) with no statistical heterogeneity (I^2^=0.0%), reinforcing our confidence in the finding of a moderate effect size and a consistent, precise result.

f Although the direction of the effect was consistent, the analysis found moderate statistical heterogeneity (I^2^=53.8%). A subsequent sensitivity analysis (n=136) including one high risk of bias study indicated a slightly larger benefit of CBT (WMD, −14.17; 95% CI, −17.82 to −10.51) with reduced statistical heterogeneity (I^2^=31.9%), reinforcing our confidence in the finding of a large effect size and a consistent, precise result.

g Although the direction of the effect was consistent, the analysis found moderate statistical heterogeneity (I^2^=44.0%). A subsequent sensitivity analysis (n=136) including one high risk of bias study indicated a slightly larger benefit of CBT (WMD, −11.49; 95% CI, −16.09 to −6.90) albeit with greater statistical heterogeneity (I^2^=52.7%), which did not substantively change our confidence in the finding of a large effect size and a consistent, precise result.

h The analysis found no statistical heterogeneity (I^2^=0.0%) and the direction of effect was not consistent across trials ranging from a very low effect size in favor of SC to a moderate effect size in favor of CBT. A subsequent sensitivity analysis (n=136) including one high risk of bias study indicated lower statistical heterogeneity (I^2^=0.0%) and a slightly larger but still insignificant benefit of CBT (SMD, −0.22; 95% CI, −0.56 to 0.12).

i The analysis found moderate statistical heterogeneity (I^2^=30.0%) and the direction of effect was not consistent across trials. A subsequent sensitivity analysis (n=136) including one high risk of bias study indicated a slightly larger but still insignificant benefit of CBT (SMD, −0.25; 95% CI, −0.62 to 0.12) with low statistical heterogeneity (I^2^=10.1%).

j The analysis found no statistical heterogeneity (I^2^=0.0%) and a subsequent sensitivity analysis (n=136) including one high risk of bias study indicated a slightly larger but still insignificant benefit of CBT (SMD, −0.39; 95% CI, −0.74 to −0.04) with very low statistical heterogeneity (I^2^=2.2%).

k The analysis found no statistical heterogeneity (I^2^=0.0%) and a subsequent sensitivity analysis (n=136) including one high risk of bias study indicated a larger but still insignificant benefit of CBT (SMD, −0.59; 95% CI, −1.16 to −0.01) with very low statistical heterogeneity (I^2^=2.2%).

Abbreviations: BAI = Beck Anxiety Inventory; BDI-2 = Beck Depression Inventory-2; CAPS = Clinician Administered PTSD Scale; CBT = Cognitive behavioral therapy; CI = confidence interval; CIDI-PTSD = Composite International Diagnostic Interview PTSD Module; CT = Cognitive therapy; IES-A = Impact of Event-Avoidance subscale; IES-I = Impact of Event-Intrusion subscale; n = number of participants; NA = not applicable; NS = Not significant; OR = Odds ratio; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial; RR = risk ratio; SC = Supportive counseling; SMD = standardized mean difference; SOE = strength of evidence; STAI = State-Trait Anxiety Inventory; WMD = weighted mean difference

Table G14 Cognitive behavioral therapy + hypnosis compared with supportive counseling

Outcome: Number of Studies; Number of Subjects; Design | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD at end of treatment: 1; 54; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT+Hypnosis vs. SC, CAPS-2, 30% vs. 50%, p=NR | Insufficient
Incidence of PTSD at 6 months: 1; 54; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT+Hypnosis vs. SC, CAPS-2, 40% vs. 58%, p=NR | Insufficient
PTSD symptom severity at end of treatment: 1; 54; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT+Hypnosis vs. SC, IES-I, 11.30 vs. 19.83, p<0.05 | Insufficient
PTSD symptom severity at 6 months: 1; 54; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT+Hypnosis vs. SC, IES-I, 13.57 vs. 20.21, p<0.05 | Insufficient
Severity of depressive symptoms at end of treatment: 1; 54; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT+Hypnosis vs. SC, BDI-2, 11.37 vs. 14.96, p=NR | Insufficient
Severity of depressive symptoms at 6 months: 1; 54; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT+Hypnosis vs. SC, BDI-2, 13.57 vs. 16.29, p=NR | Insufficient
Severity of anxiety symptoms at end of treatment: 1; 54; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT+Hypnosis vs. SC, BAI, 15.47 vs. 20.25, p=NR | Insufficient
Severity of anxiety symptoms at 6 months: 1; 54; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CBT+Hypnosis vs. SC, BAI, 17.07 vs. 21.13, p=NR | Insufficient
Incidence/severity of comorbid conditions: 0; 0 | NA | NA | NA | NA | NA | NA
Quality of Life: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Perceived utility: 0; 0 | NA | NA | NA | NA | NA | Insufficient

a High (> 20%) overall attrition; high (> 15%) differential attrition between groups; no data reported on # of sessions completed per group

b Small sample size (< 300 observations)

Abbreviations: BAI = Beck Anxiety Inventory; BDI-2 = Beck Depression Inventory-2; CAPS-2 = Clinician Administered PTSD Scale-2; CBT = Cognitive behavioral therapy; CBT+Hypnosis = CBT combined with hypnosis; CI = confidence interval; IES-I = Impact of Event Scale - Intrusion subscale; NA = not applicable; NR = not reported; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial; SC = Supportive counseling

Table G15 Cognitive therapy compared with prolonged exposure therapy

Outcome: Number of Studies; Number of Subjects; Design | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD at end of treatment: 1; 60; RCT | Low | Unknown, single study | Direct | Imprecise^a^ | PE vs. CT, CAPS-2, 33% vs. 63%, p=0.002: OR (95% CI) = 2.52 (1.28 to 4.93) | Insufficient
Incidence of PTSD at 5 months: 1; 87; RCT | Medium^b^ | Unknown, single study | Direct | Imprecise^a^ | PE vs. CT, CAPS, 21.6 vs. 20.0: OR (85% CI) = 0.87 (0.29 to 2.62)], p=0.83^c^ | Insufficient
Incidence of PTSD at 6 months: 1; 60; RCT | Low | Unknown, single study | Direct | Imprecise^a^ | PE vs. CT, CAPS-2, 37% vs. 63%, p=0.007; OR (95% CI) = 2.10 (1.12 to 3.94); NNT=3.75 | Insufficient
Incidence of PTSD at 9 months: 1; 87; RCT | Medium^b^ | Unknown, single study | Direct | Imprecise^a^ | PE vs. CT, CAPS, 21.2% vs. 22.9%, p=NR | Insufficient
PTSD symptom severity at end of treatment: 1; 60; RCT | Low | Unknown, single study | Direct | Imprecise^a^ | PE vs. CT, CAPS-2 total, 31.5 vs. 43.0, p=NR, Cohen’s d = 0.42 (−0.09 to 0.92); IES-I, 12.4 vs. 17.7, p=NR, Cohen’s d = 0.44 (−0.07 to 0.95); IES-A, 11.7 vs. 17.1, p=NR, Cohen’s d = 0.43 (−0.08 to 0.94) | Insufficient
PTSD symptom severity at 5 months: 1; 89; RCT | Medium^b^ | Unknown, single study | Direct | Imprecise^a^ | PE vs. CT, CAPS total, 28.59 vs. 29.48, p=NR; CAPS re-experiencing, 7.32 vs. 6.85, p=NR; CAPS avoidance, 11.36 vs. 12.12, p=NR; CAPS hyperarousal, 9.91 vs. 10.52, p=NR | Insufficient
PTSD symptom severity at 6 months: 1; 60; RCT | Low | Unknown, single study | Direct | Imprecise^a^ | PE vs. CT, CAPS-2 total, 32.1 vs. 49.8, p=NR, Cohen’s d = 0.60 (0.08 to 1.11); IES-I, 11.4 vs. 18.6, p=NR, Cohen’s d = 0.63 (0.11 to 1.15); IES-A, 12.8 vs. 19.2, p=0.03, Cohen’s d = 0.44 (−0.02 to 1.01) | Insufficient
PTSD symptom severity at 9 months: 1; 87; RCT | Medium^b^ | Unknown, single study | Direct | Imprecise^a^ | PE vs. CT, CAPS total: 27.52 vs. 27.89, p=NR; CAPS re-experiencing: 6.67 vs. 5.57, p=NR; CAPS avoidance: 11.21 vs. 12.97, p=NR; CAPS hyperarousal: 9.63 vs. 9.34, p=NR | Insufficient
Depression symptom severity at end of treatment: 1; 60; RCT | Low | Unknown, single study | Direct | Imprecise^a^ | PE vs. CT, BDI-2, 12.1 vs. 18.9, p=NR, Cohen’s d = 0.54 (0.01 to 1.05) | Insufficient
Depression symptom severity at 6 months: 1; 60; RCT | Low | Unknown, single study | Direct | Imprecise^a^ | PE vs. CT, BDI-2, 12.4 vs. 20.4, p=NR, Cohen’s d = 0.60 (0.09 to 1.12) | Insufficient
Anxiety symptom severity at end of treatment: 1; 60; RCT | Low | Unknown, single study | Direct | Imprecise^a^ | PE vs. CT, BAI, 13.4 vs. 23.4, p=0.008, Cohen’s d = 0.67 (0.15 to 1.19) | Insufficient
Anxiety symptom severity at 6 months: 1; 60; RCT | Low | Unknown, single study | Direct | Imprecise^a^ | PE vs. CT, BAI, 12.8 vs. 23.3, p=NR, Cohen’s d = 0.63 (0.11 to 1.15) | Insufficient
Incidence/severity of comorbid conditions: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide) 0; 0 | NA | NA | NA | NA | NA | Insufficient
Perceived utility: 0; 0 | NA | NA | NA | NA | NA | Insufficient

a Small sample size (< 300 observations)

b Completer analysis of 103 randomized participants

c Stratified pairwise group comparison

Abbreviations: BAI = Beck Anxiety Inventory; BDI-2 = Beck Depression Inventory-2; CAPS = Clinician Administered PTSD Scale; CAPS-2 = Clinician Administered PTSD Scale-2; CI = confidence interval; CT = Cognitive therapy; IES-A = Impact of Event Scale - Avoidance subscale; IES-I = Impact of Event Scale - Intrusion subscale; NA = not applicable; NNT = number needed to treat; NR = not reported; OR = odds ratio; PE = Prolonged exposure therapy; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial

Table G16 Debriefing compared with an active control condition (debriefing)

Outcome: Number of Studies; Number of Subjects; Design | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD at 2 weeks: 1; 155 | Low | Unknown, single study | Direct | Imprecise^a^ | Data=NR, p=NR^b^ | Insufficient
Incidence of PTSD at 6 weeks: 1; 155 | Low | Unknown, single study | Direct | Imprecise^a^ | Data=NR, p=NR^b^ | Insufficient
Incidence of PTSD at 6 months: 1; 155 | Low | Unknown, single study | Direct | Imprecise^a^ | Data=NR, p=NR^b^ | Insufficient
PTSD symptom severity at 2 weeks^c^: 1; 155 | Low | Unknown, single study | Direct | Imprecise^a^ | Emotional debriefing vs. Educational debriefing, SI-PTSD, 18.1 vs. 16.2, p=NR^c^ | Insufficient
PTSD symptom severity at 6 weeks^c^: 1; 155 | Low | Unknown, single study | Direct | Imprecise^a^ | Emotional debriefing vs. Educational debriefing, SI-PTSD, 14.4 vs. 11.9, p=NR^c^ | Insufficient
PTSD symptom severity at 6 months: 1; 155 | Low | Unknown, single study | Direct | Imprecise^a^ | Emotional debriefing vs. Educational debriefing, SI-PTSD, 10.2 vs. 9.3, p=NR^c^ | Insufficient
Depression symptom severity at 2 weeks: 1; 155 | Low | Unknown, single study | Direct | Imprecise^a^ | Emotional debriefing vs. Educational debriefing, HADS-D, 5.7 vs. 4.7, p=NR^c^ | Insufficient
Depression symptom severity at 6 weeks: 1; 155 | Low | Unknown, single study | Direct | Imprecise^a^ | Emotional debriefing vs. Educational debriefing, HADS-D, 4.3 vs. 3.3, p=NR^c^ | Insufficient
Depression symptom severity at 6 months: 1; 155 | Low | Unknown, single study | Direct | Imprecise^a^ | Emotional debriefing vs. Educational debriefing, HADS-D, 3.8 vs. 3.2, p=NR^c^ | Insufficient
Anxiety symptom severity at 2 weeks: 1; 155 | Low | Unknown, single study | Direct | Imprecise^a^ | Emotional debriefing vs. Educational debriefing, HADS-A, 7.6 vs. 6.6, p=NR^c^ | Insufficient
Anxiety symptom severity at 2 weeks: 1; 155 | Low | Unknown, single study | Direct | Imprecise^a^ | Emotional debriefing vs. Educational debriefing, HADS-A, 5.6 vs. 5.1, p=NR^c^ | Insufficient
Anxiety symptom severity at 2 weeks: 1; 155 | Low | Unknown, single study | Direct | Imprecise^a^ | Emotional debriefing vs. Educational debriefing, HADS-A, 5.0 vs. 4.4, p=NR^c^ | Insufficient
Incidence/severity of comorbid conditions: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Perceived utility: 0; 0 | NA | NA | NA | NA | NA | Insufficient

a Small sample size (< 300 observations)

b Data are reported for the entire sample (week 2 = 5.4%, week 6 = 4.9%; 6 month = 4.8%) rather than by treatment group; the text indicates ‘no significant differences’ between groups

c Mixed-model analysis performed on entire sample including a control treatment group indicated no group differences; however, no pairwise post-hoc comparisons were reported

Abbreviations: CI = confidence interval; HADS-A = Hospital Anxiety and Depression Scale–Anxiety subscale; HADS-D = Hospital Anxiety and Depression Scale–Depression subscale; NA = not applicable; NR = not reported; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial; SI-PTSD = Structured Interview for PTSD

Table G17 Psychoeducation compared with an active control condition (Debriefing combined with psychoeducation)

Outcome: Number of Studies; Number of Subjects; Design | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD at 6 months: 1; 106; RCT | Medium^a, b^ | Unknown, single study | Direct | Imprecise^c^ | Psychoeducation vs. Debriefing combined with psychoeducation, PSS-SR, 11% vs. 23%, p=NS | Insufficient
PTSD symptom severity at 6 months: 1; 106; RCT | Medium^a, b^ | Unknown, single study | Direct | Imprecise^c^ | Psychoeducation vs. Debriefing combined with psychoeducation, PSS-SR, 10.9 vs. 13.8, p=NS; IES, 16.7 vs. 19.7, p=NS | Insufficient
Depression symptom severity at 6 months: 1; 106; RCT | Medium^a, b^ | Unknown, single study | Direct | Imprecise^c^ | Psychoeducation vs. Debriefing combined with psychoeducation, BDI, 9.8 vs. 12.1, p=NS | Insufficient
Incidence/severity of comorbid conditions: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Perceived utility: 0; 0 | NA | NA | NA | NA | NA | Insufficient

a Primary analysis not ITT; 11-month attrition > 20%

b Due to very high overall attrition (i.e., greater than 40% at 11-month followup) in this study, we considered all outcomes collected at that timepoint as having a high risk of bias and therefore do not report them

c Small sample size (< 300 observations)

Abbreviations: BDI = Beck Depression Inventory; CI = confidence interval; IES = Impact of Event Scale; ITT = intent to treat analysis; NA = not applicable; NR = not reported; NS = not significant; PSS-SR = PTSD Symptom Scale-Self-Report; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial

Table G18 Cognitive therapy compared with SSRI (Escitalopram)

Outcome: Number of Studies; Number of Subjects; Design | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD at 5 months: 1; 54; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CT vs. SSRI, CAPS, 18.2% vs. 61.9%, p=NR^c^ | Insufficient
Incidence of PTSD 9 months: 1; 54; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CT vs. SSRI, CAPS, 22.8% vs. 42.1%, p=NR^c^ | Insufficient
PTSD symptom severity at 5 months: 1; 54; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CT vs. SSRI, CAPS total, 29.5 vs. 48.7, p=NR^c^; PSS-SR, 11.6 vs. 22.5, p=NR^c^ | Insufficient
PTSD symptom severity at 9 months: 1; 54; RCT | Medium^a^ | Unknown, single study | Direct | Imprecise^b^ | CT vs. SSRI, CAPS total, 27.9 vs. 47.2, p=NR^c^; PSS-SR, 9.6 vs. 21.6, p=NR^c^ | Insufficient
Incidence and severity of psychological symptoms: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence/severity of comorbid conditions: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Perceived utility: 0; 0 | NA | NA | NA | NA | NA | Insufficient

a Completer analysis of 63 randomized rather than ITT; high (> 20%) overall attrition; high (> 15%) differential attrition between groups

b Small sample size (< 300 observations)

c Text indicates means are significantly different but no post-hoc p values are provided

Abbreviations: CAPS = Clinician Administered PTSD Scale; CI = confidence interval; CT = Cognitive therapy; ITT = intent to treat analysis; NA = not applicable; NR = not reported; PSS-SR = PTSD Symptom Scale-Self Report; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial; SSRI = Selective serotonin reuptake inhibitor

Table G19 Prolonged exposure compared with SSRI (Escitalopram)

Outcome: Number of Studies; Number of Subjects; Design | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD at 5 months: 1; 77; RCT | Medium^b^ | Unknown, single study | Direct | Imprecise^a^ | PE vs. SSRI, CAPS, 21.4% vs. 61.9%, p=NR^c^ | Insufficient
Incidence of PTSD at 9 months: 1; 71; RCT | Medium^b^ | Unknown, single study | Direct | Imprecise^a^ | PE vs. SSRI, CAPS, 21.2% vs. 42.1%, p=NR^c^ | Insufficient
PTSD symptom severity at 5 months: 1; 77; RCT | Medium^b^ | Unknown, single study | Direct | Imprecise^a^ | PE vs. SSRI, CAPS total, 28.6 vs. 48.7, p=NR^c^; PSS-SR, 11.0 vs. 22.5, p=NR^c^ | Insufficient
PTSD symptom severity at 9 months: 1; 71; RCT | Medium^b^ | Unknown, single study | Direct | Imprecise^a^ | PE vs. SSRI, CAPS total, 27.2 vs. 47.2, p=NR^c^; PSS-SR, 10.4 vs. 21.6, p=NR^c^ | Insufficient
Incidence and severity of psychological symptoms: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence/severity of comorbid conditions: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Perceived utility: 0; 0 | NA | NA | NA | NA | NA | Insufficient

a Completer analysis of 86 randomized rather than ITT; high (> 20%) overall attrition; high (> 15%) differential attrition between groups

b Small sample size (< 300 observations)

c Text indicates means are significantly different but no post-hoc p values are provided

Abbreviations: CAPS = Clinician Administered PTSD Scale; CI = confidence interval; ITT = intent to treat analysis; NA = not applicable; NR = not reported; PE = Prolonged exposure therapy; PSS-SR = PTSD Symptom Scale-Self Report; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial; SSRI = Selective serotonin reuptake inhibitor

## Key Question 2

Table G20 Immediate critical incident stress debriefing compared with delayed critical incident stress debriefing

Outcome: Number of Studies; Number of Subjects; Design | Risk of Bias; | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD: 0; 0 | NA | NA | NA | NA | NA | Insufficient
PTSD symptom severity^a^: 1; 72; RCT | Medium^b^ | NA^c^ | Direct | Not reported^d^ | PDS, 8.8 symptoms fewer in immediate CISD than delayed CISD group (95% CI, NR) | Insufficient
Quality of Life: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Perceived utility: 0; 0 | NA | NA | NA | NA | NA | Insufficient

a Mean change from baseline to 2 weeks on the PDS.

b Unmasked RCT

c Downgraded as a single study

d Downgraded for unclear precision

Abbreviations: CI = confidence interval; CISD = Critical Incident Stress Debriefing; NA = not applicable; NR = not reported; PDS = Posttraumatic Stress Diagnostic Scale; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial

Table G21 Strength of evidence comparing light versus deep sedation

Outcome: Number of Studies; Number of Subjects; Design | Risk of Bias | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD: 0,0 | NA | NA | NA | NA | NA | Insufficient
PTSD symptom severity: 1; 135; RCT | Medium^a^ | NA^b^ | Direct | Not reported^c^ | Similar effects (10% vs. 9% with PTSD symptoms) | Insufficient
Quality of Life: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide) 0; 0 | NA | NA | NA | NA | NA | Insufficient
Perceived utility: 0; 0 | NA | NA | NA | NA | NA | Insufficient

a Unmasked RCT

b Downgraded as a single study

c Downgraded for unclear precision

Abbreviations: CI = confidence interval; NA = not applicable; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial

## Key Question 3

Table G22 Strength of evidence for subgroup effects of gender

Outcome: Number of Studies; Number of Subjects; Design | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD: 0; 0 | NA | NA | NA | NA | NA | Insufficient
PTSD symptom severity: 2; 268; RCT | Medium^a^ | Consistent^b^ | Direct | Not reported^c^ | Not reported^d^ | Low^e^
Depression symptom severity: 1; 157; RCT | Medium^a^ | Unknown^f^ | Direct | Not reported^c^ | Not reported^d^ | Insufficient^g^
Quality of Life: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Perceived utility: 0; 0 | NA | NA | NA | NA | NA | Insufficient

a Unmasked RCT

b Upgraded for consistency

c Downgraded for unclear precision

d Downgraded for unclear magnitude of effect

e Low SOE because magnitude and precision of effect not reported by either of the two studies.

f Downgraded as a single study

g Insufficient because findings reported by only one medium risk of bias trial and magnitude, direction and precision not reported.

Abbreviations: CI = confidence interval; NA = not applicable; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial; SOE = strength of evidence

Table G23 Strength of evidence for subgroup effects of previous depression

Outcome: Number of Studies; Number of Subjects; Design | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD: 0; 0 | NA | NA | NA | NA | NA | Insufficient
PTSD symptom severity: 1; 157; RCT | Medium^a^ | Unknown^b^ | Direct | Not reported^c^ | Not reported^d^ | Insufficient^e^
Depression symptom severity: 1; 157; RCT | Medium^a^ | Unknown^b^ | Direct | Not reported^c^ | Not reported^d^ | Insufficient^e^
Quality of Life: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Perceived utility: 0; 0 | NA | NA | NA | NA | NA | Insufficient

a Unmasked RCT

b Downgraded as a single study

c Downgraded for unclear precision

d Downgraded for unclear magnitude of effect.

e Insufficient because findings reported by only one medium risk of bias trial and magnitude, direction and precision not reported.

Abbreviations: CI = confidence interval; NA = not applicable; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial

Table G24 Strength of evidence for subgroup effects of history of child abuse

Outcome: Number of Studies; Number of Subjects; Design | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD: 0; 0 | NA | NA | NA | NA | NA | Insufficient
PTSD symptom severity: 1; 157; RCT | Medium^a^ | Unknown^b^ | Direct | Not reported^c^ | Not reported^d^ | Insufficient^e^
Depression symptom severity: 1; 157; RCT | Medium^a^ | Unknown^b^ | Direct | Not reported^c^ | Not reported^d^ | Insufficient^e^
Quality of Life: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Perceived utility: 0; 0 | NA | NA | NA | NA | NA | Insufficient

a Unmasked RCT

b Downgraded as a single study

c Downgraded for unclear precision

d Downgraded for unclear magnitude of effect.

e Insufficient because findings reported by only one medium risk of bias trial and magnitude, direction and precision not reported.

Abbreviations: CI = confidence interval; NA = not applicable; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial

Table G25 Strength of evidence for subgroup effects of severity of baseline distress

Outcome: Number of Studies; Number of Subjects; Design | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD: 0; 0 | NA | NA | NA | NA | NA | Insufficient
PTSD symptom severity: 2; 285; RCT | Medium^a^ | Inconsistent^b^ | Direct | Not reported^c^ | Not reported^d^ | Insufficient^e^
Depression symptom severity: 2; 285; RCT | Medium^a^ | NA | NA | NA | NA | Insufficient^f^
Quality of Life: 2; 285; RCT | Medium^a^ | NA | NA | NA | NA | Insufficient^f^
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Perceived utility: 0; 0 | NA | NA | NA | NA | NA | Insufficient

a Unmasked RCT

b Downgraded for lack of consistency

c Downgraded for unclear precision

d Downgraded for unclear magnitude of effect.

e Insufficient SOE because inconsistent findings were reported.

f Insufficient SOE because although two studies assessed this outcome, severity of baseline distress was defined differently for all outcomes other than PTSD.

Abbreviations: CI = confidence interval; NA = not applicable; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial; SOE = strength of evidence

Table G26 Strength of evidence for subgroup effects of severity of exposure to trauma

Outcome: Number of Studies, Number of Subjects | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD: 0; 0 | NA | NA | NA | NA | NA | Insufficient
PTSD symptom severity: 1; 2,443 | Medium^a^ | Unknown^b^ | Direct | Not reported^c^ | Not reported | Insufficient^d^
Depression symptom severity:0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Perceived utility: 0; 0 | NA | NA | NA | NA | NA | Insufficient

a Unmasked RCT

b Downgraded as a single study

c Downgraded for unclear precision

d Insufficient SOE because findings reported by only one medium risk of bias trial and magnitude and precision not reported.

Abbreviations: CI = confidence interval; NA = not applicable; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial; SOE = strength of evidence

Table G27 Strength of evidence for subgroup effects of type of trauma

Outcome: Number of Studies, Number of Subjects | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Incidence of PTSD: 1; 137 | Medium1 | Unknown2 | Direct | Not reported3 | Not reported | Insufficient^a^
PTSD symptom severity: 1; 137 | Medium1 | Unknown2 | Direct | Not reported3 | Not reported | Insufficient^a^
Depression symptom severity: 0;0 | NA | NA | NA | NA | NA | Insufficient
Quality of Life: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to work/return to active duty or ability to work: 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of self-injurious or suicidal thoughts, attempts, or behaviors (including suicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Incidence of aggressive or homicidal thoughts, attempts, or behaviors (including homicide): 0; 0 | NA | NA | NA | NA | NA | Insufficient
Perceived utility: 0; 0 | NA | NA | NA | NA | NA | Insufficient

a Unmasked RCT

b Downgraded as a single study

c Downgraded for unclear precision

d Insufficient SOE because: 1) findings reported by only one medium risk of bias trial; 2) no overall test of interaction (group-by-type of trauma-by-time) was done.

Abbreviations: CI = confidence interval; NA = not applicable; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial; SOE = strength of evidence

## Key Question 4

Table G28 Strength of evidence comparing emotional debriefing vs. educational debriefing vs. placebo

Outcome: Number of Studies; Number of Subjects; Design | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Overall rate of harms: 1; 236; RCT | Low^a^ | NA^b^ | Direct | Not reported | In a subgroup with hyperarousal at baseline, those receiving emotional debriefing has significantly higher PTSD scores than those in the control group at 6 week follow-up (p=0.005)^c^ | Insufficient
Overall dropout rate because of adverse events: 0; 0 | NA | NA | NA | NA | NA | Insufficient

a Single-blind RCT (outcome assessor masked)

b Downgraded as single study.

c This subgroup analysis involved a significant test for interaction, but no significant differences were found at 2 weeks or 6 months, and the former result might be a chance finding. Downgraded as post-hoc analysis of subgroup with mixed results across time points.

Abbreviations: CI = confidence interval; NA = not applicable; PTSD = posttraumatic stress disorder; RCT = randomized controlled trial

Table G29 Strength of evidence comparing light versus deep sedation

Outcome: Number of Studies; Number of Subjects; Design | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Magnitude of Effect: Summary Effect Size (95% CI) | Strength of Evidence
Overall rate of harms: 1; 137; RCT | Medium^a^ | NA^b^ | Direct | Not reported | No difference in mortality or incidence of adverse events | Insufficient^c^
Overall dropout rate because of adverse events: 0; 0 | NA | NA | NA | NA | NA | Insufficient

a Open label RCT (outcome assessor masked), overall attrition > 20%, unclear how dropouts were handled in intention-to-treat analysis

b Downgraded as single study.

c Insufficient SOE because no data reported.

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial; SOE = strength of evidence