# Risk-of-Bias Tables

Table F1 Risk of bias observational studies

Table F2 Risk of bias RCTs

## References

1 Beatty LJ, Koczwara B, Rice J, et al. A randomised controlled trial to evaluate the effects of a self-help workbook intervention on distress, coping and quality of life after breast cancer diagnosis. Med J Aust. Sep. 6. 2010;193(5 Suppl):S68-73. [pmid: 21542450].
2 Bryant RA, Mastrodomenico J, Felmingham KL, et al. Treatment of acute stress disorder: a randomized controlled trial. Arch Gen Psychiatry. Jun. 2008;65(6):659-67. [pmid: 18519824].
3 Bryant RA, Moulds M, Guthrie R, et al. Treating acute stress disorder following mild traumatic brain injury. Am J Psychiatry. Mar. 2003;160(3):585-7. [pmid: 12611847].
4 Bryant RA, Harvey AG, Dang ST, et al. Treatment of acute stress disorder: a comparison of cognitive-behavioral therapy and supportive counseling. J Consult Clin Psychol. Oct. 1998;66(5):862-6. [pmid: 9803707].
5 Bryant RA, Moulds ML, Guthrie RM, et al. The additive benefit of hypnosis and cognitive-behavioral therapy in treating acute stress disorder. J Consult Clin Psychol. Apr. 2005;73(2):334-40. [pmid: 15796641].
6 Campfield KM, Hills AM. Effect of timing of critical incident stress debriefing (CISD) on posttraumatic symptoms. J Trauma Stress. Apr. 2001;14(2):327-40. [pmid: 11469160].
7 Gamble J, Creedy D, Moyle W, et al. Effectiveness of a counseling intervention after a traumatic childbirth: a randomized controlled trial. Birth. Mar. 2005;32(1):11-9. [pmid: 15725200].
8 Melnyk BM, Alpert-Gillis L, Feinstein NF, et al. Creating opportunities for parent empowerment: program effects on the mental health/coping outcomes of critically ill young children and their mothers. Pediatrics. Jun. 2004;113(6):e597-607. [pmid: 15173543].
9 Mulligan K, Fear NT, Jones N, et al. Postdeployment Battlemind training for the U.K. armed forces: A cluster randomized controlled trial. J Consult Clin Psychol. 2012;80(3):331-41. [pmid: 22409642].
10 O’Donnell ML, Lau W, Tipping S, et al. Stepped early psychological intervention for posttraumatic stress disorder, other anxiety disorders, and depression following serious injury. J Trauma Stress. Apr. 2012;25(2):125-33. [pmid: 22522725].
11 Rose S, Brewin CR, Andrews B, et al. A randomized controlled trial of individual psychological debriefing for victims of violent crime. Psychol Med. Jul. 1999;29(4):793-9. [pmid: 10473306].
12 Rothbaum BO, Kearns MC, Price M, et al. Early Intervention May Prevent the Development of Posttraumatic Stress Disorder: A Randomized Pilot Civilian Study with Modified Prolonged Exposure. Biol Psychiatry. Jul. 2012;72(11):957-63. [pmid: 22766415].
13 Ryding EL, Wiren E, Johansson G, et al. Group counseling for mothers after emergency cesarean section: a randomized controlled trial of intervention. Birth. Dec. 2004;31(4):247-53. [pmid: 15566336].
14 Shalev AY, Ankri YLE, Israeli-Shalev Y, et al. Prevention of posttraumatic stress disorder by early treatment: results from the Jerusalem Trauma Outreach and Prevention Study. Arch Gen Psychiatry. Feb. 2012;69(2):166-76. [pmid: 21969418].
15 Sijbrandij M, Olff M, Reitsma JB, et al. Emotional or educational debriefing after psychological trauma. Randomised controlled trial. Br J Psychiatry. Aug. 2006;189:150-5. [pmid: 16880485].
16 Treggiari MM, Romand JA, Yanez ND, et al. Randomized trial of light versus deep sedation on mental health after critical illness. Crit Care Med. Sep. 2009;37(9):2527-34. [pmid: 19602975].
17 Weis F, Kilger E, Roozendaal B, et al. Stress doses of hydrocortisone reduce chronic stress symptoms and improve health-related quality of life in high-risk patients after cardiac surgery: a randomized study. J Thorac Cardiovasc Surg. Feb. 2006;131(2):277-82. [pmid: 16434254].
18 Wong EC, Marshall GN, Miles JN. Randomized controlled trial of a psychoeducational video intervention for traumatic injury survivors. Los Angeles, CA. RAND Corporation. Under review.
19 Zatzick D, Jurkovich G, Rivara F, et al. A randomized stepped care intervention trial targeting posttraumatic stress disorder for surgically hospitalized injury survivors. Seattle, WA. University of Washington. In press. 1-29.
20 Bryant RA, Sackville T, Dang ST, et al. Treating acute stress disorder: an evaluation of cognitive behavior therapy and supportive counseling techniques. Am J Psychiatry. Nov. 1999;156(11):1780-6. [pmid: 10553743].
21 Grainger RD, Levin C, Allen-Byrd L, et al. An empirical evaluation of eye movement desensitization and reprocessing (EMDR) with survivors of a natural disaster. J Trauma Stress. Oct. 1997;10(4):665-71. [pmid: 9391949].
22 Carlier IVE, Lamberts RD, Van Uchelen AJ, et al. Disaster-related post-traumatic stress in police officers: a field study of the impact of debriefing. Stress Medicine. 1998;14(3):143-8.
23 Eid J, Johnsen BH, Weisaeth L. The effects of group psychological debriefing on acute stress reactions following a traffic accident: a quasi-experimental approach. Int J Emerg Ment Health. Summer. 2001;3(3):145-54. [pmid: 11642192].
24 Foa EB, Hearst-Ikeda D, Perry KJ. Evaluation of a brief cognitive-behavioral program for the prevention of chronic PTSD in recent assault victims. J Consult Clin Psychol. Dec. 1995;63(6):948-55. [pmid: 8543717].
25 Frappell-Cooke W, Gulina M, Green K, et al. Does trauma risk management reduce psychological distress in deployed troops?. Occup Med (Lond). Dec. 2010;60(8):645-50. [pmid: 20889815].
26 Gelpin E, Bonne O, Peri T, et al. Treatment of recent trauma survivors with benzodiazepines: a prospective study. J Clin Psychiatry. Sep. 1996;57(9):390-4. [pmid: 9746445].
27 Jotzo M, Poets CF. Helping parents cope with the trauma of premature birth: an evaluation of a trauma-preventive psychological intervention. Pediatrics. 2005;(4):915-9. [pmid: 15805364].
28 Krauseneck T, Padberg F, Roozendaal B, et al. A β-adrenergic antagonist reduces traumatic memories and PTSD symptoms in female but not in male patients after cardiac surgery. Psychol Med. 2010;40(5):861-9. [pmid: 19691871].
29 Peres JF, Foerster B, Santana LG, et al. Police officers under attack: resilience implications of an fMRI study. J Psychiatr Res. Jun. 2011;45(6):727-34. [pmid: 21159352].
30 Peris A, Bonizzoli M, Iozzelli D, et al. Early intra-intensive care unit psychological intervention promotes recovery from post traumatic stress disorders, anxiety and depression symptoms in critically ill patients. Critical Care. 2011;15(1).
31 Richards D. A field study of critical incident stress debriefing versus critical incident stress management. Journal of Mental Health. 2001;10(3):351-62.
32 Rothbaum BO, Houry D, Heekin MH, et al. A pilot study of an exposure-based intervention in the ED designed to prevent posttraumatic stress disorder. Am J Emerg Med. 2008;26(3):326-30. [pmid: 18358945].
33 Vaiva G, Ducrocq F, Jezequel K, et al. Immediate treatment with propranolol decreases posttraumatic stress disorder two months after trauma. Biol Psychiatry. 2003;54(9):947-9. [pmid: 14573324].
34 Vijayakumar L, Kumar MS. Trained volunteer-delivered mental health support to those bereaved by Asian tsunami--an evaluation. Int J Soc Psychiatry. Jul. 2008;54(4):293-302. [pmid: 18720890].
35 Acierno R, Rheingold AA, Resnick HS, et al. Preliminary evaluation of a video-based intervention for older adult victims of violence. J Trauma Stress. Dec. 2004;17(6):535-41. [pmid: 15730073].
36 Adler AB, Litz BT, Castro CA, et al. A group randomized trial of critical incident stress debriefing provided to U.S. peacekeepers. J Trauma Stress. Jun. 2008;21(3):253-63. [pmid: 18553407].
37 Adler AB, Bliese PD, McGurk D, et al. Battlemind debriefing and battlemind training as early interventions with soldiers returning from iraq: Randomization by platoon. J Consult Clin Psychol. Oct. 2009;77(5):928-40. [pmid: 19803572].
38 Brom D, Kleber RJ, Hofman MC. Victims of traffic accidents: incidence and prevention of post-traumatic stress disorder. J Clin Psychol. 1993;(2):131-40. [pmid: 8486794].
39 Bryant RA, Moulds ML, Nixon RV. Cognitive behaviour therapy of acute stress disorder: a four-year follow-up. Behav Res Ther. Apr. 2003;41(4):489-94. [pmid: 12643970].
40 Bryant RA, Moulds ML, Nixon RD, et al. Hypnotherapy and cognitive behaviour therapy of acute stress disorder: a 3-year follow-up. Behav Res Ther. Sep. 2006;44(9):1331-5. [pmid: 16368074].
41 Bugg A, Turpin G, Mason S, et al. A randomised controlled trial of the effectiveness of writing as a self-help intervention for traumatic injury patients at risk of developing post-traumatic stress disorder. Behav Res Ther. Jan. 2009;47(1):6-12. [pmid: 19012880].
42 Crespo M, Arinero M. Assessment of the efficacy of a psychological treatment for women victims of violence by their intimate male partner. Span J Psychol. Nov. 2010;13(2):849-63. [pmid: 20977033].
43 Deahl M, Srinivasan M, Jones N, et al. Preventing psychological trauma in soldiers: the role of operational stress training and psychological debriefing. Br J Med Psychol. Mar. 2000;73(Pt 1):77-85. [pmid: 10759052].
44 Foa EB, Zoellner LA, Feeny NC. An evaluation of three brief programs for facilitating recovery after assault. J Trauma Stress. Feb. 2006;19(1):29-43. [pmid: 16568461].
45 Freyth C, Elsesser K, Lohrmann T, et al. Effects of additional prolonged exposure to psychoeducation and relaxation in acute stress disorder. J Anxiety Disord. Dec. 2010;24(8):909-17. [pmid: 20650600].
46 Gidron Y, Gal R, Freedman S, et al. Translating research findings to PTSD prevention: results of a randomized-controlled pilot study. J Trauma Stress. Oct. 2001;14(4):773-80. [pmid: 11776423].
47 Hobbs M, Mayou R, Harrison B, et al. A randomised controlled trial of psychological debriefing for victims of road traffic accidents. BMJ. Dec. 7. 1996;313(7070):1438-9. [pmid: 8973231].
48 Holmes A, Hodgins G, Adey S, et al. Trial of interpersonal counselling after major physical trauma. Aust N Z J Psychiatry. Nov. 2007;41(11):926-33. [pmid: 17924246].
49 Kenardy J, Thompson K, Le Brocque R, et al. Information-provision intervention for children and their parents following pediatric accidental injury. Eur Child Adolesc Psychiatry. Aug. 2008;17(5):316-25. [pmid: 18350366].
50 Pitman RK, Sanders KM, Zusman RM, et al. Pilot study of secondary prevention of posttraumatic stress disorder with propranolol. Biol Psychiatry. Jan. 15. 2002;51(2):189-92. [pmid: 11822998].
51 Resnick HS, Acierno RE, Holmes MM, et al. Prevention of post-rape psychopathology: preliminary findings of a controlled acute rape treatment study. J Anxiety Disord. 1999;13(4):359-70. [pmid: 10504107].
52 Schelling G, Kilger E, Roozendaal B, et al. Stress doses of hydrocortisone, traumatic memories, and symptoms of posttraumatic stress disorder in patients after cardiac surgery: a randomized study. Biol Psychiatry. Mar. 15. 2004;55(6):627-33. [pmid: 15013832].
53 Schelling G, Briegel J, Roozendaal B, et al. The effect of stress doses of hydrocortisone during septic shock on posttraumatic stress disorder in survivors. Biol Psychiatry. Dec. 15. 2001;50(12):978-85. [pmid: 11750894].
54 Stein MB, Kerridge C, Dimsdale JE, et al. Pharmacotherapy to prevent PTSD: Results from a randomized controlled proof-of-concept trial in physically injured patients. J Trauma Stress. Dec. 2007;20(6):923-32. [pmid: 18157888].
55 Tecic T, Schneider A, Althaus A, et al. Early short-term inpatient psychotherapeutic treatment versus continued outpatient psychotherapy on psychosocial outcome: a randomized controlled trial in trauma patients. J Trauma. Feb. 2011;70(2):433-41. [pmid: 21057336].
56 Zohar J, Yahalom H, Kozlovsky N, et al. High dose hydrocortisone immediately after trauma may alter the trajectory of PTSD: interplay between clinical and animal studies. Eur Neuropsychopharmacol. 2011;21(11):796-809. [pmid: 21741804].