# Evidence Tables

Evidence Table 1 Characteristics of included trials

Evidence Table 2 Characteristics of samples from included trials

Evidence Table 3 Treatment and control arms from included trials

Evidence Table 4 PTSD incidence and symptom severity scale outcomes

Evidence Table 5 Comorbid conditions, quality of life, impairment, ability to return to work, and perceived utility

Evidence Table 6 Harms and adverse events of included trials

Evidence Table 7 External applicability of included trials

## References

1 Beatty LJ, Koczwara B, Rice J, et al. A randomised controlled trial to evaluate the effects of a self-help workbook intervention on distress, coping and quality of life after breast cancer diagnosis. Med J Aust. Sep. 6. 2010;193(5 Suppl):S68-73. [pmid: 21542450].
2 Bryant RA, Mastrodomenico J, Felmingham KL, et al. Treatment of acute stress disorder: a randomized controlled trial. Arch Gen Psychiatry. Jun. 2008;65(6):659-67. [pmid: 18519824].
3 Bryant RA, Moulds M, Guthrie R, et al. Treating acute stress disorder following mild traumatic brain injury. Am J Psychiatry. Mar. 2003;160(3):585-7. [pmid: 12611847].
4 Bryant RA, Harvey AG, Dang ST, et al. Treatment of acute stress disorder: a comparison of cognitive-behavioral therapy and supportive counseling. J Consult Clin Psychol. Oct. 1998;66(5):862-6. [pmid: 9803707].
5 Bryant RA, Moulds ML, Guthrie RM, et al. The additive benefit of hypnosis and cognitive-behavioral therapy in treating acute stress disorder. J Consult Clin Psychol. Apr. 2005;73(2):334-40. [pmid: 15796641].
6 Campfield KM, Hills AM. Effect of timing of critical incident stress debriefing (CISD) on posttraumatic symptoms. J Trauma Stress. Apr. 2001;14(2):327-40. [pmid: 11469160].
7 Gamble J, Creedy D, Moyle W, et al. Effectiveness of a counseling intervention after a traumatic childbirth: a randomized controlled trial. Birth. Mar. 2005;32(1):11-9. [pmid: 15725200].
8 Melnyk BM, Alpert-Gillis L, Feinstein NF, et al. Creating opportunities for parent empowerment: program effects on the mental health/coping outcomes of critically ill young children and their mothers. Pediatrics. Jun. 2004;113(6):e597-607. [pmid: 15173543].
9 O’Donnell ML, Lau W, Tipping S, et al. Stepped early psychological intervention for posttraumatic stress disorder, other anxiety disorders, and depression following serious injury. J Trauma Stress. Apr. 2012;25(2):125-33. [pmid: 22522725].
10 Rose S, Brewin CR, Andrews B, et al. A randomized controlled trial of individual psychological debriefing for victims of violent crime. Psychol Med. Jul. 1999;29(4):793-9. [pmid: 10473306].
11 Ryding EL, Wiren E, Johansson G, et al. Group counseling for mothers after emergency cesarean section: a randomized controlled trial of intervention. Birth. Dec. 2004;31(4):247-53. [pmid: 15566336].
12 Shalev AY, Ankri YLE, Israeli-Shalev Y, et al. Prevention of posttraumatic stress disorder by early treatment: results from the Jerusalem Trauma Outreach and Prevention Study. Arch Gen Psychiatry. Feb. 2012;69(2):166-76. [pmid: 21969418].
13 Sijbrandij M, Olff M, Reitsma JB, et al. Emotional or educational debriefing after psychological trauma. Randomised controlled trial. Br J Psychiatry. Aug. 2006;189:150-5. [pmid: 16880485].
14 Treggiari MM, Romand JA, Yanez ND, et al. Randomized trial of light versus deep sedation on mental health after critical illness. Crit Care Med. Sep. 2009;37(9):2527-34. [pmid: 19602975].
15 Weis F, Kilger E, Roozendaal B, et al. Stress doses of hydrocortisone reduce chronic stress symptoms and improve health-related quality of life in high-risk patients after cardiac surgery: a randomized study. J Thorac Cardiovasc Surg. Feb. 2006;131(2):277-82. [pmid: 16434254].
16 Grainger RD, Levin C, Allen-Byrd L, et al. An empirical evaluation of eye movement desensitization and reprocessing (EMDR) with survivors of a natural disaster. J Trauma Stress. Oct. 1997;10(4):665-71. [pmid: 9391949].
17 Bryant RA, Sackville T, Dang ST, et al. Treating acute stress disorder: an evaluation of cognitive behavior therapy and supportive counseling techniques. Am J Psychiatry. Nov. 1999;156(11):1780-6. [pmid: 10553743].